# Comparison of Included Studies

Study | USPSTF Review, 2012 | Prevention | | Cessation
Study | USPSTF Review, 2012 | Christakis, 2003^73^ | Thomas, 2007^43^ | PHS, 2008^63^ | Grimshaw, 2009^39^ | Sussman, 2009^61^ | Reason for Exclusion in Current USPSTF Review^†^
Adelman, 2001^123^ | | | | | | X | Classroom based intervention
Ary, 1990^124^ | | | X | | | X | Classroom based intervention
Audrey, 2006^125^ | | | | | | X | Classroom based intervention
Ausems, 2002^85^ | X | | | | | | NA
Aveyard, 2001^26^ | | | | | X | X^*^ | Classroom based intervention
Baskerville, 1993^127^ | | | | | | X | Quasi-experimental
Bauman, 2001^100^ | X | | X | | | X^*^ | NA
Beaglehole, 1978^128^ | | | | | | X | Classroom based intervention
Biglan, 1987^129^ | | | X | | | | Classroom based intervention
Bloor, 1999^130^ | | | | | | X | Classroom based intervention
Brown, 2003^131^ | | | | X | X | X | Adolescents with psychiatric disorders
Chan, 1988^132^ | | | | | X | X | Freshman dorms
Charlton, 1992^133^ | | | | | | X | Classroom based intervention
Cinnomin, 1995^134^ | | | | | | X | Classroom based intervention
Colby, 2005^87^ | X | | | X | X | X | NA
Colby, 2012^104^ | X | | | | | | NA
Coleman-Wallace, 1999^135^ | | | | | | X | Quasi-experimental
Connell, 2007^136^ | | | X | | | | Classroom based intervention
Cullen, 1996^137^ | | | X | | | | Long-term followup for child behavior disorders
Curry, 2003^11^ | X | | X | | | | NA
Diguisto, 1994^138^ | | | | | | X | Quasi-experimental
Dino, 1998^139^ | | | | | | X | Quasi-experimental
Dino, 2001 (Prev Med)140 | | | | | X | X | Quasi-experimental
Dino, 2001 (J School Nurs)141 | | | | | | X | Quasi-experimental
Dishion, 1995^142^ | | | X | | | | No relevant outcomes
Elder, 1996^143^ | | | X | | | | School policy intervention
Etter, 1999^144^ | | | | | | X | Quasi-experimental
Fidler, 2001^88^ | X | X | | | | | NA
Forman, 1990^145^ | | | X | | | | Classroom based intervention
Forster, 1998^146^ | | | | | | X | Community intervention
Glasgow, 1999^147^ | | | | | | X | Mean age >18 years
Gray, 2011^89^ | X | | | | | | NA
Greenberg, 1978^148^ | | | | | X | X | Quasi-experimental
Haggerty, 2007^90^ | X | | | | | | NA
Hamilton, 2005^149^ | | | | | | X | Classroom based intervention
Hancock, 2001^150^ | | | | | | X | Community intervention
Hoffman, 2008^151^ | | | | | X | | School intervention
Hollis, 2005^91^ | X | | | | X | X | NA
Horn, 1999^152^ | | | | | | X | School intervention
Horn, 2004^153^ | | | | | X | X | Quasi-experimental
Horn, 2005^154^ | | | | | X | X | Quasi-experimental
Horn, 2005 (Prev Chronic Dis)155 | | | | | | X | Quasi-experimental
Horn, 2007^156^ | | | | X | X | X | High or differential attrition
Horswell, 1997^157^ | | | | | | X | Quasi-experimental
Hotte, 1997^158^ | | | | | | X | Quasi-experimental
Hovell, 1996^81^ | X | X | | | | | NA
Jackson, 2006^92^ | X | | X | | | | NA
Jason, 1982^159^ | | | | | | X | Classroom based intervention
Josendal, 1998^160^ | | | X | | | | Excluded at abstract stage
Kelly, 2006^161^ | | | | | X | | Control group received active intervention
Kentala, 1999^93^ | X | X | | | | X | NA
Killen, 1988 162 | | | | | | X | Classroom based intervention
Killen, 2004^94^ | X | | | | X | | NA
Kohler, 2005^163^ | | | | | | X | Quasi-experimental
Knutsen, 1991^164^ | | | X | | | | Tobacco use not primary target
Kohler, 2008^165^ | | | | | X | X^*^ | Quasi-experimental
Lando, 2007^95^ | X | | | | | X^*^ | NA
Lazovich, 2001^166^ | | | | | | X | Contingency-based court diversion
Lipkus, 2004^167^ | | | | | X | X | Control group received active intervention
Lotecka, 1983^168^ | | | | | | X | Quasi-experimental
Moolchan, 2005^169^ | | | | | X | | High attrition
Muramoto, 2007^96^ | X | | | | X | | NA
Murray, 1994^170^ | | | | | | X | Quasi-experimental
Myers, 2005^171^ | | | | X | X | X | Quasi-experimental
Nutbeam, 1993^172^ | | | X | | | | Classroom based intervention
Olds, 1998^173^ | | | X | | | | Early childhood home visitation targeting children's antisocial behavior
Patten, 2006^174^ | | | | | X | | Control group received active intervention
Pbert, 2006^175^ | | | | | | X | Quasi-experimental
Pbert, 2008^79^ | X | | | | | | NA
Pbert, 2011^80^ | X | | | | | | NA
Perry, 1980^176^ | | | | | | X | Classroom based
Peterson, 1986^177^ | | | | | | X | Quasi-experimental
Peterson, 2009^178^ | | | | | X | | Setting
Prado, 2007^97^ | X | | | | | | NA
Quinlan, 2000^179^ | | | | | | X | Mean age >18 years
Reddy, 2002^180^ | | | X | | | | School intervention
Rigotti, 1997^181^ | | | | | | X | Quasi-experimental
Robinson, 2003^182^ | | | | X | X | X | Population (students violating smoking policy at school)
Rodgers, 2005^183^ | | | | | | X | Mean age >18 years
Salminen, 2005^184^ | | | X | | | | High or differential attrition
Schinke, 2004^185^ | | | X | | | | Tobacco use is not primary target
Sherbot, 2005^186^ | | | | | X | | Followup <6 months
Spoth, 2001^187^ | | | X | | | | School intervention
Spoth, 2002^188^ | | | X | | | | School intervention
Stevens, 2002^98^ | X | X | X | | | | NA
Stoddard, 2005^189^ | | | | | | X | Work site intervention
Storr, 2002^190^ | | | X | | | | Classroom based intervention
Suedfeld, 1972^191^ | | | | | | X | Followup <6 months
Sussman, 1995^192^ | | | | | | X | School intervention
Sussman, 2001^193^ | | | | X | X | | Classroom based
Sussman, 2002^194^ | | | | | | X | Classroom based
Sussman, 2007^195^ | | | | | | X | Classroom based
Winkleby, 2004^196^ | | | | | | X | Classroom based
Woodruff, 2007^197^ | | | | | X | | Setting
Wu, 2003^198^ | | | X | | | | Control group received active intervention
Yiming, 2000^108^ | | | | | | X | Followup <6 months
Zack, 2005^199^ | | | | | | X | School intervention
Zavela, 1991^200^ | | | | | | X | School intervention
Zheng, 2004^201^ | | | | | | X | School intervention
Total | 19 | 4 | 22 | 7 | 24 | 59^‡^

* Cited a publication associated with the same trial.

† Other reasons for exclusion could have applied; only one reason was noted in this table.

‡ The Sussman review had 64 citations in the meta-analysis. One citation was listed six times (once for each cohort presented in the study) and is only listed in this table once.

Abbreviations: NA = not applicable; USPSTF = U.S. Preventive Services Task Force.