# Inclusion/Exclusion Criteria

Category | Inclusion Criteria | Exclusion Criteria
Condition Definition | ■ Use of tobacco, including cigarettes, smokeless tobacco, cigars, and pipes.; ■ A standard definition of tobacco use in adolescents is any use in the past 30 days. However, we will accept different definitions used in included trials, such as any use in the past 7 days, daily users, etc.; ■ Categories of users include never users (never used tobacco at all), former users, experimental or episodic users, and regular users
Population | ■ Humans, all races, ethnicities, cultural groups; ■ Adolescents (ages 13–18 years) and children (ages <13 years); ■ More than 50% of participants ages 18 years or younger OR subgroup of participants ages 18 years or younger are analyzed and reported separately from adults | ■ Adults (ages >18 years), unless adolescent subgroup results reported separately from adult results; ■ Trials limited to children or adolescents with cognitive, substance abuse, mental health, or other health issues that would limit generalizability to general primary care patients; ■ Pregnant adolescents
Interventions | ■ Primary care-relevant* behavioral counseling interventions, including individual, group, phone, or computer-based, including quitlines and health care system-level interventions; ■ May include adjunctive use of nicotine replacement therapy or buproprion (Zyban) or varenicline tartrate (Chantix); ■ Complementary and alternative medicine treatments, such as acupuncture, hypnosis; * Conducted in primary care or judged to be feasible or applicable to primary care:; ■ involves individual-level identification; ■ usually involves primary care staff (primary care physicians, other physicians, nurses, nurse practitioners, physician assistants, or related clinical staff [e.g., health educators, other counselors]), or the intervention is seen as connected to the health care system by participant; ■ delivered to individuals or small groups (15 or less participants, generally no more than 8 group sessions over 12 months); ■ located anywhere, as long as linked to primary care OR primary care referable such that the intervention is conducted as part of a health care setting, or is widely available in the community at a national level | ■ Broad public health or policy interventions; ■ Trials to reduce environmental tobacco exposure as a means for preventing future smoking in children; ■ Trials using peer counseling where individuals are likely to know one another; ■ Trials where participants are highly likely to know one another (i.e., closed social groups) and participant interaction is likely
Comparisons | ■ Usual care; ■ Minimal care (no more than one single brief contact per year, or brief written materials such as pamphlets); ■ No intervention; ■ Attention control; ■ Wait list | Active intervention (more intensive than a single, brief contact per year or brief written materials)
Outcomes | KQ 1; ■ Prevalence or severity of asthma, chronic bronchitis, or other respiratory disorders; ■ Dental/oral health; ■ Adult smoking rate, incidence, or prevalence; KQ 2; ■ Smoking rate, incidence, or prevalence; ■ Smoking cessation; KQ 3; ■ Paradoxical increase in smoking rate, incidence, or prevalence; ■ Demoralization due to failed quit attempt; ■ Depression; ■ Adverse effects of pharmacotherapy or other physical intervention (e.g., acupuncture) | ■ Reduction in amount smoked; ■ Attitudes or knowledge about tobacco
Outcome Assessment | ■ Self-report; ■ Biochemically verified | Population-based smoking rates (i.e., not based on study sample, but on underlying population)
Time Period | Published from 1980 to present | Published prior to 1980
Setting | Primary care, other health care, research clinic/office, dental clinics, school-based health clinics | ■ Schools (other than health clinics delivering primary care); ■ Inpatient; ■ Institutional/residential
Study Geography | Developed countries, rated “very high” using HDI 2010 methodology (http://hdr.undp.org/en/statistics/), including: Andorra, Australia, Austria, Bahrain, Barbados, Belgium, Brunei Darussalam, Canada, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, China (SAR), Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea (Republic of), Liechtenstein, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States | All other countries
Publication Language | English | All other languages
Study design | KQs 1–3 (behaviorally-based only); ■ RCT, GRT, CCT; ■ Minimum 6-month followup postbaseline (24 weeks); KQ 3 (pharmacotherapy or other physical intervention only); ■ RCT, GRT, CCT, comparative observational designs; ■ No minimum followup | KQs1–3 (behaviorally-based only); ■ All other study designs; ■ Less than 6-month followup postbaseline (24 weeks); KQs 1, 2 (pharmacotherapy or other physical intervention only); ■ Nonplacebo controlled; KQ 3 (pharmacotherapy or other physical intervention only); ■ All other study designs
Quality | Fair or Good quality | ■ Poor quality; ■ <60% retention overall

Abbreviations: CCT = case controlled trial; GRT = group randomized trial; HDI = Human Development Index; KQ = key question; RCT = randomized controlled trial.