# Search Results and Progression of Article Inclusion

Figure 1 displays the literature search results and article flow for the review. A total of 4381 articles were identified through database searching, 182 through 3 relevant systematic reviews, and 162 articles were identified through other searching. 2453 articles were screened after duplicates were removed. 111 full-text articles were assessed for eligibility. No articles were included for key question 1. 23 articles (18 trials) were included for key question 2. 24 articles (19 trials) were included for key question 3. This figure is described in the report as follows: “Two investigators independently reviewed 2453 abstracts against prespecified inclusion and exclusion criteria; of those, 111 articles were subsequently evaluated for inclusion.”