# Original Search Strategies

## Smoking Cessation in General

Ovid MEDLINE Without Revisions 1996 to June Week 2 2011,^*^ Ovid MEDLINE Daily Update June 15, 2011, Ovid MEDLINE In-Process and Other Nonindexed Citations June 15, 2011

# | Searches | Results
1 | smoking cessation/ | 13813
2 | “Tobacco Use Disorder”/ | 5208
3 | tobacco.ti,ab. | 38831
4 | smoking.ti,ab. | 84323
5 | cigarette*.ti,ab. | 25508
6 | 3 or 4 or 5 | 113276
7 | cessation.ti,ab. | 27297
8 | quit*.ti,ab. | 51398
9 | “stop*”.ti,ab. | 50675
10 | 7 or 8 or 9 | 122072
11 | 6 and 10 | 16487
12 | 1 or 2 or 11 | 23682
13 | adolescent/ or child/ | 887220
14 | children.ti,ab. | 336279
15 | adolescen*.ti,ab. | 91418
16 | child.ti,ab. | 109223
17 | childhood.ti,ab. | 79525
18 | teen*.ti,ab. | 11300
19 | youth*.ti,ab. | 22371
20 | 13 or 14 or 15 or 16 or 17 or 18 or 19 | 1048657
21 | 12 and 20 | 5711
22 | (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. | 389844
23 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ | 137571
24 | clinical trial*.ti,ab. | 126298
25 | (control* adj3 trial*).ti,ab. | 88513
26 | random*.ti,ab. | 418740
27 | placebo*.ti,ab. | 87129
28 | 22 or 23 or 24 or 25 or 26 or 27 | 796180
29 | 21 and 28 | 1181
30 | limit 29 to english language | 1115
31 | limit 30 to yr=“2009 -Current” | 263

* Search results were updated January 31, 2012.

PsycINFO 2002 to June Week 2 2011,^*^ via Ovid

# | Searches | Results
1 | tobacco.ti,ab,hw,id. | 13110
2 | smoking.ti,ab,hw,id. | 17136
3 | cigarette*.ti,ab,hw,id. | 5912
4 | 1 or 2 or 3 | 19512
5 | cessation.ti,ab,hw,id. | 7153
6 | quit*.ti,ab,hw,id. | 13902
7 | “stop*”.ti,ab,hw,id. | 7199
8 | 5 or 6 or 7 | 24953
9 | 4 and 8 | 6467
10 | (adolescence 13 17 yrs or school age 6 12 yrs).ag. | 145956
11 | (child$ or adolescen$ or teen$ or youth$).ti,ab,hw,id. | 219211
12 | 10 or 11 | 266560
13 | 9 and 12 | 1441
14 | experiment controls/ | 266
15 | controlled trial$.ti,ab,id,hw. | 11159
16 | clinical trial$.ti,ab,id,hw. | 12933
17 | random$.ti,ab,id,hw. | 56753
18 | meta analy*.ti,ab,hw,id. | 8372
19 | metaanaly*.ti,ab,hw,id. | 177
20 | placebo*.ti,ab,id,hw. | 12091
21 | 14 or 15 or 16 or 17 or 18 or 19 or 20 | 75404
22 | 13 and 21 | 233
23 | limit 22 to english language | 230
24 | limit 23 to yr=“2009 -Current” | 56

* Search results were updated January 31, 2012.

## Smoking Cessation Pharmacotherapy

Ovid MEDLINE Without Revisions 1996 to June Week 2 2011,^*^ Ovid MEDLINE Daily Update June 15, 2011, Ovid MEDLINE In-Process and Other Nonindexed Citations June 15, 2011

# | Searches | Results
1 | smoking cessation/ | 13813
2 | “Tobacco Use Disorder”/ | 5208
3 | tobacco.ti,ab. | 38831
4 | smoking.ti,ab. | 84323
5 | cigarette*.ti,ab. | 25508
6 | 3 or 4 or 5 | 113276
7 | cessation.ti,ab. | 27297
8 | quit*.ti,ab. | 51398
9 | “stop*”.ti,ab. | 50675
10 | 7 or 8 or 9 | 122072
11 | 6 and 10 | 16487
12 | 1 or 2 or 11 | 23682
13 | (administration dosage or drug effects or drug therapy or pharmacology).fs. | 2065538
14 | Bupropion/ | 1665
15 | Nicotinic Agonists/ | 4433
16 | Bupropion.ti,ab. | 2011
17 | Zyban.ti,ab. | 108
18 | varenicline.ti,ab. | 461
19 | Chantix.ti,ab. | 26
20 | nicotine replacement*.ti,ab. | 1565
21 | nrt.ti,ab. | 870
22 | pharmacotherap*.ti,ab. | 13750
23 | pharmacologic*.ti,ab. | 108055
24 | 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 | 2112112
25 | 12 and 24 | 6301
26 | “Tobacco Use Disorder”/dt [Drug Therapy] | 574
27 | 25 or 26 | 6301
28 | adolescent/ or child/ | 887220
29 | children.ti,ab. | 336279
30 | adolescen*.ti,ab. | 91418
31 | child.ti,ab. | 109223
32 | childhood.ti,ab. | 79525
33 | teen*.ti,ab. | 11300
34 | youth*.ti,ab. | 22371
35 | 28 or 29 or 30 or 31 or 32 or 33 or 34 | 1048657
36 | 27 and 35 | 865
37 | (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. | 389844
38 | case-control studies/ or retrospective studies/ or cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ | 854724
39 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ | 137571
40 | clinical trial*.ti,ab. | 126298
41 | (control* adj3 trial*).ti,ab. | 88513
42 | random*.ti,ab. | 418740
43 | placebo*.ti,ab. | 87129
44 | case control*.ti,ab. | 47703
45 | cohort.ti,ab. | 144411
46 | longitudinal.ti,ab. | 75788
47 | follow up.ti,ab. | 348066
48 | followup.ti,ab. | 9614
49 | prospective*.ti,ab. | 261358
50 | retrospective*.ti,ab. | 227199
51 | comparison group*.ti,ab. | 6979
52 | control group*.ti,ab. | 161396
53 | observational.ti,ab. | 45221
54 | nonrandom*.ti,ab. | 8318
55 | database*.ti,ab. | 120808
56 | population*.ti,ab. | 602047
57 | 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 | 2325589
58 | 36 and 57 | 539
59 | limit 58 to english language | 507
60 | limit 59 to yr=“2009 -Current” | 131

* Search results were updated January 31, 2012.

PsycINFO 2002 to June Week 2 2011,^*^ via Ovid

# | Searches | Results
1 | tobacco.ti,ab,hw,id. | 13110
2 | smoking.ti,ab,hw,id. | 17136
3 | cigarette*.ti,ab,hw,id. | 5912
4 | 1 or 2 or 3 | 19512
5 | cessation.ti,ab,hw,id. | 7153
6 | quit*.ti,ab,hw,id. | 13902
7 | “stop*”.ti,ab,hw,id. | 7199
8 | 5 or 6 or 7 | 24953
9 | 4 and 8 | 6467
10 | Drug Therapy/ | 41176
11 | bupropion.ti,ab,hw,id. | 913
12 | zyban.ti,ab,hw,id. | 27
13 | varenicline.ti,ab,hw,id. | 185
14 | chantix.ti,ab,hw,id. | 9
15 | nicotine replacement*.ti,ab,hw,id. | 693
16 | nrt.ti,ab,hw,id. | 350
17 | pharmacotherap*.ti,ab,hw,id. | 4891
18 | pharmacologic*.ti,ab,hw,id. | 13884
19 | 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 | 53349
20 | 9 and 19 | 1340
21 | (adolescence 13 17 yrs or school age 6 12 yrs).ag. | 145956
22 | (child$ or adolescen$ or teen$ or youth$).ti,ab,hw,id. | 219211
23 | 21 or 22 | 266560
24 | 20 and 23 | 122
25 | limit 24 to english language | 118
26 | limit 25 to yr=“2009 -Current” | 30

* Search results were updated January 31, 2012.

## Smoking Prevention

Ovid MEDLINE Without Revisions 1996 to June Week 2 2011,^*^ Ovid MEDLINE Daily Update June 15, 2011, Ovid MEDLINE In-Process and Other Nonindexed Citations June 15, 2011

# | Searches | Results
1 | Smoking/ | 56913
2 | “Tobacco Use Disorder”/ | 5208
3 | smoking.ti,ab. | 84323
4 | tobacco.ti,ab. | 38831
5 | cigarette*.ti,ab. | 25508
6 | 1 or 2 or 3 or 4 or 5 | 127321
7 | prevention & control.fs. | 535454
8 | prevent*.ti,ab. | 513098
9 | initiat*.ti,ab. | 225479
10 | (start* adj3 smok*).ti,ab. | 891
11 | behavio?r* change*.ti,ab. | 10366
12 | behavio?r* intervention*.ti,ab. | 3367
13 | 7 or 8 or 9 or 10 or 11 or 12 | 1093967
14 | 6 and 13 | 32475
15 | adolescent/ or child/ | 887220
16 | children.ti,ab. | 336279
17 | adolescen*.ti,ab. | 91418
18 | child.ti,ab. | 109223
19 | childhood.ti,ab. | 79525
20 | teen*.ti,ab. | 11300
21 | youth*.ti,ab. | 22371
22 | 15 or 16 or 17 or 18 or 19 or 20 or 21 | 1048657
23 | 14 and 22 | 9518
24 | (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. | 389844
25 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ | 137571
26 | clinical trial*.ti,ab. | 126298
27 | (control* adj3 trial*).ti,ab. | 88513
28 | random*.ti,ab. | 418740
29 | 24 or 25 or 26 or 27 or 28 | 785887
30 | 23 and 29 | 1630
31 | limit 30 to english language | 1504
32 | limit 31 to yr=“2002 -Current” | 1092

* Search results were updated January 31, 2012.

PsycINFO 2002 to June Week 2 2011,^*^ via Ovid

# | Searches | Results
1 | tobacco.ti,ab,hw,id. | 13110
2 | smoking.ti,ab,hw,id. | 17136
3 | cigarette*.ti,ab,hw,id. | 5912
4 | 1 or 2 or 3 | 19512
5 | prevent*.ti,ab,hw,id. | 65623
6 | initiat*.ti,ab,hw,id. | 32176
7 | (start* adj3 smok*).ti,ab,hw,id. | 274
8 | behavio?r* change*.ti,ab,hw,id. | 8074
9 | behavio?r* intervention*.ti,ab,hw,id. | 3394
10 | 5 or 6 or 7 or 8 or 9 | 103292
11 | 4 and 10 | 5277
12 | (adolescence 13 17 yrs or school age 6 12 yrs).ag. | 145956
13 | (child$ or adolescen$ or teen$ or youth$).ti,ab,hw,id. | 219211
14 | 12 or 13 | 266560
15 | 11 and 14 | 2463
16 | experiment controls/ | 266
17 | controlled trial$.ti,ab,id,hw. | 11159
18 | clinical trial$.ti,ab,id,hw. | 12933
19 | random$.ti,ab,id,hw. | 56753
20 | meta analy*.ti,ab,hw,id. | 8372
21 | metaanaly*.ti,ab,hw,id. | 177
22 | 16 or 17 or 18 or 19 or 20 or 21 | 71305
23 | 15 and 22 | 314
24 | limit 23 to english language | 306
25 | limit 24 to yr=“2002 -Current” | 306

* Search results were updated January 31, 2012.

## All Questions

PubMed, June 16, 2011, “Publisher” Subset of Articles That Are Not in Ovid

# | Search | Result
11 | #6 OR #8 Limits: English, Publication Date from 2002 to 2012 | 138
10 | #6 OR #8 Limits: English | 166
9 | #6 OR #8 | 175
8 | #4 AND #7 | 141
7 | prevent*[tiab] OR initiat*[tiab] | 1070466
6 | #4 AND #5 | 55
5 | cessation[tiab] OR quit*[tiab] OR stop*[tiab] | 124030
4 | #3 AND publisher[sb] | 421
3 | #1 AND #2 | 17492
2 | children[tiab] OR child[tiab] OR adolescen*[tiab] OR childhood[tiab] OR youth*[tiab] OR teen*[tiab] | 916707
1 | tobacco[tiab] OR smoking[tiab] OR cigarette*[tiab] | 167060

Cochrane Central Register of Controlled Trials (Central), Issue 2 of 4, April 2011, via Wiley

# | Search | Hits
1 | tobacco:ti,ab,kw in Clinical Trials | 2172
2 | smoking:ti,ab,kw in Clinical Trials | 10557
3 | cigarette*:ti,ab,kw in Clinical Trials | 2833
4 | (#1 OR #2 OR #3) | 11171
5 | child*:ti,ab,kw in Clinical Trials | 54883
6 | adolescen*:ti,ab,kw in Clinical Trials | 72149
7 | teen*:ti,ab,kw in Clinical Trials | 597
8 | youth*:ti,ab,kw in Clinical Trials | 1311
9 | (#5 OR #6 OR #7 OR #8) | 104866
10 | (#4 AND #9) | 2138
11 | cessation:ti,ab,kw in Clinical Trials | 5752
12 | quit*:ti,ab,kw in Clinical Trials | 2666
13 | stop*:ti,ab,kw in Clinical Trials | 5720
14 | (#11 OR #12 OR #13) | 12328
15 | (#10 AND #14), from 2009 to 2011 | 111
16 | prevent*:ti,ab,kw in Clinical Trials | 86321
17 | initiat*:ti,ab,kw in Clinical Trials | 11410
18 | (start* NEAR smok*):ti,ab,kw in Clinical Trials | 86
19 | (behavio* NEAR chang*):ti,ab,kw in Clinical Trials | 2964
20 | (behavio* NEAR intervention*):ti,ab,kw in Clinical Trials | 3013
21 | (#16 OR #17 OR #18 OR #19 OR #20) | 98777
22 | (#10 AND #21), from 2002 to 2011 | 597
23 | (#15 OR #22) | 659

DARE (Database of Abstracts of Reviews of Effects) June 16, 2011, via Centre for Reviews and Dissemination

# | Search | Hits
1 | (smoking) OR (tobacco) OR (cigarette*) IN DARE | 515
2 | ((child*) OR (adolescen*) OR (youth*) OR (teen*)) and (Systematic review:ZDT and Bibliographic:ZPS) IN DARE FROM 2002 TO 2011 | 499
3 | ((child*) OR (adolescen*) OR (youth*) OR (teen*)) and (Systematic review:ZDT and Abstract:ZPS) IN DARE FROM 2002 TO 2011 | 1539
4 | #2 OR #3 | 2038
5 | #1 AND #4 | 75

Cochrane Database of Systematic Reviews, Issue 6 of 12, June 2011, via Wiley

# | Search | Hits
1 | tobacco:ti,ab,kw in Cochrane Reviews | 60
2 | smoking:ti,ab,kw in Cochrane Reviews | 124
3 | cigarette*:ti,ab,kw in Clinical Trials in Cochrane Reviews | 21
4 | (#1 OR #2 OR #3) | 127
5 | child*:ti,ab,kw in Cochrane Reviews | 1451
6 | adolescen*:ti,ab,kw in Cochrane Reviews | 290
7 | teen*:ti,ab,kw in Cochrane Reviews | 18
8 | youth*:ti,ab,kw in Cochrane Reviews | 23
9 | (#5 OR #6 OR #7 OR #8) | 1513
10 | (#4 AND #9) | 24

Key
- / = MeSH (MEDLINE) subject heading
- ti = word in title
- ab = word in abstract
- * = truncation
- adj = adjacent
- adj# = adjacent within x number of words
- pt = publication type
- fs = MeSH subheading
- hw = word in subject heading (PsycINFO)
- id = key concept (PsycINFO)