# DISCUSSION

## Summary of Review Findings

As in the 2005 USPSTF review,1, 2 we found no direct evidence on effects of prenatal screening for HIV infection versus no screening on risk of mother-to-child transmission or maternal or infant clinical outcomes. Other evidence reviewed in this update is summarized in Table 5.

Table 5 Summary of Evidence

Main findings from 2005 USPSTF review | Number and type of studies identified for update Overall quality^*^ | Limitations | Consistency | Applicability | Updated findings
Key Question 1. What are the benefits of HIV screening vs. no screening in asymptomatic pregnant women on maternal or child morbidity, mortality, or quality of life or rates of mother-to-child transmission?
No studies | No studies | No studies | No studies | No studies | No study directly compared clinical outcomes (including risk of perinatal transmission) between pregnant women screened and not screened for HIV infection.
Key Question 2a. What is the yield of repeat HIV screening in asymptomatic pregnant women?
No studies | No studies | No studies | No studies | No studies | No study evaluated the yield of repeat prenatal HIV screening compared to one-time screening, or compared the yield of different strategies for repeat screening.
Key Question 2b. What are the adverse effects (including false-positive results and anxiety) of rapid vs. standard HIV testing in asymptomatic pregnant women?
1 observational study reported false-alarm rate of 10% with rapid testing during labor | 2 observational studies^†^ Overall quality: Fair | Few studies; small numbers of HIV-infected women | Consistent | No issues | One large (n=7,753), fair-quality prospective study of women presenting in labor with unknown HIV status (prevalence 0.7%) found the positive predictive value for the rapid test was higher (90% [52/58]) than for the standard test (74% [52/70]). One other, smaller study reported consistent results, but only five HIV cases were identified. No study evaluated adverse clinical consequences of interventions given as a result of false-positive results.
Key Question 3a. What is the effectiveness of newer antiretroviral regimens for reducing mother-to-child transmission?
4 cohort studies found full-course combination antiretroviral therapy associated with substantially lower risk of transmission compared to no antiretrovirals or regimens with fewer drugs (absolute risk 1%–2%) | 4 cohort studies and 6 RCTs Overall quality: Fair | No RCTs of full-course combination antiretroviral therapy in nonresource-poor settings | Consistent | RCTs evaluated shorter-course antiretroviral regimens in primarily breastfeeding women in resource-poor countries | Three cohort studies of antiretroviral therapy conducted in nonbreastfeeding women in the U.S. and Europe confirm the findings from the 2005 USPSTF review that full-course combination antiretroviral therapy is highly effective at reducing risk of mother-to-child transmission (<1% to 2.4% with combination antiretroviral therapy compared to 9% to 22% with no antiretroviral therapy). Shorter courses of antiretroviral therapy are not as effective as full-course regimens, but also reduce risk of mother-to-child transmission.
Key Question 3b. What are the effects of antiretroviral regimens in pregnant, HIV-positive women on long-term maternal morbidity, mortality, or quality of life?
1 study of women originally enrolled in an RCT of zidovudine monotherapy found no adverse maternal outcomes after 4 years | No studies | No studies | No studies | No studies | No new studies evaluated effects of prenatal antiretroviral therapy on long-term maternal clinical outcomes.
Key Question 3c. What are the effects of antiretroviral regimens in pregnant, HIV-positive women on long-term maternal morbidity, mortality, or quality of life?
Pregnancy outcomes
1 meta-analysis and one large cohort study found no clear association between combination antiretroviral therapy use and low birth weight, and mixed evidence on premature delivery | 1 RCT and 10 cohort studies Overall quality: Fair | No RCTs of full-course combination antiretroviral therapy | Some inconsistency | No issues | One RCT and four prospective cohort studies that adjusted for confounders found some antiretroviral regimens associated with increased risk of preterm delivery. Four studies that did not adjust for confounders reported inconsistent results. Cohort studies found no association between antiretroviral therapy use and low birth weight.
Mitochondrial dysfunction
3 cohort studies found in utero antiretroviral exposure associated with laboratory mitochondrial dysfunction, but did not assess clinical effects | 3 cohort studies Overall quality: Fair | No RCTs of full-course combination antiretroviral therapy; studies did not assess clinical outcomes | Consistent | No issues | Three studies evaluated risk of mitochondrial dysfunction following in utero exposure to antiretroviral therapy, but none evaluated clinical outcomes associated with mitochondrial dysfunction.
Congenital abnormalities
1 prospective cohort study found no association between in utero antiretroviral exposure and congenital abnormalities | 4 cohort studies Overall quality: Fair | No RCTs of full-course combination antiretroviral therapy | Consistent | No issues | Four studies found no association between in utero exposure to antiretroviral drugs and risk of congenital abnormalities
Neurodevelopment
1 prospective cohort study found no effect of in utero antiretroviral exposure on neurodevelopment | 2 cohort studies Overall quality: Fair | No RCTs of full-course combination antiretroviral therapy | Consistent | No issues | Two studies found no association between in utero exposure to antiretroviral drugs and neurodevelopment through ages 2 to 3 years.
Other harms of in utero exposure
1 cohort study found no association between in utero exposure to zidovudine and echocardiographic abnormalities | 5 cohort studies Overall quality: Fair | No RCTs of full-course combination antiretroviral therapy; studies of mitochondrial dysfunction and echocardiography abnormalities did not assess clinical outcomes | Consistent | No issues | Four cohort studies found an association between exposure to perinatal antiretroviral therapy and increased risk during infancy of hematological abnormalities and echocardiographic markers of impaired myocardial growth, but the clinical significance of these findings was unclear. One cohort study found no association between exposure to perinatal antiretroviral therapy and increased risk of childhood cancer.
Maternal harms
1 meta-analysis found no association between perinatal zidovudine monotherapy and maternal deaths or long-term harms. 1 study found antiretroviral therapy associated with gestational diabetes. 1 trial found continuous nevirapine associated with serious hepatic or cutaneous toxicity in women with CD4 counts >0.250 × 10^9^ cells/L | 2 cohort studies Overall quality: Fair | No RCTs of full-course combination antiretroviral therapy; not clear if gestational diabetes diagnosed prior to initiation of antiretroviral therapy | Consistent | No issues | 2 cohort studies found an association between antiretroviral therapy during pregnancy and gestational diabetes, but causality was unclear or estimates were not statistically significant.

* “Overall quality” is based on new evidence identified for this update plus previously reviewed evidence.

† One of the observational studies reports longer-term followup from a study included in the prior review.

The 2005 USPSTF review1, 2 found that HIV tests are accurate. The strongest evidence on potential harms associated with rapid testing is from the large MIRIAD study, which found a lower positive predictive value with standard EIA than for a rapid test (74% and 90%, respectively) in a population of women presenting in labor with 0.7 percent prevalence of undiagnosed HIV infection. This could result in unnecessary maternal and fetal exposure to antiretroviral therapy.39 The positive predictive value would be expected to be lower in lower-prevalence populations, potentially resulting in more unnecessary antiretroviral exposure. No study has evaluated the clinical consequences of unnecessary exposure to antiretroviral therapy as a result of an initially false-positive rapid HIV test result, though any such harms would have to be weighed against the potential benefits of prenatal identification and treatment of undiagnosed HIV infection. As in the 2005 USPSTF review, no study has evaluated the yield of repeated HIV screening during pregnancy, which depends on the incidence of new HIV infection.

New cohort studies of antiretroviral therapy conducted in nonbreastfeeding women in the United States and Europe confirm the findings from the 2005 USPSTF review that full-course combination antiretroviral therapy is highly effective at reducing risk of mother-to-child transmission (<1% to 2.4% with combination antiretroviral therapy vs. 9% to 22% with no antiretroviral therapy).56–58 Randomized trials also found low risk of transmission with combination therapy regimens started around the end of the second trimester in breastfeeding African women.60, 63 Shorter courses of antiretroviral therapy are not as effective as full-course regimens, but also reduce risk of mother-to-child transmission compared with historical transmission rates without antiretroviral therapy, and are relevant for women who might be started on therapy late due to delayed diagnosis or treatment.61, 62, 64

Evidence on harms of antiretroviral therapy was also largely consistent with the 2005 USPSTF review. Current evidence continues to suggest that the long-term harms associated with antiretroviral therapy are relatively small. New, primarily observational studies found perinatal antiretroviral therapy associated with increased risk of preterm delivery,72, 74–82 with no clear association with low birth weight,73, 75, 76, 78, 81, 82 congenital abnormalities,59, 93–95 or impaired infant neurodevelopment.96, 97 Although other studies found an association between in utero exposure to antiretroviral therapy and echocardiographic abnormalities,99 hematologic abnormalities,100–102 or markers of mitochondrial dysfunction,90–92 the clinical significance of these findings remains unclear. Evidence on long-term maternal harms associated with short-term exposure to antiretroviral therapy during pregnancy, or antiretroviral therapy started during pregnancy and continued after pregnancy, remains sparse.

## Limitations

We excluded nonEnglish-language articles, which could result in language bias, though we identified no nonEnglish-language studies that would have met inclusion criteria. We could not formally assess for publication bias with graphical or statistical methods because of small numbers of studies and differences in study designs, populations, and outcomes assessed. We included observational studies, which are more susceptible to bias and confounding than well-conducted randomized trials, though we focused on results from studies that performed statistical adjustment for potential confounding. Randomized trials of combination antiretroviral therapy have only been conducted in Africa. The applicability of studies conducted in resource-poor and high-prevalence settings to U.S. practice is likely to be limited due to differences in the antiretroviral drugs evaluated, evaluation of shorter regimens, reliance on breastfeeding, and other factors.

## Emerging Issues

Antiretroviral therapy regimens for use during pregnancy and indications for initiating long-term antiretroviral therapy continue to evolve. Regularly updated guidelines on selection of antiretroviral therapy in pregnant women are available.24

## Future Research

More research is needed on the long-term maternal effects of transient exposure to antiretroviral therapy during pregnancy or use of less-intense antiretroviral regimens during pregnancy. Integrase inhibitors may be a potential option for antiretroviral therapy in women who present late in pregnancy due to potent and rapid virological suppression, but require additional study to determine effects on transmission and safety in pregnancy.110 Children exposed to antiretroviral therapy in utero should continue to be followed to help identify unexpected or emerging long-term harms from combination regimens. More research is also needed to understand the clinical significance of the hematologic abnormalities, echocardiographic abnormalities, and markers of mitochondrial dysfunction observed in some children exposed to antiretroviral therapy.

## Conclusions

In summary, prenatal HIV screening is accurate, and antiretroviral therapy in combination with avoidance of breastfeeding and Cesarean delivery in women with HIV RNA levels >1,000 copies/mL near the time of delivery is effective at reducing risk of mother-to-child transmission. Use of certain antiretroviral therapy regimens during pregnancy may be associated with increased risk of preterm delivery, but more evidence is needed to fully understand short- and long-term maternal and infant effects.