# METHODS

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,37 the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework with the key questions and patient populations, interventions, and outcomes reviewed (Figure). The target population for HIV screening was pregnant women without signs or symptoms of HIV infection.

Figure Analytic Framework for Screening for HIV in Pregnant Women

Key Questions

1. What are the benefits of HIV screening versus no screening in asymptomatic pregnant women on maternal or child morbidity, mortality, or quality of life or rates of mother-to-child transmission?

2a. What is the yield (number of new diagnoses) of repeat HIV screening in asymptomatic pregnant women?

2b. What are the adverse effects (including false-positive results and anxiety) of rapid versus standard HIV testing in asymptomatic pregnant women?

3a. What is the effectiveness of newer antiretroviral regimens for reducing mother-to-child transmission?

3b. What are the effects of antiretroviral regimens in pregnant, HIV-positive women on long-term maternal morbidity, mortality, or quality of life?

3c. What are the harms (including longer-term harms) to the mother or child associated with antiretroviral therapy during pregnancy?

This figure depicts the analytic framework, which outlines the evidence areas covered in the review, including populations, screening, testing, interventions, and outcomes. The population includes pregnant women who are asymptomatic for HIV and screened in settings generalizable to primary care. There is an initial branch in the framework that splits pregnant women into low-risk or high-risk groups after screening, where key question 2a assesses the yield (number of new diagnoses) of repeat HIV screening. Then after HIV testing, the framework further splits patients into HIV positive and negative antibody groups. Harms of rapid versus standard HIV testing are assessed in key question 2b. A subsequent branch splits the framework into those with low CD4 counts or high viral loads and those with high CD4 counts and low viral loads. Key question 3a then assesses the effectiveness of newer antiretroviral regimens for reducing mother-to-child transmission, and key question 3b assesses the effects of antiretroviral regimens in pregnant, HIV-positive women on long-term maternal morbidity, mortality, or quality of life. An arrow from the interventions assesses the harms, including longer-term harms, to the mother or child associated with antiretroviral therapy during pregnancy (key question 3c). Intermediate outcomes of the interventions are improved CD4 counts, viremia, decreased risky behaviors, and future reproductive behaviors. Clinical health outcomes include reduced premature death and disability for women and children, and reduced mother-to-child transmission. An overarching arrow from screening to the clinical health outcomes addresses key question 1. A dotted line between the intermediate and clinical health outcomes represents the association between intermediate and clinical health outcomes.

### Key Questions

Key Question 1. What are the benefits of HIV screening versus no screening in asymptomatic pregnant women on maternal or child morbidity, mortality, or quality of life or rates of mother-to-child transmission?

Key Question 2a. What is the yield (number of new diagnoses) of repeat HIV screening in asymptomatic pregnant women?

Key Question 2b. What are the adverse effects (including false-positive results and anxiety) of rapid versus standard HIV testing in asymptomatic pregnant women?

Key Question 3a. What is the effectiveness of newer antiretroviral regimens for reducing mother-to-child transmission?

Key Question 3b. What are the effects of antiretroviral regimens in pregnant, HIV-positive women on long-term maternal morbidity, mortality, or quality of life?

Key Question 3c. What are the harms (including longer-term harms) to the mother or child associated with antiretroviral therapy during pregnancy?

Key question 1 focuses on direct evidence that prenatal screening for HIV infection improves important health outcomes compared with not screening. Such direct evidence on the effectiveness of screening interventions may not be available. Therefore, the remainder of the analytic framework (key questions 2a through 3c) evaluates the chain of indirect evidence needed to link screening for HIV infection with improvement in important health outcomes. Links in the chain of indirect evidence include the performance, yield, and acceptability of the screening test for identifying HIV infection, the effectiveness of interventions for reducing perinatal transmission as well as effects on other clinical outcomes (such as long-term maternal outcomes), and any harms associated with screening and subsequent interventions. The general diagnostic accuracy of standard HIV testing was not re-reviewed for this update, since it is well established as highly accurate.1, 2 Rather, the update focuses on research gaps identified in the prior review, such as harms (including false-positive results and anxiety) of alternative testing methods (rapid vs. standard testing) and the yield of repeat screening. This update also does not re-review effects of avoidance of breastfeeding and elective Cesarean delivery in women with viremia on risk of perinatal transmission, as the effectiveness of these interventions is well established1, 2 and part of standard U.S. practice. Rather, the update focuses on new evidence on effectiveness of combination antiretroviral regimens on perinatal transmission, as well as evidence on long-term clinical outcomes in the mother and harms to either the mother or infant.

## Search Strategies

We searched Ovid MEDLINE from 2004 to June 2012 and the Cochrane Library Database from 2005 through the second quarter of 2012 and reviewed reference lists to identify relevant articles published in English. Search strategies are shown in Appendix A1.

## Study Selection

At least two reviewers independently evaluated each study to determine eligibility for inclusion. We selected studies on the basis of inclusion and exclusion criteria developed for each key question (Appendix A2). Articles were selected for full review if they were about HIV infection in pregnancy, were relevant to a key question, and met the predefined inclusion criteria. We restricted inclusion to English-language articles and excluded studies only published as abstracts. Studies of nonhuman subjects were also excluded, and studies had to include original data.

For all key questions, we included studies of pregnant women without signs or symptoms of HIV infection or HIV-positive pregnant women receiving treatment. For key question 3c, we also included infants exposed to antiretroviral drugs in utero or postnatally. The screening interventions were standard or rapid HIV antibody testing. For treatment interventions, we focused on antiretroviral drug therapy. Outcomes were mother-to-child transmission, morbidity, mortality, quality of life, and harms from antiretroviral therapy (such as adverse pregnancy outcomes; adverse congenital, neurodevelopmental, cardiovascular, metabolic, or hematologic outcomes in exposed children; and adverse clinical outcomes in mothers), including long-term (defined as 1 or more years after birth for women and 2 or more years after birth for children) outcomes. We included randomized, controlled trials and cohort studies for all key questions. For key questions related to harms and other long-term maternal and infant outcomes, we also included case-control studies and intervention series if randomized trials and cohort studies were unavailable or lacking. Although the target intervention was full-course combination antiretroviral regimens (started by the second trimester and continued through delivery, with postnatal treatment of the infant) and the target population was nonbreastfeeding women, we included studies from resource-poor settings that evaluated short-course antiretroviral regimens or breastfeeding populations, as these may provide some information about the effectiveness of antiretroviral therapies in women who present late in pregnancy or about the general effectiveness of combination antiretroviral therapy. Appendix A3 shows the results of our literature search and selection process and Appendix A4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

One investigator abstracted details about the study design, patient population, setting, screening method, treatment regimen, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. Two investigators independently applied criteria developed by the USPSTF37 to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through a consensus process.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each key question (good, fair, poor) using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence.37 Meta-analysis was not attempted as the data could not be pooled, due to differences across studies in design, interventions, populations, and other factors.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners prior to finalization (Appendix A6).