# EVIDENCE AND QUALITY TABLES

Appendix B1 Key Question 2b: Quality Ratings of Diagnostic Accuracy Studies

Appendix B2 Key Question 3a: Evidence Table of Cohort Studies of Mother-to-Child HIV Transmission While Using Antiretroviral Therapy

Appendix B3 Key Question 3a: Quality Ratings of Cohort Studies of Mother-to-Child HIV Transmission While Using Antiretroviral Therapy

Appendix B4 Key Question 3a: Evidence Table of African-Based Randomized, Controlled Trials of Mother-to-Child HIV Transmission While Using Antiretroviral Therapy

Appendix B5 Key Question 3a: Quality Ratings of African-Based Randomized, Controlled Trials of Mother-to-Child HIV Transmission While Using Antiretroviral Therapy

Appendix B6 Key Question 3c: Studies of Adverse Outcomes Associated With Antiretroviral Therapy

Appendix B7 Key Question 3c: Quality Rating of a Randomized, Controlled Trial of Adverse Outcomes Associated With Antiretroviral Therapy

Appendix B8 Key Question 3c: Quality Ratings of Cohort Studies of Adverse Outcomes Associated With Antiretroviral Therapy