# DETAILED METHODS

## Appendix A1 Search Strategies

### All Key Questions

Database: EBM Reviews - Cochrane Database of Systematic Reviews
1. hiv.ti.
2. limit 1 to full systematic reviews
3. antiretroviral.mp. [mp=title, short title, abstract, full text, keywords, caption text]
4. haart.mp. [mp=title, short title, abstract, full text, keywords, caption text]
5. 3 or 4
6. 2 and 5
7. screen$.mp. [mp=title, short title, abstract, full text, keywords, caption text]
8. 2 and 7
9. test$.mp. [mp=title, short title, abstract, full text, keywords, caption text]
10. 2 and 9
11. 6 or 8 or 10
12. limit 11 to last 8 years
13. pregnan$.mp. [mp=title, short title, abstract, full text, keywords, caption text]
14. 12 and 13

### Key Questions 1, 2a, and 2b

Database: Ovid MEDLINE(R) without Revisions
1. exp AIDS Serodiagnosis/
2. exp HIV Seronegativity/
3. exp HIV Antigens/
4. exp HIV/
5. exp HIV Seroprevalence/
6. exp HIV Seropositivity/
7. exp HIV Antibodies/
8. or/2–7
9. exp Mass Screening/
10. 8 and 9
11. 1 or 10
12. (hiv adj1 screen$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
13. 11 or 12
14. 13 and (200406$ or 200407$ or 200408$ or 200409$ or 20041$ or 2005$ or 2006$ or 2007$ or 2008$ or 2009$ or 2010$ or 2011$).ed.
15. limit 14 to English language
16. limit 14 to abstracts
17. 15 or 16
18. limit 17 to humans
19. Pregnancy/
20. pregnan$.mp.
21. 19 or 20
22. 18 and 21

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. exp AIDS Serodiagnosis/
2. exp HIV Seronegativity/
3. exp HIV Antigens/
4. exp HIV/
5. exp HIV Seroprevalence/
6. exp HIV Seropositivity/
7. exp HIV Antibodies/
8. or/2–7
9. exp Mass Screening/
10. 8 and 9
11. 1 or 10
12. (hiv adj1 screen$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13. 11 or 12
14. limit 13 to yr=“2004 -Current”
15. Pregnancy/
16. 14 and 15

### Key Question 3a

Database: Ovid MEDLINE(R) without Revisions
1. Antiretroviral Therapy, Highly Active/
2. haart.mp.
3. 1 or 2
4. Anti-HIV Agents/
5. 3 or 4
6. Infectious Disease Transmission, Vertical/
7. HIV Infections/tm [Transmission]
8. 6 or 7
9. 5 and 8
10. Pregnancy/
11. 9 and 10
12. limit 11 to English language
13. limit 11 to abstracts
14. 12 or 13
15. limit 14 to yr=“2004 -Current”

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. Antiretroviral Therapy, Highly Active/
2. haart.mp.
3. 1 or 2
4. Anti-HIV Agents/
5. 3 or 4
6. Infectious Disease Transmission, Vertical/
7. HIV Infections/tm [Transmission]
8. 6 or 7
9. 5 and 8
10. Pregnancy/
11. 9 and 10
12. limit 11 to yr=“2004 -Current”

### Key Question 3b and 3c

Database: Ovid MEDLINE(R) without Revisions
1. Antiretroviral Therapy, Highly Active/
2. Anti-HIV Agents/
3. haart.mp.
4. or/1–3
5. Pregnancy/
6. 4 and 5
7. limit 6 to yr=“2004 - Current”
8. limit 7 to English language
9. limit 7 to abstracts
10. 8 or 9
11. 10 not (letter or editorial or comment or case reports).pt.

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. Antiretroviral Therapy, Highly Active/
2. Anti-HIV Agents/
3. haart.mp.
4. or/1–3
5. Pregnancy/
6. 4 and 5
7. limit 6 to yr= “2004 -Current”

## Appendix A2 Inclusion and Exclusion Criteria per Key Question

| Include | Exclude
All Key Questions
Settings | Primary care or other settings generalizable to primary care (e.g., family planning clinics, school-based health clinics), other health care settings in which screening is commonly performed (e.g., emergency room or urgent care). Focus on studies conducted in the United States and other developed countries, except for randomized trials of antiretroviral therapies (Africa). | Developing countries, unless fair- or good-quality trials and studies in the United States are lacking
Key Question 1: What are the benefits of HIV screening vs. no screening in asymptomatic pregnant women on maternal or child morbidity, mortality, or quality of life or rates of mother-to-child transmission?
Populations | Asymptomatic pregnant women; neonates, infants, and children who were exposed to ART in utero | Known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Comparisons | HIV screening versus no screening
Outcomes | Mother-to-child transmission rates of HIV, mortality related to HIV infection, and quality of life for mothers and their newborns | Pharmacokinetics
Study designs | Randomized, controlled trials and controlled observational studies | Modeling studies
Key Question 2a: What is the yield of repeat HIV screening in asymptomatic pregnant women?
Populations | Asymptomatic pregnant women | Known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Comparisons | Repeat HIV screening during pregnancy versus one-time screening, or screening at one interval versus another interval
Outcomes | Number of positive test results
Study designs | Randomized, controlled trials and controlled observational studies | Modeling studies
Key Question 2b: What are the adverse effects (including false-positive results and anxiety) of rapid vs. standard HIV testing in asymptomatic pregnant women?
Populations | Asymptomatic pregnant women | Known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Comparisons | Rapid versus standard HIV testing
Outcomes | False-positive results, anxiety, and effects of labeling; partner discord, abuse, or violence
Study designs | Randomized, controlled trials and comparative observational studies | Modeling studies
Key Question 3a: What is the effectiveness of newer antiretroviral regimens for reducing mother-to-child transmission?
Populations | Pregnant women with HIV; neonates and infants who were exposed to antiretroviral regimens in utero | Women already or previously on ART prior to pregnancy; acute HIV or HIV subtypes
Interventions | Newer antiretroviral regimens | Discontinuing ART during pregnancy; treatment interruption
Comparisons | Newer antiretroviral regimens versus placebo, older antiretroviral regimens, or one another
Outcomes | Mother-to-child transmission rates of HIV
Study designs | Randomized, controlled trials and controlled observational studies | Modeling studies
Key Question 3b: What are the effects of antiretroviral regimens in pregnant, HIV-positive women on long-term maternal morbidity, mortality, or quality of life?
Populations | Women who were on antiretroviral regimens while pregnant | Women already or previously on ART prior to pregnancy; acute HIV or HIV subtypes
Interventions | Newer antiretroviral regimens | Discontinuing ART during pregnancy; treatment interruption
Comparisons | Newer antiretroviral regimens versus placebo, older antiretroviral regimens, or one another
Outcomes | Long-term maternal morbidity, mortality, or quality of life | Pharmacokinetics
Study designs | Any
Timing | One or more years after giving birth | Less than 1 year after giving birth
Key Question 3c: What are the harms (including longer-term harms) to the mother or child associated with antiretroviral therapy during pregnancy?
Populations | Women who were on antiretroviral regimens while pregnant; neonates, infants, and children who were exposed to antiretroviral therapy in utero | Women already or previously on antiretroviral therapy prior to pregnancy; acute HIV or HIV subtypes
Interventions | Newer antiretroviral regimens | Discontinuing antiretroviral therapy during pregnancy; treatment interruption
Comparisons | Newer antiretroviral regimens versus placebo, older antiretroviral regimens, or one another
Outcomes | Harmful effects on pregnancy outcomes, neonatal outcomes, or effects on exposed children; long-term cardiovascular and metabolic maternal outcomes | Pharmacokinetics
Study designs | Any
Timing | Any

## Appendix A3 Literature Flow Diagram

^*^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^†^ Other sources include reference lists, suggestions from peer reviewers.

^‡^ Some articles are included for more than one key question.

Appendix A3 is a flow chart that summarizes the search and selection of articles related to HIV screening in pregnant women. Citations were identified through bibliographic databases, including MEDLINE, Cochrane Central Register of Controlled Trials, and Cochrane Database of Systematic Reviews, as well as through other sources, including experts and reference lists. There were 1,636 abstracts of potentially relevant articles reviewed. After excluding 1,249 abstracts and titles and articles from other sources that were not relevant to key questions, 387 full-text articles were retrieved for further review. A total of 344 full-text articles were excluded for the following reasons: wrong population (69), wrong intervention (32), wrong outcome (84), wrong study design for key question (30), no original data (106), out of scope (10), sample size too small (8), and systematic review, not directly included (5). For key question 1, no studies were included. For key question 2a, no studies were included. For key question 2b, 2 studies were included. For key question 3a, 10 studies were included. For key question 3b, no studies were included. For key question 3c, 27 studies were included, specifically 11 studies on preterm/other birth outcomes, 3 studies on mitochrondrial effects, 4 studies on congenital abnormalities, 2 studies on infant neurodevelopment, 5 studies on other infant harms, and 2 studies on maternal harms.

## Appendix A4 Excluded Studies List

### Wrong Population

Alrajhi A, Edathodu J, Halim M, Dahham M. Mother-to-child transmission of HIV: experience at a referral hospital in Saudi Arabia. Ann Saudi Med. 2010;30:15-7. [pmid: 20103953].
Aluisio A, Richardson BA, Bosire R, John-Stewart G, Mbori-Ngacha D, Farquhar C. Male antenatal attendance and HIV testing are associated with decreased infant HIV infection and increased HIV-free survival. J Acquir Immune Defic Syndr. 2011;56(1):76-82. [pmid: 21084999].
Asavapiriyanont S, Kasiwat S. Prevalence of low birthweight infants in HIV-infected women delivered in Rajavithi Hospital. J Med Assoc Thai. 2011;94(Suppl 2):S66-70. [pmid: 21717881].
Azcoaga-Lorenzo A, Ferreyra C, Alvarez A, Palma PP, Velilla E, del Amo J. Effectiveness of a PMTCT programme in rural Western Kenya. AIDS Care. 2011;23(3):274-80. [pmid: 21347890].
Becker S, Mlay R, Schwandt HM, Lyamuya E. Comparing couples’ and individual voluntary counseling and testing for HIV at antenatal clinics in Tanzania: a randomized trial. AIDS Behav. 2010;14(3):558-66. [pmid: 19763813].
Betancourt TS, Abrams EJ, McBain R, Fawzi MC. Family-centred approaches to the prevention of mother to child transmission of HIV. J Int AIDS Soc. 2010;13(2). [pmid: 20573284].
Black V, Hoffman RM, Sugar CA, Menon P, Venter F, Currier JS, et al. Safety and efficacy of initiating highly active antiretroviral therapy in an integrated antenatal and HIV clinic in Johannesburg, South Africa. J Acquir Immune Defic Syndr. 2008;49(3):276-81. [pmid: 18845949].
Black V, von Mollendorf CE, Moyes JA, Scott LE, Puren A, Stevens WS. Poor sensitivity of field rapid HIV testing: implications for mother-to-child transmission programme. BJOG. 2009;116(13):1805-8. [pmid: 19781042].
Boer K, Nellen JF, Patel D, Timmermans S, Tempelman C, Wibaut M, et al. The AmRo study: pregnancy outcome in HIV-1-infected women under effective highly active antiretroviral therapy and a policy of vaginal delivery. BJOG. 2007;114(2):148-55. [pmid: 17305888].
Bracher L, Valerius NH, Rosenfeldt V, Herlin T, Fisker N, Nielsen H, et al. Long-term effectiveness of highly active antiretroviral therapy (HAART) in perinatally HIV-infected children in Denmark. Scand J Infect Dis. 2007;39(9):799-804. [pmid: 17701719].
Briand N, Le Coeur S, Traisathit P, Karnchanamayul V, Hansudewechakul R, Ngampiyasakul C, et al. Growth of human immunodeficiency virus-uninfected children exposed to perinatal zidovudine for the prevention of mother-to-child human immunodeficiency virus transmission. Pediatr Infect Dis J. 2006;25(4):325-32. [pmid: 16567984].
Bussmann H, Wester CW, Wester CN, Lekoko B, Okezie O, Thomas AM, et al. Pregnancy rates and birth outcomes among women on efavirenz-containing highly active antiretroviral therapy in Botswana. J Acquir Immune Defic Syndr. 2007;45(3):269-73. [pmid: 17450102].
Casula M, Bosboom-Dobbelaer I, Smolders K, Otto S, Bakker M, de Baar MP, et al. Infection with HIV-1 induces a decrease in mtDNA. J Infect Dis. 2005;191(9):1468-71. [pmid: 15809905].
Casula M, Weverling GJ, Wit FW, Timmermans EC, Stek M, Lange JM, et al. Mitochondrial DNA and RNA increase in peripheral blood mononuclear cells from HIV-1-infected patients randomized to receive stavudine-containing or stavudine-sparing combination therapy. J Infect Dis. 2005;192(10):1794-800. [pmid: 16235179].
Chama C, Gashau W, Oguche S. The value of highly active antiretroviral therapy in the prevention of mother-to-child transmission of HIV. J Obstet Gynaecol. 2007;27(2):134-7. [pmid: 17454457].
Chatterjee A, Bosch RJ, Kupka R, Hunter DJ, Msamanga GI, Fawzi WW. Predictors and consequences of anaemia among antiretroviral-naive HIV-infected and HIV-uninfected children in Tanzania. Public Health Nutr. 2010;13(2):289-96. [pmid: 19650963].
Chi BH, Sinkala M, Stringer EM, Cantrell RA, Mtonga V, Bulterys M, et al. Early clinical and immune response to NNRTI-based antiretroviral therapy among women with prior exposure to single-dose nevirapine. AIDS. 2007;21(8):957-64. [pmid: 17457089].
Ching N, Deville JG, Nielsen KA, Ank B, Wei LS, Sim MS, et al. Cellular and humoral immune responses to a tetanus toxoid booster in perinatally HIV-1-infected children and adolescents receiving highly active antiretroviral therapy (HAART). Eur J Pediatr. 2007;166(1):51-6. [pmid: 16868780].
Ciaranello AL, Perez F, Maruva M, Chu J, Engelsmann B, Keatinge J, et al. WHO 2010 guidelines for prevention of mother-to-child HIV transmission in Zimbabwe: modeling clinical outcomes in infants and mothers. PLoS One. 2011;6(6):e20224. [pmid: 21655097].
Coovadia A, Abrams EJ, Stehlau R, Meyers T, Martens L, Sherman G, et al. Reuse of nevirapine in exposed HIV-infected children after protease inhibitor–based viral suppression. JAMA. 2010;304(10):1082-90. [pmid: 20823434].
Coovadia HM, Brown ER, Fowler MG, Chipato T, Moodley D, Manji K, et al. Efficacy and safety of an extended nevirapine regimen in infant children of breastfeeding mothers with HIV-1 infection for prevention of postnatal HIV-1 transmission (HPTN 046): a randomised, double-blind, placebo-controlled trial. Lancet. 2012;379(9812):221-8. [pmid: 22196945].
Dabis F, Elenga N, Meda N, Leroy V, Viho I, Manigart O, et al. 18-Month mortality and perinatal exposure to zidovudine in West Africa. AIDS. 2001;15(6):771-9. [pmid: 11371692].
Danel C, Moh R, Anzian A, Abo Y, Chenal H, Guehi C, et al. Tolerance and acceptability of an efavirenz-based regimen in 740 adults (predominantly women) in West Africa. J Acquir Immune Defic Syndr. 2006;42(1):29-35. [pmid: 16763490].
Darin N, Oldfors A, Moslemi A-R, Holme E, Tulinius M. The incidence of mitochondrial encephalomyopathies in childhood: Clinical features and morphological, biochemical, and DNA abnormalities. Ann Neurol. 2001;49(3):377-83. [pmid: 11261513].
Davies MA, Moultrie H, Eley B, Rabie H, Van Cutsem G, Giddy J, et al. Virologic failure and second-line antiretroviral therapy in children in South Africa--the IeDEA Southern Africa collaboration. J Acquir Immune Defic Syndr. 2011;56(3):270-8. [pmid: 21107266].
Dryden-Peterson S, Shapiro RL, Hughes MD, Powis K, Ogwu A, Moffat C, et al. Increased risk of severe infant anemia after exposure to maternal HAART, Botswana. J Acquir Immune Defic Syndr. 2011;56(5):428-36. [pmid: 21266910].
Ekouevi DK, Coffie PA, Becquet R, Tonwe-Gold B, Horo A, Thiebaut R, et al. Antiretroviral therapy in pregnant women with advanced HIV disease and pregnancy outcomes in Abidjan, Cote d’Ivoire. AIDS. 2008;22(14):1815-20. [pmid: 18753864].
Ekouevi DK, Coffie PA, Ouattara E, Moh R, Amani-Bosse C, Messou E, et al. Pregnancy outcomes in women exposed to efavirenz and nevirapine: an appraisal of the IeDEA West Africa and ANRS Databases, Abidjan, Cote d’Ivoire. J Acquir Immune Defic Syndr. 2011;56(2):183-7. [pmid: 21084995].
Farquhar C, Kiarie JN, Richardson BA, Kabura MN, John FN, Nduati RW, et al. Antenatal couple counseling increases uptake of interventions to prevent HIV-1 transmission. J Acquir Immune Defic Syndr. 2004;37(5):1620-6. [pmid: 15577420].
Geddes R, Giddy J, Butler LM, Van Wyk E, Crankshaw T, Esterhuizen TM, et al. Dual and triple therapy to prevent mother-to-child transmission of HIV in a resource-limited setting--lessons from a South African programme. S Afr Med J. 2011;101(9):651-4. [pmid: 21920158].
Gumbo FZ, Kandawasvika GQ, Duri K, Mapingure MP, Kurewa NE, Nathoo K, et al. Reduced HIV transmission at subsequent pregnancy in a resource-poor setting. Trop Doct. 2011;41(3):132-5. [pmid: 21576348].
Herman JS, Easterbrook PJ. The metabolic toxicities of antiretroviral therapy. Int J STD AIDS. 2001;12(9):555-64. [pmid: 11516363].
Hernandez S, Moren C, Lopez M, Coll O, Cardellach F, Gratacos E, et al. Perinatal outcomes, mitochondrial toxicity and apoptosis in HIV-treated pregnant women and in-utero-exposed newborn. AIDS. 2012;26(4):419-28. [pmid: 22156962].
Hughes CA, Zuk D, Foisy M, Robinson J, Singh AE, Houston S. Prenatal screening and perinatal HIV transmission in Northern Alberta, 1999–2006. Am J Public Health. 2009;99(2). [pmid: 19372528].
Jackson JB, Musoke P, Fleming T, Guay LA, Bagenda D, Allen M, et al. Intrapartum and neonatal single-dose nevirapine compared with zidovudine for prevention of mother-to-child transmission of HIV-1 in Kampala, Uganda: 18-month follow-up of the HIVNET 012 randomised trial. Lancet. 2003;362(9387):859-68. [pmid: 13678973].
Jao J, Palmer D, Leus I, Tih P, Baweja M, Klotman M, et al. Prevalence and predictors of proteinuria in HIV-infected and uninfected pregnant women in Cameroon. Nephrol Dial Transplant. 2011;26(9):3051-3. [pmid: 21719713].
Joseph O, Biodun O, Michael E. Pregnancy outcome among HIV positive women receiving antenatal HAART versus untreated maternal HIV infection. J Coll Physicians Surg Pak. 2011;21(6):356-9. [pmid: 21711992].
Jungmann EM, Mercey D, DeRuiter A, Edwards S, Donoghue S, Booth T, et al. Is first trimester exposure to the combination of antiretroviral therapy and folate antagonists a risk factor for congenital abnormalities?. Sex Transm Infect. 2001;77(6):441-3. [pmid: 11714944].
Khalsa A, Karim R, Mack W, Minkoff H, Cohen M, Young M, et al. Hypertension in HIV-infected Women Related to HAART: Women’s Interagency HIV Study. 11th Conference on Retroviruses and Opportunistic Infections. 2004. Abstract 741.
Kiarie JN, Kreiss JK, Richardson BA, John-Stewart GC. Compliance with antiretroviral regimens to prevent perinatal HIV-1 transmission in Kenya. AIDS. 2003;17(1):65-71. [pmid: 12478070].
Leroy V, Karon JM, Alioum A, Ekpini ER, van de Perre P, Greenberg AE, et al. Postnatal transmission of HIV-1 after a maternal short-course zidovudine peripartum regimen in West Africa. AIDS. 2003;17(10):1493-501. [pmid: 12824787].
Lindsey JC, Malee KM, Brouwers P, Hughes MD. Neurodevelopmental functioning in HIV-infected infants and young children before and after the introduction of protease inhibitor-based highly active antiretroviral therapy. Pediatrics. 2007;119(3):e681-93. [pmid: 17296781].
Lopez-Vilchez MA, Guxens Junyent M, Mur Mila E, Mur Sierra A. HIV-mother-to-child transmission in a tertiary hospital in the era of generalization of preventive interventions [Spanish]. Med Clin (Barc). 2009;132(13):487-94. [pmid: 19345962].
Machado ES, Hofer CB, Costa TT, Nogueira SA, Oliveira RH, Abreu TF, et al. Pregnancy outcome in women infected with HIV-1 receiving combination antiretroviral therapy before versus after conception. Sex Transm Infect. 2009;85:82-7. [pmid: 18987014].
Matida LH, Santos NJS, Ramos AN Jr, Gianna MC, da Silva MH, Domingues CSB, et al. Eliminating vertical transmission of HIV in Sao Paulo, Brazil: progress and challenges. J Acquir Immune Defic Syndr. 2011;57(Suppl 3):S164-70. [pmid: 21857313].
Miura T, Goto M, Hosoya N, Odawara T, Kitamura Y, Nakamura T, et al. Depletion of mitochondrial DNA in HIV-1-infected patients and its amelioration by antiretroviral therapy. J Med Virol. 2003;70(4):497-505. [pmid: 12794710].
Moodley D, Esterhuizen TM, Pather T, Chetty V, Ngaleka L. High HIV incidence during pregnancy: compelling reason for repeat HIV testing. AIDS. 2009;23(10):1255-9. [pmid: 19455017].
Myers JJ, Modica C, Dufour MS, Bernstein C, McNamara K. Routine rapid HIV screening in six community health centers serving populations at risk. J Gen Intern Med. 2009;24(12):1269-74. [pmid: 19655204].
Ndirangu J, Newell ML, Tanser F, Herbst AJ, Bland R. Decline in early life mortality in a high HIV prevalence rural area of South Africa: evidence of HIV prevention or treatment impact?. AIDS. 2010;24(4):593-602. [pmid: 20071975].
Onyeador N, Patel D, Lyall H. Renal tubular dysfunctionassociated wiht tenofovir-based HAART in perinatally acquired HIV: the need for paediatric formulations and pharmacokinetic studies. HIV Med. 2008;9(Supplement 1):26 (P61).
Ouyang DW, Shapiro DE, Lu M, Brogly SB, French AL, Leighty RM, et al. Increased risk of hepatotoxicity in HIV-infected pregnant women receiving antiretroviral therapy independent of nevirapine exposure. AIDS. 2009;23(18):2425-30. [pmid: 19617813].
Palumbo P, Lindsey JC, Hughes MD, Cotton MF, Bobat R, Meyers T, et al. Antiretroviral treatment for children with peripartum nevirapine exposure. N Engl J Med. 2010;363(16):1510-20. [pmid: 20942667].
Parekh N, Ribaudo H, Souda S, Chen J, Mmalane M, Powis K, et al. Risk factors for very preterm delivery and delivery of very-small-for-gestational-age infants among HIV-exposed and HIV-unexposed infants in Botswana. Int J Gynaecol Obstet. 2011;115(1):20-5. [pmid: 21767835].
Patel K, Ming X, Williams PL, Robertson KR, Oleske JM, Seage GR 3rd, et al. Impact of HAART and CNS-penetrating antiretroviral regimens on HIV encephalopathy among perinatally infected children and adolescents. AIDS. 2009;23(14):1893-901. [pmid: 19644348].
Peixoto MF, Pilotto JH, Stoszek SK, Kreitchmann R, Mussi-Pinhata MM, Melo VH, et al. Lopinavir/ritonavir dosing during pregnancy in Brazil and maternal/infant laboratory abnormalities. Braz J Infect Dis. 2011;15(3):253-61. [pmid: 21670927].
Phanuphak N, Apornpong T, Intarasuk S, Teeratakulpisarn S, Phanuphak P. Toxicities from nevirapine in HIV-infected males and females, including pregnant females with various CD4 cell counts. 12th Conference on Retroviruses and Opportunistic Infections. 2005. Abstract 21.
Powis KM, Smeaton L, Ogwu A, Lockman S, Dryden-Peterson S, van Widenfelt E, et al. Effects of in utero antiretroviral exposure on longitudinal growth of HIV-exposed uninfected infants in Botswana. J Acquir Immune Defic Syndr. 2011;56(2):131-8. [pmid: 21124227].
Ramautarsing RA, van der Lugt J, Gorowara M, Kerr SJ, Burger D, Ruxrungtham K, et al. Thai HIV-1-infected women do not require a dose increase of lopinavir/ritonavir during the third trimester of pregnancy. AIDS. 2011;25(10):1299-303. [pmid: 21516029].
Semrau K, Kuhn L, Vwalika C, Kasonde P, Sinkala M, Kankasa C, et al. Women in couples antenatal HIV counseling and testing are not more likely to report adverse social events. AIDS. 2005;19(6):603-9. [pmid: 15802979].
Singh HK, Gupte N, Kinikar A, Bharadwaj R, Sastry J, Suryavanshi N, et al. High rates of all-cause and gastroenteritis-related hospitalization morbidity and mortality among HIV-exposed Indian infants. BMC Infect Dis. 2011;11:193. [pmid: 21762502].
Szyld E, Warley E, Freimanis L, Gonin R, Cahn P, Calvet GA, et al. Maternal antiretroviral drugs during pregnancy and infant low birth weight and preterm birth. AIDS. 2006;20:2345-53. [pmid: 17117021].
Theron GB, Shapiro DE, Van Dyke R, Cababasay MP, Louw J, Watts DH, et al. Rapid intrapartum or postpartum HIV testing at a midwife obstetric unit and a district hospital in South Africa. Int J Gynaecol Obstet. 2011;113(1):44-9. [pmid: 21251654].
Uusimaa J, Remes AM, Rantala H, Vainionpaa L, Herva R, Vuopala K, et al. Childhood encephalopathies and myopathies: a prospective study in a defined population to assess the frequency of mitochondrial disorders. Pediatrics. 2000;105(3):598-603. [pmid: 10699115].
van der Merwe K, Hoffman R, Black V, Chersich M, Coovadia A, Rees H. Birth outcomes in South African women receiving highly active antiretroviral therapy: a retrospective observational study. J Int AIDS Soc. 2011;14:42. [pmid: 21843356].
van Lettow M, Bedell R, Landes M, Gawa L, Gatto S, Mayuni I, et al. Uptake and outcomes of a prevention-of mother-to-child transmission (PMTCT) program in Zomba district. Malawi BMC Public Health. 2011;11:426. [pmid: 21639873].
Viani RM, Hubbard P, Ruiz-Calderon J, Araneta MR, Lopez G, Chacon-Cruz E, et al. Performance of rapid HIV testing using Determine HIV-1/2 for the diagnosis of HIV infection during pregnancy in Tijuana, Baja California, Mexico. Int J STD AIDS. 2007;18(2):101-4. [pmid: 17331281].
Vyankandondera J, Luchters S, Hassink E, Pakker N, Mmiro F, Okong P, et al. Reducing risk of HIV-1 transmission from mother to infant through breastfeeding using antiretroviral prophylaxis in infants (SIMBA study). 2nd International AIDS Society Conference on HIV Pathogenesis and Treatment. 2003. Abstract LB7.
Wood SM, Shah SS, Steenhoff AP, Rutstein RM. The impact of AIDS diagnoses on long-term neurocognitive and psychiatric outcomes of surviving adolescents with perinatally acquired HIV. AIDS. 2009;23(14):1859-65. [pmid: 19584705].

### Wrong Intervention

Almario CV, Moskowitz EJ, Koran J, Berman B, Pracilio VP, Crawford A, et al. Examining the effectiveness of an opt-in approach to prenatal human immunodeficiency virus screening. Am J Obstet Gynecol. 2010;202(2):159.e1-6. [pmid: 19846053].
Arrive E, Chaix ML, Nerrienet E. The TEmAA ANRS 12109 phase II trial, step 1: tolerance and viral resistance after single dose nevirapine and short course of tenofovir disoproxil fumarate and emtricitabine to prevent mother-to-child transmission of HIV-1. 15th Conference on Retroviruses and Opportunistic Infections. 2008. Abstract 45b.
Bae WH, Wester C, Smeaton LM, Shapiro RL, Lockman S, Onyait K, et al. Hematologic and hepatic toxicities associated with antenatal and postnatal exposure to maternal highly active antiretroviral therapy among infants. AIDS. 2008;22(13):1633-40. [pmid: 18670224].
Baroncelli S, Pinnetti C, Genovese O, Tamburrini E, Floridia M. Hematological effects of zidovudine prophylaxis in newborn infants with and without prenatal exposure to zidovudine. J Med Virol. 2011;83(3):551-6. [pmid: 21264878].
Boer K, Smit C, van der Flier M, de Wolf F. group Acs. The comparison of the performance of two screening strategies identifying newly-diagnosed HIV during pregnancy. Eur J Public Health. 2011;21(5):632-7. [pmid: 21051473].
Chi BH, Wang L, Read JS, Sheriff M, Fiscus S, Brown ER, et al. Timing of maternal and neonatal dosing of nevirapine and the risk of mother-to-child transmission of HIV-1: HIVNET 024. AIDS. 2005;19(16):1857-64. [pmid: 16227794].
Chibwesha CJ, Giganti MJ, Putta N, Chintu N, Mulindwa J, Dorton BJ, et al. Optimal time on HAART for prevention of mother-to-child transmission of HIV. J Acquir Immune Defic Syndr. 2011;58(2):224-8. [pmid: 21709566].
Chintu N, Giganti MJ, Putta NB, Sinkala M, Sadoki E, Stringer EM, et al. Peripartum nevirapine exposure and subsequent clinical outcomes among HIV-infected women receiving antiretroviral therapy for at least 12 months. Trop Med Int Health. 2010;15(7):842-7. [pmid: 20487418].
Dabis F, Bequet L, Ekouevi DK, Viho I, Rouet F, Horo A, et al. Field efficacy of zidovudine, lamivudine and single-dose nevirapine to prevent peripartum HIV transmission. AIDS. 2005;19(3):309-18. [pmid: 15718842].
Dorenbaum A, Cunningham CK, Gelber RD, Culnane M, Mofenson L, Britto P, et al. Two-dose intrapartum/newborn nevirapine and standard antiretroviral therapy to reduce perinatal HIV transmission. JAMA. 2002;288(2):189-98. [pmid: 12095383].
European Collaborative Study. Bailey H, Townsend C, Cortina-Borja M, Thorne C. Insufficient antiretroviral therapy in pregnancy: missed opportunities for prevention of mother-to-child transmission of HIV in Europe. Antivir Ther. 2011;16(6):895-903. [pmid: 21900722].
Forsyth BWC, Barringer SR, Walls TA, Landry ML, Ferguson D, Tinghitella TJ, et al. Rapid HIV testing of women in labor: too long a delay. J Acquir Immune Defic Syndr. 2004;35(2):151-4. [pmid: 14722447].
Galegov GA. Highly efficient chemoprophylaxis of perinatal transmission of HIV 1 infection in HIV-infected pregnant women [Russian]. Antibiot Khimioter. 2009;54(3–4):58-60. [pmid: 19711853].
Giaquinto C, Rampon O, De Rossi A. Antiretroviral therapy for prevention of mother-to-child HIV transmission: focus on single-dose nevirapine. Clin Drug Investig. 2006;26(11):611-27. [pmid: 17163296].
Ivanova ES, Shmagel NG, Vorob’eva NN. Nikavir in chemoprevention regimens for vertical HIV infection transmission [Russian]. Vopr Virusol. 2010;55(2):31-4. [pmid: 20455469].
Kim JY, Zaoutis T, Chu J, Zhao H, Rutstein R. Effects of highly active antiretroviral therapy (HAART) on cholesterol in HIV-1 infected children: a retrospective cohort study. Pharmacoepidemiol Drug Saf. 2009;18(7):589-94. [pmid: 19402031].
Kuhn L, Aldrovandi GM, Sinkala M, Kankasa C, Semrau K, Mwiya M, et al. Effects of early, abrupt weaning on HIV-free survival of children in Zambia. N Engl J Med. 2008;359(2):130-41. [pmid: 18525036].
Kuhn L, Sinkala M, Semrau K, Kankasa C, Kasonde P, Mwiya M, et al. Elevations in mortality associated with weaning persist into the second year of life among uninfected children born to HIV-Infected mothers. Clin Infect Dis. 2010;50(3):437-44. [pmid: 20047479].
Lallemant M, Jourdain G, Le Coeur S, Kim S, Koetsawang S, Comeau AM, et al. A trial of shortened Zidovudine regimens to prevent mother-to-child transmission of human immunodeficiency virus type 1. N Engl J Med. 2000;343(14):982-91. [pmid: 11018164].
Limpongsanurak S, Thaithumyanon P, Chaithongwongwatthana S, Thisyakorn U, Ruxrungtham K, Kongsin P, et al. Short course zidovudine maternal treatment in HIV-1 vertical transmission: randomized controlled multicenter trial. J Med Assoc Thai. 2001;84(Suppl 1):S338-45. [pmid: 11529355].
Marazzi MC, Germano P, Liotta G, Guidotti G, Loureiro S, da Cruz Gomes A, et al. Safety of nevirapine-containing antiretroviral triple therapy regimens to prevent vertical transmission in an African cohort of HIV-1-infected pregnant women. HIV Med. 2006;7(5):338-44. [pmid: 16945080].
Marazzi MC, Palombi L, Nielsen-Saines K, Haswell J, Zimba I, Magid NA, et al. Extended antenatal use of triple antiretroviral therapy for prevention of mother-to-child transmission of HIV-1 correlates with favorable pregnancy outcomes. AIDS. 2011;24;25(13):1611-8. [pmid: 21673553].
McIntyre JA, Martinson N, Gray GE, Hopley M, Kimura T, Robinson P, et al. Addition of short course combivir (CBV) to single dose viramune (sdNVP) for the prevention of mother to child transmission (pMTCT) of HIV-1 can significantly decrease the subsequent development of maternal and paediatric NNRTI-resistant virus. The 3rd IAS Conference on HIV Pathogenesis and Treatment. 2005. Abstract no. TuFo0204.
McIntyre JA, Martinson N, Grey GE, Team TI. Single-dose nevirapine combined with a short course of combivir for prevention of mother to child transmission of HIV-1 can significantly decrease the subsequent development of maternal and infant resistant virus. Antivir Ther. 2005;10(Suppl 1):S4.
Money DM, Khoo D, MacDonald G. A comparison of toxicity in nevirapine vs protease inhibitor-containing HAART regimens in pregnant women. 12th Conference on Retroviruses and Opportunistic Infections. 2005. Abstract 784.
Omer SB. Six Week Extended Dose Nevirapine Study T. Twelve-month follow-up of six week extended dose nevirapine randomized controlled trials: differential impact of extended-dose nevirapine on mother-to-child transmission and infant death by maternal CD4 cell count. AIDS. 2011;25(6):767-76. [pmid: 21330912].
Onen NF, Nurutdinova D, Sungkanuparph S, Gase D, Mondy K, Overton ET. Effect of postpartum HIV treatment discontinuation on long-term maternal outcome. J Int Assoc Physicians AIDS Care. 2008;7(5):245-51. [pmid: 18812593].
Padua E, Almeida C, Nunes B, Cortes Martins H, Castela J, Neves C, et al. Assessment of mother-to-child HIV-1 and HIV-2 transmission: an AIDS reference laboratory collaborative study. HIV Med. 2009;10(3):182-90. [pmid: 19207600].
Pilotto JH, Velasque LS, Friedman RK, Moreira RI, Veloso VG, Grinsztejn B, et al. Maternal outcomes after HAART for the prevention of mother-to-child transmission in HIV-infected women in Brazil. Antivir Ther. 2011;16(3):349-56. [pmid: 21555817].
Stringer JS, Sinkala M, Chapman V, Acosta EP, Aldrovandi GM, Mudenda V, et al. Timing of the maternal drug dose and risk of perinatal HIV transmission in the setting of intrapartum and neonatal single-dose nevirapine. AIDS. 2003;17(11):1659-65. [pmid: 12853748].
Taha TE, Kumwenda N, Gibbons A, Hoover D, Lema V, Fiscus S, et al. Effect of HIV-1 antiretroviral prophylaxis on hepatic and hematological parameters of African infants. AIDS. 2002;16(6):851-8. [pmid: 11919486].
Webber MP, Demas P, Enriquez E, Shanker R, Oleszko W, Beatrice ST, et al. Pilot study of expedited HIV-1 testing of women in labor at an inner-city hospital in New York City. Am J Perinatol. 2001;18(1):49-57. [pmid: 11321245].

### Wrong Outcome

Aaron E, Levine AB, Monahan K, Biondo CP. A rapid HIV testing program for labor and delivery in an inner-city teaching hospital. AIDS Read. 2006;16(1):22-4. [pmid: 16433470].
Antiretroviral Pregnancy Registry Steering Committee. Antiretroviral Pregnancy Registry International Interim Report for 1 January 1989 through 31 July 2007. 2007.
Bardeguez AD, Lindsey JC, Shannon M, Tuomala RE, Cohn SE, Smith E, et al. Adherence to antiretrovirals among US women during and after pregnancy. J Acquir Immune Defic Syndr. 2008;48(4):408-17. [pmid: 18614923].
Bedikou G, Viho I, Tonwe-Gold B, Coffie JP, Amani-Bosse C, Allou G, et al. 6-month immunological response with HAART containing nevirapine in HIV-infected women post exposure to single does of nevirapine for PMTCT. The MTCT-PLUS initiative in Abidjan, Côte D’ivoire (2003–2005). 3rd International AIDS Society Conference on HIV Pathogenesis and Treatment. 2005. Abstract No. MoOa0203.
Beitune PE, Duarte G, Foss MC, Montenegro RM, Spara P, Quintana SM, et al. Effect of antiretroviral agents on carbohydrate metabolism in HIV-1 infected pregnant women. Diabetes Metab Res Rev. 2006;22(1):59-63. [pmid: 16021650].
Bhadrakom C, Simonds RJ, Mei JV, Asavapiriyanont S, Sangtaweesin V, Vanprapar N, et al. Oral zidovudine during labor to prevent perinatal HIV transmission, Bangkok: tolerance and zidovudine concentration in cord blood. AIDS. 2000;14(5):509-16. [pmid: 10780713].
Borges-Almeida E, Milanez HM, Vilela MM, Cunha FG, Abramczuk BM, Reis-Alves SC, et al. The impact of maternal HIV infection on cord blood lymphocyte subsets and cytokine profile in exposed non-infected newborns. BMC Infect Dis. 2011;11:38. [pmid: 21291536].
Bryson Y, Stek A, Mirochnick M, Mofenson L, Connor J, Watts H, et al. Pharmacokinetics, Antiviral Activity, and Safety of Nelfinavir (NFV) with ZDV/3TC in Pregnant HIV-Infected Women and Their Infants: PACTG 353 Cohort 2. 9th Conf Retrovir Oppor Infect. 2002. abstract no. 795-W.
Castejon OC, Lopez AJ, Perez Ybarra LM, Castejon OC. Placental villous lesions in HIV-1 infection treated with zidovudine [Spanish]. Ginecol Obstet Mex. 2011;79(5):269-79. [pmid: 21966815].
Cédric A, Olivier T. Amprenavir or fosamprenavir plus ritonavir in HIV infection: pharmacology, efficacy and tolerability profile. Drugs. 2005;65:633-59. [pmid: 15748098].
Ciccacci C, Borgiani P, Ceffa S, Sirianni E, Marazzi MC, Altan AM, et al. Nevirapine-induced hepatotoxicity and pharmacogenetics: a retrospective study in a population from Mozambique. Pharmacogenomics. 2010;11(1):23-31. [pmid: 20017669].
Clarke SM, Mulcahy F, Healy CM, Condon S, Butler KM. The efficacy and tolerability of combination antiretroviral therapy in pregnancy: infant and maternal outcome. Int J STD AIDS. 2000;11(4):220-3. [pmid: 10772084].
Coovadia A, Marais B, Abrams E, Sherman G, Barry G, Hammer S, et al. Virologic Response to NNRTI Treatment among Women Who Took Single-dose Nevirapine 18 to 36 Months Earlier. 13th Conference on Retroviruses and Opportunistic Infections. 2006.
Cunningham CK, Chaix M-L, Rekacewicz C, Britto P, Rouzioux C, Gelber RD, et al. Development of resistance mutations in women receiving standard antiretroviral therapy who received intrapartum nevirapine to prevent perinatal human immunodeficiency virus type 1 transmission: a substudy of Pediatric AIDS Clinical Trials Group Protocol 316. J Infect Dis. 2002;186(2):181-8. [pmid: 12134253].
Dabis F, Ekouevi DK, Bequet L, Rouet F, Horo A, Fassinou P, et al. A Short Course of Zidovudine + Peripartum Nevirapine is Highly Efficacious in Preventing Mother-to-Child Transmission of HIV-1: The ANRS 1201 DITRAME-plus Study, Abidjan, Cote d’Ivoire. 10th Conference on Retroviruses and Opportunistic Infections. 2003. Abstract 854.
D’Costa GF, Khadke K, Patil YV. Pathology of placenta in HIV infection. Indian J Pathol Microbiol. 2007;50(3):515-9. [pmid: 17883121].
Ekouevi DK, Touré R, Becquet R, Viho I, Sakarovitch C, Rouet F, et al. Serum lactate levels in infants exposed peripartum to antiretroviral agents to prevent mother-to-child transmission of HIV: Agence Nationale de Recherches Sur le SIDA et les Hépatites Virales 1209 Study, Abidjan, Ivory Coast. Pediatrics. 2006;118(4):e1071-e7. [pmid: 16950945].
El Beitune P, Duarte G. Antiretroviral agents during pregnancy: Consequences on hematologic parameters in HIV-exposed, uninfected newborn infant. Eur J Obstet Gynecol Reprod Biol. 2006;128:59-63. [pmid: 16876310].
El Beitune P, Duarte G, Campbell O, Quintana SM, Rodrigues LC. Effects of antiretroviral agents during pregnancy on liver enzymes and amylase in HIV-exposed, uninfected newborn infants. Braz J Infect Dis. 2007;11(3):314-7. [pmid: 17684631].
El-Beitune P, Duarte G, de Morais EN, Campbell O, Spara-Gadelha P, Mauad-Filho F, et al. Antiretroviral agents and acid-base balance at delivery of the neonate. Braz J Med Biol Res. 2007;40(7):957-61. [pmid: 17653449].
Eshleman SH, Guay LA, Mwatha A, Cunningham SP, Brown ER, Musoke P, et al. Comparison of nevirapine (NVP) resistance in Ugandan women 7 days vs. 6–8 weeks after single-dose NVP prophylaxis: HIVNET 012. AIDS Res Hum Retroviruses. 2004;20(6):595-9. [pmid: 15242535].
Eshleman SH, Jackson JB. Nevirapine resistance after single dose prophylaxis. AIDS Rev. 2002;4(2):59-63. [pmid: 12152519].
Feiterna-Sperling C, Weizsaecker K, Buhrer C, Casteleyn S, Loui A, Schmitz T, et al. Hematologic effects of maternal antiretroviral therapy and transmission prophylaxis in HIV-1-exposed uninfected newborn infants. J Acquir Immune Defic Syndr. 45(1):43-51. [pmid: 17356471].
Fiore S, Thorne C, Newell ML. European participation in an international perinatal trial. Med Wieku Rozwoj. 2003;7(4 Pt 1):449-58. [pmid: 15010555].
Gingelmaier A, Eberle J, Kost BP, Bogner JR, Hofmann J, Weissenbacher T, et al. Protease inhibitor-based antiretroviral prophylaxis during pregnancy and the development of drug resistance. Clin Infect Dis. 2010;50(6):890-4. [pmid: 20166821].
Griner R, Williams PL, Read JS, Seage GR 3rd, Crain M, Yogev R, et al. In utero and postnatal exposure to antiretrovirals among HIV-exposed but uninfected children in the United States. AIDS Patient Care STDS. 2011;25(7):385-94. [pmid: 21992592].
Hankin C, Thorne C, Newell ML. Does exposure to antiretroviral therapy affect growth in the first 18 months of life in uninfected children born to HIV-infected women?. J Acquir Immune Defic Syndr. 2005;40(3):364-70. [pmid: 16249713].
Hughes S, Hughes A, Brothers C, Spreen W, Thorborn D. PREDICT-1 (CNA106030): the first powered, prospective trial of pharmacogenetic screening to reduce drug adverse events. Pharm Stat. 2008;7(2):121-9. [pmid: 17534855].
Ibieta MF, Cano JM, Amador JT, Gonzalez-Tome MI, Martin SG, Gomez MN, et al. Growth of uninfected infants exposed to antiretrovirals born to HIV-infected woman [Spanish]. An Pediatr (Barc). 2009;71(4):299-309. [pmid: 19660998].
Katz IT, Shapiro R, Li D, Govindarajulu U, Thompson B, Watts DH, et al. Risk factors for detectable HIV-1 RNA at delivery among women receiving highly active antiretroviral therapy in the women and infants transmission study. J Acquir Immune Defic Syndr. 2010;54(1):27-34. [pmid: 20065861].
Keiser O, Gayet-Ageron A, Rudin C, Brinkhof MW, Gremlich E, Wunder D, et al. Antiretroviral treatment during pregnancy. AIDS. 2008;22(17):2323-30. [pmid: 18981771].
Kuhn L, Trabattoni D, Kankasa C, Sinkala M, Lissoni F, Ghosh M, et al. Hiv-specific secretory IgA in breast milk of HIV-positive mothers is not associated with protection against HIV transmission among breast-fed infants. J Pediatr. 2006;149(5):611-6. [pmid: 17095329].
Kuhn LP, Trabattoni DB, Kankasa CM, Semrau KM, Kasonde PM, Lissoni FM, et al. [alpha]-Defensins in the prevention of HIV transmission among breastfed infants. J Acquir Immune Defic Syndr. 2005;39(2):138-42. [pmid: 15905728].
Kully C, Yerly S, Erb P, Kind C, Krautheim A, Perrin L, et al. Codon 215 mutations in human immunodeficiency virus-infected pregnant women. Swiss Collaborative ‘HIV and Pregnancy’ Study. J Infect Dis. 1999;179(3):705-8. [pmid: 9952382].
Lahoz R, Noguera A, Rovira N, Catala A, Sanchez E, Jimenez R, et al. Antiretroviral-related hematologic short-term toxicity in healthy infants: implications of the new neonatal 4-week zidovudine regimen. Pediatr Infect Dis J. 2010;29(4):376-9. [pmid: 19949355].
Lallemant M, Jourdain G, Le Coeur S, Mary JY, McIntosh K, Ngo-Giang Huong N, et al. Multicenter, randomized RCT, assessing the safety and efficacy of nevirapine in addition to zidovudine for the prevention of prenatal HIV in Thailand: PHPT-2 update. 2nd International AIDS Society Conference on HIV Pathogenesis and Treatment. 2003. Abstract 62.
Lallemant M, Ngo-Giang-Huong N, Jourdain G, Traisaithit P, Cressey TR, Collins IJ, et al. Efficacy and safety of one-month postpartum zidovudine and didanosine to prevent HIV-resistance mutations following intrapartum single-dose nevirapine. Clin Infect Dis. 2010;50(6):898-908. [pmid: 20158398].
Lehman DA, Chung MH, Mabuka JM, John-Stewart GC, Kiarie J, Kinuthia J, et al. Lower risk of resistance after short-course HAART compared with zidovudine/single-dose nevirapine used for prevention of HIV-1 mother-to-child transmission. J Acquir Immune Defic Syndr. 2009;51(5):522-9. [pmid: 19502990].
Lehtovirta P, Skogberg K, Salo E, Ammala P, Ristola M, Suni J, et al. Pregnancy outcome among HIV-infected women in the Helsinki metropolitan area. Acta Obstet Gynecol Scand. 2005;84(10):945-50. [pmid: 16167909].
Livingston EG, Cohn SE, Yang Y, Watts HD, Bardeguez AD, Jones TB, et al. Lipids and lactate in human immunodeficiency virus-1-infected pregnancies with or without protease inhibitor-based therapy. Obstet Gynecol. 2007;110(2, Part 1):391-7. [pmid: 17666616].
Lockman S, Hughes MD, McIntyre J, Zheng Y, Chipato T, Conradie F, et al. Antiretroviral therapies in women after single-dose nevirapine exposure. N Engl J Med. 2010;363(16):1499-509. [pmid: 20942666].
Lockman S, Shapiro RL, Smeaton LM, Wester C, Thior I, Stevens L, et al. Response to antiretroviral therapy after a single, peripartum dose of nevirapine. N Engl J Med. 2007;356(2):135-47. [pmid: 17215531].
Lyons FE, Coughlan S, Byrne CM, Hopkins SM, Hall WW, Mulcahy FM. Emergence of antiretroviral resistance in HIV-positive women receiving combination antiretroviral therapy in pregnancy. AIDS. 2005;19(1):63-7. [pmid: 15627034].
Magder LS, Mofenson L, Paul ME, Zorrilla CD, Blattner WA, Tuomala RE, et al. Risk factors for in utero and intrapartum transmission of HIV. J Acquir Immune Defic Syndr. 2005;38(1):87-95. [pmid: 15608531].
Mandelbrot L, Mazy F, Floch-Tudal C, Meier F, Azria E, Crenn-Hebert C, et al. Atazanavir in pregnancy: impact on neonatal hyperbilirubinemia. Eur J Obstet Gynecol Reprod Biol. 2011;157(1):18-21. [pmid: 21492993].
Manfredi R, Calza L, Chiodo F. Efavirenz versus nevirapine in current clinical practice: a prospective, open-label observational study. J Acquir Immune Defic Syndr. 2004;35(5):492-502. [pmid: 15021314].
Martin F, Navaratne L, Khan W, Sarner L, Mercey D, Anderson J, et al. Pregnant women with HIV infection can expect healthy survival: three-year follow-up. J Acquir Immune Defic Syndr. 2006;43(2):186-92. [pmid: 16940856].
Martinson NA, Ekouevi DK, Dabis F, Morris L, Lupodwana P, Tonwe-Gold B, et al. Transmission rates in consecutive pregnancies exposed to single-dose nevirapine in Soweto, South Africa and Abidjan, Cote d’Ivoire. J Acquir Immune Defic Syndr. 2007;45(2):206-9. [pmid: 17438480].
Martinson NA, Morris L, Johnson J, Gray GE, Pillay V, Ledwaba J, et al. Women exposed to single-dose nevirapine in successive pregnancies: effectiveness and nonnucleoside reverse transcriptase inhibitor resistance. AIDS. 2009;23(7):809-16. [pmid: 19287298].
Mbori-Ngacha D, Nduati R, John G, Reilly M, Richardson B, Mwatha A, et al. Morbidity and mortality in breastfed and formula-fed infants of HIV-1-infected women. JAMA. 2001;286(19):2413-20. [pmid: 11712936].
McConnell M, Bakaki P, Eure C, Mubiru M, Bagenda D, Downing R, et al. Effectiveness of repeat single-dose nevirapine for prevention of mother-to-child transmission of HIV-1 in repeat pregnancies in Uganda. J Acquir Immune Defic Syndr. 2007;46(3):291-6. [pmid: 18167645].
Minkoff H, Ahdieh L, Watts H, Greenblatt RM, Schmidt J, Schneider M, et al. The relationship of pregnancy to the use of highly active antiretroviral therapy. Am J Obstet Gynecol. 2001;184(6):1221-7. [pmid: 11349192].
Mirochnick M, Dorenbaum A, Blanchard S, Cunningham CK, Gelber RD, Mofenson L, et al. Predose infant nevirapine concentration with the two-dose intrapartum neonatal nevirapine regimen: association with timing of maternal intrapartum nevirapine dose. J Acquir Immune Defic Syndr. 2003;33(2):153-6. [pmid: 12794547].
Mirochnick M, Dorenbaum A, Holland D, Cunningham-Schrader B, Cunningham C, Gelber R, et al. Concentrations of protease inhibitors in cord blood after in utero exposure. Pediatr Infect Dis J. 2002;21(9):835-8. [pmid: 12352805].
Mirochnick M, Rodman JH, Robbins BL, Fridland A, Gandia J, Hitti J, et al. Pharmacokinetics of oral zidovudine administered during labour: a preliminary study. HIV Med. 2007;8(7):451-6. [pmid: 17760737].
Mmiro FA, Aizire J, Mwatha AK, Eshleman SH, Donnell D, Fowler MG, et al. Predictors of early and late mother-to-child transmission of HIV in a breastfeeding population: HIV Network for Prevention Trials 012 experience, Kampala, Uganda. J Acquir Immune Defic Syndr. 2009;52(1):32-9. [pmid: 19617849].
Nachman SA, Chernoff M, Gona P, Van Dyke RB, Dankner WM, Seage GR 3rd, et al. Incidence of noninfectious conditions in perinatally HIV-infected children and adolescents in the HAART era. Arch Pediatr Adolesc Med. 2009;163(2):164-71. [pmid: 19188649].
Nasi M, Pinti M, Chiesa E, Fiore S, Manzini S, Del Giovane C, et al. Decreased mitochondrial DNA content in subcutaneous fat from HIV-infected women taking antiretroviral therapy as measured at delivery. Antivir Ther. 2011;16(3):365-72. [pmid: 21555819].
Noguera A, Fortuny C, Munoz-Almagro C, Sanchez E, Vilaseca MA, Artuch R, et al. Hyperlactatemia in human immunodeficiency virus-uninfected infants who are exposed to antiretrovirals. Pediatrics. 2004;114(5). [pmid: 15492359].
Nurutdinova D, Onen NF, Hayes E, Mondy K, Overton ET. Adverse effects of tenofovir use in HIV-infected pregnant women and their infants. Ann Pharmacother. 2008;42(11):1581-5. [pmid: 18957630].
Nyandiko WM, Otieno-Nyunya B, Musick B, Bucher-Yiannoutsos S, Akhaabi P, Lane K, et al. Outcomes of HIV-exposed children in western Kenya: efficacy of prevention of mother to child transmission in a resource-constrained setting. J Acquir Immune Defic Syndr. 2010;54(1):42-50. [pmid: 20224420].
Phanuphak N, Apornpong T, Teeratakulpisarn S, Chaithongwongwatthana S, Taweepolcharoen C, Mangclaviraj S, et al. Nevirapine-associated toxicity in HIV-infected Thai men and women, including pregnant women. HIV Med. 2007;8(6):357-66. [pmid: 17661843].
Phanuphak N, Teeratakulpisarn S, Apornpong T, Phanuphak P, et al. Comparison of hepatic and cutaneous toxicities in pregnant women with baseline CD4 ≤250 cells/mm^3^ versus those with CD4 >250 cells/mm^3^ receiving nevirapine (NVP)-containing highly active anti-retroviral therapy (HAART) for the prevention of mother-to-child transmission (PMTCT) in Thailand. Seventh International Congress on Drug Therapy in HIV Infection. 2004:P322.
Pinnetti C, Baroncelli S, Molinari A, Nardini G, Genovese O, Ricerca BM, et al. Common occurrence of anaemia at the end of pregnancy following exposure to zidovudine-free regimens. J Infect. 2011;63(2):144-50. [pmid: 21683094].
Pornprasert S, Faye A, Mary JY, Dolcini G, Leechanachai P, Chaouat G, et al. Down modulation of TNF-alpha mRNA placental expression by AZT used for the prevention of HIV-1 mother-to-child transmission. Placenta. 2006;27(9–10):989-95. [pmid: 16359728].
Rahangdale L, Sarnquist C, Maldonado Y, Cohan D. Patient acceptance of and satisfaction with rapid HIV testing in a labor and delivery setting. J Womens Health (Larchmt). 2008;17(3):465-71. [pmid: 18373491].
Rajegowda BK, Das BB, Lala R, Rao S, McNeeley DF. Expedited human immunodeficiency virus testing of mothers and new-borns with unknown HIV status at time of labor and delivery. J Perinat Med. 2000;28(6):458-63. [pmid: 11155432].
Raymond EG, Taylor D, Cates W Jr, Tolley EE, Borasky D, Cancel A, et al. Pregnancy in effectiveness trials of HIV prevention agents. Sex Transm Infect. 2007;34(12):1035-9. [pmid: 17621249].
Schlosser R, Linde R, Dunsch D, Reitter A, Haberl A, Bauer K. Side effects of antiretroviral treatment for transmission prophylaxis in preterm and near-term infants [German]. Z Geburtshilfe Neonatol. 2007;211(6):230-5. [pmid: 18176903].
Solis Villamarzo I, Munoz Galligo E, Ramos Amador JT, Gonzalez Tome MI, Rojano Luque X, Almeda Ortega J, et al. Maternal characteristics of a cohort of pregnant women with HIV-1 infection [Spanish]. Med Clin (Barc). 2006;127(4):121-5. [pmid: 16831391].
Stuart GS, Castano PM, Sheffield JS, McElwee B, McIntire DD, Wendel GD. Postpartum sterilization choices made by HIV-infected women. Infect Dis Obstet Gynecol. 2005;13(4):217-22. [pmid: 16338782].
Study EC, Newell ML, Dunn D, Peckham CS, Ades AE, Pardi G, et al. Risk factors for mother-to-child transmission of HIV-1. Lancet. 1992;339(8800):1007. [pmid: 1349050].
Tempelman C, Timmermans S, Godfried MH, Dieleman JP, Boer K, van der Ende ME. Highly active antiretroviral therapy (HAART) in HIV-positive pregnant women in the Netherlands, 1997–2003 safe, effective and with few side effects [Dutch]. Ned Tijdschr Geneeskd. 2004;148(41):2021-5. [pmid: 15553999].
Tepper NK, Farr SL, Danner SP, Maupin R, Nesheim SR, Cohen MH, et al. Rapid human immunodeficiency virus testing in obstetric outpatient settings: the MIRIAD study. Am J Obstet Gynecol. 2009;201(1). [pmid: 19398094].
Timmermans S, Tempelman C, Godfried MH, Nellen J, Dieleman J, Sprenger H, et al. Nelfinavir and nevirapine side effects during pregnancy. AIDS. 2005;19(8):795-9. [pmid: 15867493].
van der Lugt J, Autar S, Ubolyam S, Cooper D, Lamge J, Phanuphak P, et al. Pharmacokinetics and Pharmacodynamics of Double Boosted PI Regimen of Saquinavir and Lopinavir/Ritonavir in Treatment Naive HIV-1 Infected Adults. 14th Conference on Retroviruses and Opportunistic Infections. 2007. Abstract 578.
Wade NA, Unadkat JD, Huang S, Shapiro DE, Mathias A, Yasin S, et al. Pharmacokinetics and safety of stavudine in HIV-infected pregnant women and their infants: Pediatric AIDS Clinical Trials Group protocol 332. J Infect Dis. 2004;190(12):2167-74. [pmid: 15551216].
Wagner TA, Kress CM, Beck I, Techapornroong M, Wittayapraparat P, Tansuphasawasdikul S, et al. Detection of HIV-1 drug resistance in women following administration of a single dose of nevirapine: comparison of plasma RNA to cellular DNA by consensus sequencing and by oligonucleotide ligation assay. J Clin Microbiol. 2010;48(5):1555-61. [pmid: 20181911].
Walter J, Kuhn L, Kankasa C, Semrau K, Sinkala M, Thea DM, et al. Reuse of single-dose nevirapine in subsequent pregnancies for the prevention of mother-to-child HIV transmission in Lusaka, Zambia: a cohort study. BMC Infect Dis. 2008;8(172). [pmid: 19116004].
Witt KL, Cunningham CK, Patterson KB, Kissling GE, Dertinger SD, Livingston E, et al. Elevated frequencies of micronucleated erythrocytes in infants exposed to zidovudine in utero and postpartum to prevent mother-to-child transmission of HIV. Environ Mol Mutagen. 2007;48(3–4):322-9. [pmid: 17358032].
Yang SC, Lu CY, Lee CY, Hung CC, Chen MY, Chuang CY, et al. Clinical course of children of human immunodeficiency virus-infected mothers in Taiwan. J Microbiol Immunol Infect. 2004;37(4):225-30. [pmid: 15340650].
Zorrilla C, Van Dyke R, Bardeguez A. Clinical Response, Safety and Tolerability of Saquinavir-SGC With Low Dose Ritonavir Boosting in Combination With Zidovudine and Lamibudine in HIV-Infected Pregnant Women: Preliminary Results of PACTG 386. 10th Conference on Retroviruses and Opportunistic Infections. 2003.

### Wrong Study Design for Key Question

Arrive E, Dabis F, Newell ML. Frequency of nevirapine resistance (NVPR) after single dose nevirapine (SD-NVP) use to prevent HIV-1 vertical transmission: a meta-analysis. Proceedings of the 3rd IAS Conference. 2005. Abstract TuPe5.2P15.
Brindley NM. Antiretroviral agents mimicking functional neonatal bowel obstruction: a case report. Eur J Pediatr Surg. 2006;16(4):276-8. [pmid: 16981095].
Chi BH, Sinkala M, Levy J. Maternal immune response and clinical outcomes on NNRTI-based antiretroviral therapy (ART) following exposure to single dose nevirapine (NVP) for prevention of mother to child transmission (PMTCT). XVI International AIDS Conference. 2006. Abstract WEAB0104.
Coulter-Smith S, Lambert JS, Butler K, Brennan M, Cafferkey M. HIV testing and treatment in the antenatal care setting. Ir Med J. 2010;103(1):14-7. [pmid: 20222387].
De Santis M, Carducci B, De Santis L, Cavaliere AF, Straface G. Periconceptional exposure to efavirenz and neural tube defects. Arch Intern Med. 2002;162(3):355. [pmid: 11822930].
Force PH. Safety and toxicity of individual antiretroviral agents in pregnancy. 2010.
Fregonese F, Maleesatharn A, Ratanakosol J, Yuthavisuthi P, Ariyadej S, Chalermpantmetagul S, et al. Six months follow up of highly active antiretroviral therapy (HAART) initiated during pregnancy in Thailand. International Conference on AIDS. 2004. Abstract no. ThPeB7088.
Furco A, Gosrani B, Nicholas S, Williams A, Braithwaite W, Pozniak A, et al. Successful use of darunavir, etravirine, enfuvirtide and tenofovir/emtricitabine in pregnant woman with multiclass HIV resistance. AIDS. 2009;23(3):434-5. [pmid: 19188762].
Ghosn J, De Montgolfier I, Cornelie C, Dominguez S, Perot C, Peytavin G, et al. Antiretroviral therapy with a twice-daily regimen containing 400 milligrams of indinavir and 100 milligrams of ritonavir in human immunodeficiency virus type 1-infected women during pregnancy. Antimicrob Agents Chemother. 2008;52(4):1542-4. [pmid: 18250187].
Gonzalez-Tome MI, Ramos J, Solis I, Munoz E, Guillen S, Almeda J, et al. Gestational Diabetes and ART in Pregnant HIV-1 Infected Women. 12th Conference on Retroviruses and Opportunistic Infections. 2005. Abstract 68.
Hankin C, Lyall H, Willey B, Peckham C, Masters J, Tookey P. In utero exposure to antiretroviral therapy: feasibility of long-term follow-up. AIDS Care. 2009;21(7):809-16. [pmid: 19504373].
Hill JB, Sheffield JS, Zeeman GG, Wendel GDJ. Hepatotoxicity with antiretroviral treatment of pregnant women. Obstet Gynecol. 2001;98(5, Part 2):909-11. [pmid: 11704198].
Hillis SD, Rakhmanova A, Vinogradova E, Voronin E, Yakovlev A, Khaldeeva N, et al. Rapid HIV testing, pregnancy, antiretroviral prophylaxis and infant abandonment in St Petersburg. Int J STD AIDS. 2007;18(2):120-2. [pmid: 17331286].
Jaworsky D, Thompson C, Yudin MH, Bitnun A, Brophy J, Samson L, et al. Use of newer antiretroviral agents, darunavir and etravirine with or without raltegravir, in pregnancy: a report of two cases. Antivir Ther. 2010;15(4):677-80. [pmid: 20587860].
Kassis N, Heard A, Sprawka N, Cu-Uvin S, Anderson B. Antiretroviral-induced hepatotoxicity presenting as nonreassuring fetal testing. Obstet Gynecol. 2010;2:515-7. [pmid: 20664438].
Kramer F, Stek A, Du WB, Kovacs A. Nevirapine Tolerability in HIV-infected Women in Pregnancy. Conf Retrovir Oppor Infect. 2004;11. Abstract # 923.
Lopriore E, Rozendaal L, Gelinck LB, Bokenkamp R, Boelen CC, Walther FJ. Twins with cardiomyopathy and complete heart block born to an HIV-infected mother treated with HAART. AIDS. 2007;21(18):2564-5. [pmid: 18025905].
Loubeyre-Unique C, Gautier A, Vauzelle-Gardier C, Champart AM, Bavoux F. Antiretroviral agents and pregnancy: mitochondrial dysfunction and nucleoside analogs [French]. Therapie. 2001;56(3):261-6. [pmid: 11475805].
Martinson N, Morris L, Gray G, Moodley D, Lupondwana P, Chezzi C, et al. HIV Resistance and Transmission Following Single-Dose Nevirapine in a PMTCT Cohort. 11th Conference on Retroviruses and Opportunistic Infections. 2004. abstract no. 38.
Myers SA, Torrente S, Hinthorn D, Clark PL. Life-threatening maternal and fetal macrocytic anemia from antiretroviral therapy. Obstet Gynecol. 2005;106(5 Pt 2):1189-91. [pmid: 16260567].
Namukwaya Z, Mudiope P, Kekitiinwa A, Musoke P, Matovu J, Kayma S, et al. The impact of maternal highly active antiretroviral therapy and short-course combination antiretrovirals for prevention of mother-to-child transmission on early infant infection rates at the Mulago National Referral Hospital in Kampala, Uganda, January 2007 to May 2009. J Acquir Immune Defic Syndr. 2011;56(1):69-75. [pmid: 21099692].
Overton ET, Sungkanuparph S, Nurutdinova D, Powderly WG. Antiretroviral resistance among HIV-positive pregnant women who have antiretroviral experience from previous pregnancy. AIDS. 2005;19(13):1439-40. [pmid: 16103781].
Taha TE, Kumwenda J, Cole SR, Hoover DR, Kafulafula G, Fowler MG, et al. Postnatal HIV-1 transmission after cessation of infant extended antiretroviral prophylaxis and effect of maternal highly active antiretroviral therapy. The J Infect Dis. 2009;200(10):1490-7. [pmid: 19832114].
Theron G, Nellensteijn M, Theron A, Louw J. HIV transmission from mother to child--HAART compared with dual therapy. S Afr Med J. 2009;99(10). [pmid: 20128268].
Thomas TK, Masaba R, Borkowf CB, Ndivo R, Zeh C, Misore A, et al. Triple-antiretroviral prophylaxis to prevent mother-to-child HIV transmission through breastfeeding--the Kisumu Breastfeeding Study, Kenya: a clinical trial. PLoS Med. 2011;8(3):e1001015. [pmid: 21468300].
Tonwe-Gold B, Ekouevi DK, Viho I, Amani-Bosse C, Toure S, Coffie PA, et al. Antiretroviral treatment and prevention of peripartum and postnatal HIV transmission in West Africa: evaluation of a two-tiered approach. PLoS Med. 2007;4(8). [pmid: 17713983].
Tovo PA, Chiapello N, Gabiano C, Zeviani M, Spada M. Zidovudine administration during pregnancy and mitochondrial disease in the offspring. Antivir Ther. 2005;10(6):697-9. [pmid: 16218167].
Velinov M, Dolzhanskaya N, Mendez H. Mitochondrial T9098C sequence change in the MTATP6 gene and development of severe mitochondrial disease after in utero antiretroviral prophylaxis. Pharmacotherapy. 2009;29(12). [pmid: 19947808].
Wensing AM, Boucher CA, van Kasteren M, van Dijken PJ, Geelen SP, Juttmann JR. Prevention of mother-to-child transmission of multi-drug resistant HIV-1 using maternal therapy with both enfuvirtide and tipranavir. AIDS. 200620(10):1465-7. [pmid: 16791028].

### No Original Data

Mother-to-child transmission of HIV infection and its prevention. Curr HIV Res. 2003;1:447-62. [pmid: 15049430].
Abarzua F, Hubinont C, Yombi JC, Bernard P, Debieve F, Goubau P, et al. Highly Active Antiretroviral Therapy (HAART) in Pregnant HIV-Infected Women. Efficacy and Safety for the Mothers and Infants. 9th European AIDS Conference (EACS). 2003. Abstract 14.2/1.
Abarzua F, Nunez F, Hubinont C, Bernard P, Yombi JC, Vandercam B. Human immunodeficiency virus (HIV) infection in pregnancy: antiretroviral treatment (ART) and mode of delivery [Spanish]. Rev Chilena Infectol. 2005;22(4):327-37. [pmid: 16341354].
Ammann AJ. Optimal versus suboptimal treatment for HIV-infected pregnant women and HIV-exposed infants in clinical research studies. J Acquir Immune Defic Syndr. 2009;15;51(5):509-12. [pmid: 19521253].
Anastos K. Good news for women living with HIV. J Infect Dis. 2007;196(7):971-3. [pmid: 17763315].
Anderson JR. XV International AIDS Conference: women and HIV in the spotlight. Hopkins HIV Rep. 2004;16(5):7-9. [pmid: 15529456].
Anderson JR. HIV and pregnancy at the 12 CROI. Hopkins HIV Rep. 2005;17(2):6-7. 9. [pmid: 16419317].
Anderson JR. 3rd IAS Conference: pregnancy issues. Hopkins HIV Rep. 2005;17(5):6-7. [pmid: 16419302].
Who publishes new guidelines on preventing mother to child transmission of HIV. Cent Eur J Public Health. 2004;12(4):223. [pmid: 15672499].
Preventing mother to child transmission of HIV. J Adv Nurs. 2004;48(4). [pmid: 15543657].
Testing: no damages for woman, baby over false-positive HIV test. AIDS Policy Law. 2007;7;22(17):8. [pmid: 18228625].
Treatment: study findings show HAART drugs benefit pregnant women. AIDS Policy & Law. 2007;22(19):2. [pmid: 18210649].
Treatment: study could revolutionize HIV policies for pregnant women. AIDS Policy Law. 2007;22(19):2. [pmid: 18203398].
Birth defect rates unchanged by antiretrovirals. AIDS Patient Care STDS. 2007;21(6). [pmid: 17594253].
Bateman C. Finally--PMTCT dual therapy. S Afr Med J. 2008;98(3). [pmid: 18350215].
Baylor M, Truffa M, Gibbs N. Hepatic Toxicity of Antiretrovirals in HIV-infected Pregnant Women: A Review of the FDA’s Adverse Event Reporting System. Conf Retrovir Oppor Infect. 2004. 11th (no. 944).
Becquet R, Ekouevi DK. Breastfeeding, triple ARV prophylaxis, and MTCT prevention. Lancet Infect Dis. 2011;11(3):154-5. [pmid: 21237717].
Bersoff-Matcha SJ, Rourke D, Blank J. Evaluation of the safety of nevirapine therapy during pregnancy. J Acquir Immune Defic Syndr. 2010;15;54(5):560-2. [pmid: 20647826].
Brinkman K, ter Hofstede HJ, Burger DM, Smeitink JA, Koopmans PP. Adverse effects of reverse transcriptase inhibitors: mitochondrial toxicity as common pathway. AIDS. 1998;12(14):1735-44. [pmid: 9792373].
Brogly S, Williams P, Seage GR, Van Dyke R. In utero nucleoside reverse transcriptase inhibitor exposure and cancer in HIV-uninfected children: an update from the Pediatric AIDS Clinical Trials Group 219 and 219C cohorts. J Acquir Immune Defic Syndr. 2006;41(4):535-6. [pmid: 16652068].
Buchholz B, Beichert M, Marcus U, Grubert T, Gingelmaier A, Haberl A, et al. German-Austrian recommendations for HIV1-therapy in pregnancy and in HIV1-exposed newborn, update 2008. Eur J Med Res. 2009;14(11):461-79. [pmid: 19948442].
Capparelli E, Rakhmanina N, Mirochnick M. Pharmacotherapy of perinatal HIV. Semin Fetal Neonatal Med. 2005;10(2):161-75. [pmid: 15701581].
Carosi G, Nasta P, Fiore S, Matteelli A, Cauda R, Ferrazzi E, et al. Women facing HIV: key question on women with HIV infection: Italian consensus workshop. Infection. 2009;37(2):168-78. [pmid: 19308320].
Catherine MW. Perinatal HIV transmission--a global problem: controversy and protection of the next generation. Semin Pediatr Infect Dis. 1998;9(4):339-44.
Centers for Disease Control and Prevention. Rapid HIV antibody testing during labor and delivery for women of unknown HIV status. 2004. Available at: http://www.cdc.gov/hiv/rapid_testing/materials/Labor&DeliveryRapidTesting.pdf.
Clayden P. Pregnancy outcomes in the DART trial. GMHC Treat Issues. 2006;20(8–12):14-5. [pmid: 17569165].
Coll O, Suy A, Martinez E, Lonca M, Lazzari E, Pisa S, et al. Increased Risk of Pre-eclampsia and Fetal Death in HIV-infected Pregnant Women Receiving Highly Active Antiretroviral Therapy. 11th Conference on Retroviruses and Opportunistic Infections. 2004. Abstract 921. [pmid: 16327320].
Cooper E. HIVNET 012 and Petra. Lancet. 2004;363(9404):245-6. [pmid: 14738808].
Coovadia H. Antiretroviral agents--how best to protect infants from HIV and save their mothers from AIDS. N Engl J Med. 2004;15;351(3):289-92. [pmid: 15247337].
Cossarizza A, Moyle Ga. Antiretroviral nucleoside and nucleotide analogues and mitochondria. AIDS. 2004;18(2):137-51. [pmid: 15075530].
Delva W, Temmerman M. The efficacy-effectiveness gap in PMTCT. S Afr Med J. 2004;94(10). [pmid: 15532743].
Dunable D. News from the 11th conference on retroviruses and opportunistic infections. Surviv News (Atlanta Ga). 2004;15(2):9-10. [pmid: 15124572].
El Beitune P, Duarte G, Quintana SM, Figueiro-Filho EA, Marcolin AC, Abduch R. Antiretroviral therapy during pregnancy and early neonatal life: consequences for HIV-exposed, uninfected children. Braz J Infect Dis. 2004;8(2):140-50. [pmid: 15361992].
Fellay J, Cavassini M. HIV-AIDS: answers to new questions [French]. Rev Med Suisse. 2006;2(60):912-7. [pmid: 16673722].
Fernandez AD, McNeeley DF. Management of the infant born to a mother infected with human immunodeficiency virus type 1 (HIV-1): current concepts. Am J Perinatol. 2000;17(08):429-36. [pmid: 11142394].
Ford N, Calmy A, Mofenson L. Safety of efavirenz in the first trimester of pregnancy: an updated systematic review and meta-analysis. AIDS. 2011;25(18):2301-4. [pmid: 21918421].
Foster C, Lyall H. HIV and mitochondrial toxicity in children. J Antimicrob Chemother. 2008;61(1):8-12. [pmid: 17999978].
Foster C, Lyall H, Olmscheid B, Pearce G, Zhang S, Gibb DM. Tenofovir disoproxil fumarate in pregnancy and prevention of mother-to-child transmission of HIV-1: is it time to move on from zidovudine?. HIV Med. 2009;10(7):397-406. [pmid: 19459986].
Foster CJ, Lyall EG. HIV in pregnancy: evolution of clinical practice in the UK. Int J STD AIDS. 2006;17(10):660-7. [pmid: 17059634].
Fowler MG. Prevention of perinatal HIV infection: what do we know? Where should future research go?. Ann N Y Acad Sci. 2000;918:45-52. [pmid: 11131733].
Funk MJ, Belinson SE, Pimenta JM, Morsheimer M, Gibbons DC. Mitochondrial disorders among infants exposed to HIV and antiretroviral therapy. Drug Saf. 2007;30(10):1-12. [pmid: 17194166].
Goldschmidt RH, Fogler JA. Opportunities to prevent HIV transmission to newborns. Pediatrics. 2006;117(1):208-9. [pmid: 16396878].
Goldschmidt RH, Poage RE. Preventing HIV--a primary care imperative. Am Fam Physician. 2004;70(2):15. [pmid: 15291083].
Gonzalez Garcia A, Fernandez MI, Cotter AM. Nevirapine toxicity in the obstetrical population when used in combination with other antiretrovirals. 15th Internations AIDS conference. 2007. Abstract WePeB5918.
Hankin C, Lyall H, Peckham C, Tookey P. Monitoring death and cancer in children born to HIV-infected women in England and Wales: use of HIV surveillance and national routine data. AIDS. 2007;21(7):867-9. [pmid: 17415042].
Harris C. Testing pregnant patients. N J Med. 1998;95(3). [pmid: 16013140].
Hudson CP. HIVNET 012 and Petra. Lancet. 2004;363(9404):17. [pmid: 14738804].
Hudson CP. Zidovudine monotherapy and the prevention of mother-to-child HIV-1 transmission. Lancet Infect Dis. 2005;5(2). [pmid: 15680770].
Hughes V. Extra drugs and slower weaning lowers HIV risk for newborns. Nat Med. 2008;14(7). [pmid: 18607354].
Jackson B, Mmiro F. HIVNET 102 Study Team. HIVNET 012 and Petra. Lancet. 2004;363(9404):245-6. [pmid: 14738808].
Jourdain G, Ngo-Giang-Huong N, Tungyai P, Kummee A, Bowonwatanuwong C, Kantipong P, et al. Exposure to Intrapartum Single-dose Nevirapine and Subsequent Maternal 6-Month Response to NNRTI-based Regimens. 11th Conference on Retroviruses and Opportunistic Infections. 2004. Abstract 41LB.
Karakousis PC, Page KR, Bishai WR. From the Infectious Diseases Society of America (IDSA) meeting--important new findings in HIV treatment and pathogenesis, 2003. Hopkins HIV Rep. 2004;16(1):2-3. [pmid: 14989191].
Katzenstein TL, Gerstoft J. Zidovudine monotherapy in pregnancy: is it state of the art?. HIV Med. 2008;9(7):445-7. [pmid: 18840149].
Koenig LJ, Nesheim S, Abramowitz S. Adolescents with perinatally acquired HIV: emerging behavioral and health needs for long-term survivors. Curr Opin Obstet Gynecol. 2011;23(5):321-7. [pmid: 21836510].
Kourtis AP, Fowler MG. Antiretroviral use during pregnancy and risk of preterm delivery: more questions than answers. J Infect Dis. 2011;204(4):493-4. [pmid: 21791648].
Kreitchmann R, Canti I, Gomes da Silva MM, Barcelos N, Fuchs SC. Discussing the effectiveness of short-term zidovudine prophylaxis on detection of HIV-1 subtype E in human placenta and vertical transmission. J Acquir Immune Defic Syndr. 2006;15;42(5):649-50. [pmid: 16837870].
Kresge KJ. Women and HIV: women’s research roundup. BETA. 2005;17(4):30-3. [pmid: 16124120].
Kriebs JM. Changing the paradigm: HIV in pregnancy. J Perinat Neonatal Nurs. 2006;20(1):71-3. [pmid: 16508466].
Lallemant M, Jourdain G. Preventing mother-to-child transmission of HIV-protecting this generation and the next. N Engl J Med. 2010;363(16):1570-2. [pmid: 20942674].
Lane HC, Folkers GK, Fauci AS. Reports on nevirapine threaten public health. Nat Med. 2005;11(3). [pmid: 15746930].
Laurence J. Fighting a flexible virus with flexible drugs. AIDS Read. 2004;14(7):345-6. [pmid: 15281169].
Lavigne JE, Shearer WT, Thompson B, Orav EJ, Starc TJ, Colan SD, et al. Cardiovascular outcomes of pediatric seroreverters perinatally exposed to HAART: design of a longitudinal clinical study. Cardiovasc Toxicol. 2004;4(2):187-97. [pmid: 15371634].
Lewis W, Dalakas MC. Mitochondrial toxicity of antiviral drugs. Nat Med. 1995;1(5):417-22. [pmid: 7585087].
Mascolini M. Prevention, planning, resistance, toxicity. IAPAC sessions--USA. May 20–21, 2004. Chicago. IAPAC Mon. 2004;10(6):196-215. [pmid: 15484372].
Mascolinli M, Kort R. 5th International AIDS Society Conference on HIV Pathogenesis, Treatment and Prevention: summary of key research and implications for policy and practice--biomedical prevention. J Int AIDS Soc. 2010;13(1). [pmid: 20519025].
McConnell MS, Stringer JS, Kourtis AP, Weidle PJ, Eshleman SH. Use of single-dose nevirapine for the prevention of mother-to-child transmission of HIV-1: does development of resistance matter?. Am J Obstet Gynecol. 2007;197(3 Suppl). [pmid: 17825651].
McIntosh K. Mitochondrial toxicity of perinatally administered zidovudine. Conf Retrovir Oppor Infect. 2000. 7th. [pmid: 11712936].
McIntyre J. Prevention of mother-to-child transmission of HIV: treatment options. Expert Rev Anti Infect Ther. 2005;3(6):971-80. [pmid: 16307509].
McIntyre J. Strategies to prevent mother-to-child transmission of HIV. Curr Opin Infect Dis. 2006;19(1):33-8. [pmid: 16374215].
McIntyre JA. Controversies in the use of nevirapine for prevention of mother-to-child transmission of HIV. Expert Opin Pharmacother. 2006;7(6):677-85. [pmid: 16556085].
Morris L, Martinson N, Pillay C. Persistence of nevirapine resistance mutations 6 months following single dose nevirapine. 15th International AIDS Conference. 2004.
Musoke P. Recent advances in prevention of mother to child (PMTCT) of HIV. Afr Health Sci. 2004;4(3):144-5. [pmid: 15687065].
Myer L. Initiating antiretroviral therapy in pregnancy: the importance of timing. J Acquir Immune Defic Syndr. 2011;58(2):125-6. [pmid: 21799436].
Nagy GS. Report from the 12th Retrovirus Conference. Perinatal transmission. AIDS Clin Care. 2005;17(4):41-2. [pmid: 15884152].
Nolan D, Mallal S. Complications associated with NRTI therapy: update on clinical features and possible pathogenic mechanisms. Antivir Ther. 2004;9:849-63. [pmid: 15651744].
Oleske JM. Long-term outcomes in infants born to HIV-infected women. J Acquir Immune Defic Syndr. 2003;32(4):353. [pmid: 12640190].
World Health Organization. New data on the prevention of mother-to-child transmission of HIV and their policy implications: conclusions and recommendations. 2001.
Orio M, Pena JM, Rives MT, Sanz M, Bates I, Madero R, et al. Changes in vertical HIV transmission: comparison between 1994 and 2004 [Spanish]. Med Clin (Barc). 2007;128(9):321-4. [pmid: 17376357].
Patel AK, Patel KK, Sharma R, Ranjan RR, Shukla RK, Patel JA. Prevention of mother-to-child HIV transmission using 3-drug combination antiretroviral treatment: observational cohort in clinical practice setting in India. J Acquir Immune Defic Syndr. 2009;50(2):231-3. [pmid: 19155769].
Rahangdale L, Sarnquist C, Feakins C, Nassos P, Haller B, Cohan D. Rapid HIV testing on labor and delivery: lessons from the field. J Acquir Immune Defic Syndr. 2007;46(3):376-8. [pmid: 18090304].
Rakhmanina NY, van den Anker JN, Soldin SJ. Safety and pharmacokinetics of antiretroviral therapy during pregnancy. Ther Drug Monit. 2004;26(2):110-5. [pmid: 15228149].
Sabin M, Lo YR. Progress in providing HIV testing and counseling in health facilities: WHO/UNAIDS guidance. JAMA. 2010;304(3):342-3. [pmid: 20639569].
Senise JF, Castelo A, Martinez M. Current treatment strategies, complications and considerations for the use of HIV antiretroviral therapy during pregnancy. AIDS Rev. 2011;13(4):198-213. [pmid: 21975356].
Shapiro RL, Ribaudo H, Powis K, Chen J, Parekh N. Extended antenatal use of triple antiretroviral therapy for prevention of mother-to-child transmission of HIV-1 correlates with favorable pregnancy outcomes. AIDS. 2012;26(1):120-1. [pmid: 22126816].
Smith CB, Battin MP, Francis LP, Jacobson JA. Should rapid tests for HIV infection now be mandatory during pregnancy? Global differences in scarcity and a dilemma of technological advance. Dev World Bioeth. 2007;7(2):86-103. [pmid: 17614994].
Smith DM. The controversies of nevirapine for preventing mother-to-child HIV transmission. AIDS. 2006;20(2):281-3. [pmid: 16511423].
Stek AM. Antiretroviral medications during pregnancy for therapy or prophylaxis. Curr HIV/AIDS Rep. 2009;6(2):68-76. [pmid: 19358777].
Study EC. Pregnancy-related changes in the longer-term management of HIV-infected women in Europe. Euro J Obstet Gynecol Reprod Biol. 2003;111(1):3-8. [pmid: 14557003].
Sturt AS, Read JS. Antiretroviral use during pregnancy for treatment or prophylaxis. Expert Opin Pharmacother. 2011;12(12):1875-85. [pmid: 21534886].
Surjushe A, Maniar J. Prevention of mother-to-child transmission. Indian J Dermatol Venereol Leprol. 2008;74(3):200-7. [pmid: 18583783].
Talaie H, Nava-Ocampo AA, Koren G. Antiretroviral treatment of maternal HIV infection. Can Fam Physician. 2004;50:865-8. [pmid: 15233367].
Tardieu M. The risk of very long-term brain dysfunction in treated adolescents with perinatally acquired HIV-1 infection. AIDS. 2009;23(14):1891-2. [pmid: 19574881].
The Perinatal Safety Review Working Group. Nucleoside exposure in the children of HIV-infected women receiving antiretroviral drugs: absence of clear evidence for mitochondrial disease in children who died before 5 years of age in five United States cohorts. J Acquir Immune Defic Syndr. 2000;25(3):261-8. [pmid: 11115957].
Thorne C, Newell ML. Prevention of mother-to-child transmission of HIV infection. Curr Opin Infect Dis. 2004;17(3):247-52. [pmid: 15166829].
Thorne C, Newell ML. Treatment options for the prevention of mother-to-child transmission of HIV. Curr Opin Investig Drugs. 2005;6(8):804-11. [pmid: 16121687].
Thorne C, Newell ML. Safety of agents used to prevent mother-to-child transmission of HIV: is there any cause for concern?. Drug Saf. 2007;30(3):203-13. [pmid: 17343429].
Townsend CL, Tookey PA, Cortina-Borja M, Peckham CS. Antiretroviral therapy and congenital abnormalities in infants born to HIV-1-infected women in the United Kingdom and Ireland, 1990 to 2003. J Acquir Immune Defic Syndr. 2006;42(1):91-4. [pmid: 16763496].
Venhoff N, Walker UA. Mitochondrial disease in the offspring as a result of antiretroviral therapy. Expert Opin Drug Saf. 2006;5(3):373-81. [pmid: 16610967].
Vigano A, Cerini C, Pattarino G, Fasan S, Zuccotti GV. Metabolic complications associated with antiretroviral therapy in HIV-infected and HIV-exposed uninfected paediatric patients. Expert Opin Drug Saf. 2010;9(3):431-45. [pmid: 20078250].
Volmink J. HIV: mother to child transmission. Clin Evid. 2003;9:785-94. [pmid: 12967392].
Volmink J. HIV: mother to child transmission. Clin Evid. 2004;11:902-12. [pmid: 15652045].
Waters L, John L, Nelson M. Non-nucleoside reverse transcriptase inhibitors: a review. Int J Clin Pract. 2007;61(1):105-18. [pmid: 17229185].
Watts DH. Treating HIV during pregnancy: an update on safety issues. Drug Saf. 2006;29(6):467-90. [pmid: 16752931].
Wilfert CM. Perinatal HIV transmission--a global problem: controversy and protection of the next generation. Semin Pediatr Infect Dis. 1998;9(4):339-44.
Wunder D, Evison JM. Antiretroviral therapy and pregnancy [German]. Ther Umsch. 2005;62(1):37-42. [pmid: 15702705].
Zijenah L, Kadzirange G, Rusakaniko S, Kupfa T, Tobaiwa O, Moyo S, et al. Community-based generic antiretroviral therapy following single-dose nevirapine or short-course AZT in Zimbabwe. 12th Conference on Retroviruses and Opportunistic Infections. 2005. abstract 632.

### Out of Scope

Barker PM, Mphatswe W, Rollins N. Antiretroviral drugs in the cupboard are not enough: the impact of health systems’ performance on mother-to-child transmission of HIV. J Acquir Immune Defic Syndr. 2011;56(2):e45-8. [pmid: 21084998].
Ciaranello AL, Seage GR 3rd, Freedberg KA, Weinstein MC, Lockman S, Walensky RP. Antiretroviral drugs for preventing mother-to-child transmission of HIV in sub-Saharan Africa: balancing efficacy and infant toxicity. AIDS. 2359;22(17):2359-69. [pmid: 18981776].
Dennis RL, Negron TJ, Lindsay M, Nesheim SR, Lee FK, Jamieson DJ. Rapid human immunodeficiency virus testing in labor and delivery: a comparison of implementation models between 2 hospitals. J Perinat Neonatal Nurs. 2007;21(4):298-306. [pmid: 18004167].
Koulinska IN, Villamor E, Chaplin B, Msamanga G, Fawzi W, Renjifo B, et al. Transmission of cell-free and cell-associated HIV-1 through breast-feeding. J Acquir Immune Defic Syndr. 2006;41(1):93-9. [pmid: 16340480].
Newell ML, Borja MC, Peckham C. European Collaborative Study. Height, weight, and growth in children born to mothers with HIV-1 infection in Europe. Pediatrics. 2003;111(1):e52-e60. [pmid: 12509595].
Palumbo P, Holland B, Dobbs T, Pau CP, Luo CC, Abrams EJ, et al. Antiretroviral resistance mutations among pregnant human immunodeficiency virus type 1-infected women and their newborns in the United States: vertical transmission and clades. J Infect Dis. 2001;184(9):1120-6. [pmid: 11598834].
Patterson KB, Leone PA, Fiscus SA, Kuruc J, McCoy SI, Wolf L, et al. Frequent detection of acute HIV infection in pregnant women. AIDS. 2007;21(17):2303-8. [pmid: 18090278].
Townsend CL, Cortina-Borja M, Peckham CS, Tookey PA. Trends in management and outcome of pregnancies in HIV-infected women in the UK and Ireland, 1990–2006. BJOG. 2008;115(9):1078-86. [pmid: 18503577].
Townsend CL, Tookey PA, Newell ML, Cortina-Borja M. Antiretroviral therapy in pregnancy: balancing the risk of preterm delivery with prevention of mother-to-child HIV transmission. Antivir Ther. 2010;15(5):775-83. [pmid: 20710059].
Udeh B, Udeh C, Graves N. Perinatal HIV transmission and the cost-effectiveness of screening at 14 weeks gestation, at the onset of labour and the rapid testing of infants. BMC Infect Dis. 2008;8(174). [pmid: 19117527].

### Sample Size Too Small

Brogly SB, DiMauro S, Van Dyke RB, Williams PL, Naini A, Libutti DE, et al. Short communication: transplacental nucleoside analogue exposure and mitochondrial parameters in HIV-uninfected children. AIDS Res Hum Retroviruses. 2011;27(7):777-83. [pmid: 21142587].
Giaquinto C, De Romeo A, Giacomet V, Rampon O, Ruga E, Burlina A, et al. Lactic acid levels in children perinatally treated with antiretroviral agents to prevent HIV transmission. AIDS. 2001;15(8):1074-5. [pmid: 11399997].
Lorenzi P, Spicher VM, Laubereau B, Hirschel B, Kind C, Rudin C, et al. Antiretroviral therapies in pregnancy: maternal, fetal and neonatal effects. AIDS. 1998;12(18):F241-7. [pmid: 9875571].
Martin AM, Hammond E, Nolan D, Pace C, Den Boer M, Taylor L, et al. Accumulation of mitochondrial DNA mutations in human immunodeficiency virus-infected patients treated with nucleoside-analogue reverse-transcriptase inhibitors. Am J Hum Genet. 2003;72(3):549-60. [pmid: 12587093].
Shiramizu B, Shikuma KM, Kamemoto L, Gerschenson M, Erdem G, Pinti M, et al. Placenta and cord blood mitochondrial DNA toxicity in HIV-infected women receiving nucleoside reverse transcriptase inhibitors during pregnancy. J Acquir Immune Defic Syndr. 2003;32(4):370-4. [pmid: 12640193].
Wimalasundera RC, Larbalestier N, Smith JH, de Ruiter A, Thom SA, Hughes AD, et al. Pre-eclampsia, antiretroviral therapy, and immune reconstitution. Lancet. 2002;360(9340):1152-4. [pmid: 12387967].
Zorrilla CD, Van Dyke R, Bardeguez A, Acosta EP, Smith B, Hughes MD, et al. Clinical response and tolerability to and safety of saquinavir with low-dose ritonavir in human immunodeficiency virus type 1-infected mothers and their infants. Antimicrob Agents Chemother. 2208;51(6):2208-10. [pmid: 17420209].

### Systematic Review, Not Directly Used

Chigwedere P, Seage GR, Lee TH, Essex M. Efficacy of antiretroviral drugs in reducing mother-to-child transmission of HIV in Africa: a meta-analysis of published clinical trials. AIDS Res Hum Retroviruses. 2008;24(6):827-37. [pmid: 18544018].
Kourtis AP, Schmid CH, Jamieson D, Lau B. Use of antiretroviral therapy in pregnant HIV-infected women and the risk of premature delivery: a meta-analysis. AIDS. 2007;21:607-15. [pmid: 17314523].
McKoy JM, Bennett CL, Scheetz MH, Differding V, Chandler KL, Scarsi KK, et al. Hepatotoxicity associated with long- versus short-course HIV-prophylactic nevirapine use: a systematic review and meta-analysis from the Research on Adverse Drug Events and Reports (RADAR) project. Drug Saf. 2009;32(2):147-58. [pmid: 19236121].
Siegfried N, van der Merwe L, Brocklehurst P, Sint TT. Antiretrovirals for reducing the risk of mother-to-child transmission of HIV infection. Cochrane Database Syst Rev. 2010;8. [pmid: 21735394].
Suksomboon N, Poolsup N, Ket-Aim S. Systematic review of the efficacy of antiretroviral therapies for reducing the risk of mother-to-child transmission of HIV infection. J Clin Pharm Ther. 2007;32(3):293-311. [pmid: 17489882].

## Appendix A5 U.S. Preventive Services Task Force Quality Rating Criteria

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate results in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test
- Random or consecutive selection of patients
- Screening cutoff pre-determined
- All patients undergo the reference standard

#### Definition of ratings based on above criteria

Good: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease; study attempts to enroll a random or consecutive sample of patients who meet inclusion criteria screening cutoffs pre-stated.
Fair: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients (i.e. applicable to most screening settings).
Poor: | Has important limitation such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

### Randomized Controlled Trials (RCTs) and Cohort Studies

#### Criteria

- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Source: Harris R, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3S):21–35.

## Appendix A6 Expert Reviewers of the Draft Report

Marc Bulterys, MD, MPH, PhD

Director, Centers for Disease Control and Prevention, Global AIDS Program - China

Timothy Dondero, MD

Centers for Disease Control and Prevention, Division of HIV/AIDS Prevention

Laurie Zephyrin, MD

National Director for Reproductive Health, Department of Veterans Affairs