# DISCUSSION

## Summary of Review Findings

As in the 2005 USPSTF review,1-3 we found no direct evidence on effects of screening for HIV infection versus no screening on clinical outcomes. Other evidence reviewed in this update is summarized in Table 7.

Table 7 Summary of Evidence

Main findings from 2005 USPSTF review | Number and type of studies identified for update Overall quality^*^ | Limitations | Consistency | Applicability | Summary of findings
KQ 1. What are the benefits of universal or targeted HIV screening vs. no screening or each other in asymptomatic, nonpregnant adolescents and adults on disease transmission, morbidity, mortality, and quality of life?
No evidence | No studies | No studies | No studies | No studies | No study directly compared clinical outcomes between adults and adolescents screened and not screened for HIV infection.
KQ 2a. What is the yield (number of new diagnoses) of HIV screening at different intervals in nonpregnant adolescents and adults?
No evidence | No studies | No studies | No studies | No studies | No study evaluated the yield of repeat HIV screening compared with one-time screening.^†^
KQ 2b. What are the effects of universal vs. targeted HIV screening on testing acceptability and uptake in nonpregnant adolescents and adults?
No evidence | 1 cohort study and 2 uncontrolled screening series Overall quality: Poor | No study of universal vs. targeted screening reported testing acceptability and uptake | Some inconsistency | No major issues | No study directly compared the acceptability of universal vs. targeted HIV screening strategies. One fair-quality, nonrandomized study of emergency department patients found universal, opt-out rapid screening associated with higher likelihood of testing compared with physician-directed, targeted rapid screening (25% vs. 0.8%; RR, 30 [95% CI, 26 to 34]), but testing uptake (the proportion of patients offered testing who accepted) was not reported. In 2 uncontrolled implementation studies of universal HIV screening conducted in primary care settings, 35% (standard test) and 60% (rapid test) of those offered screening underwent screening.
KQ 2c. What is the effect of opt-out vs. opt-in testing or different pre- or post-test HIV counseling methods on screening uptake or rates of followup and linkage to care in nonpregnant adolescents and adults?
1 uncontrolled implementation study found 35% of patients with HIV infection identified through routine screening in an urgent care setting entered care within 4 months | 2 cohort studies Overall quality: Poor | No RCTs; no data on rates of followup and linkage to care; no evidence on different counseling methods | Some inconsistency | Studies conducted in emergency department setting | One cohort study found an opt-out approach associated with higher likelihood of testing compared with an opt-in approach (13% vs. 7%; RR, 2.1 [95% CI, 1.9 to 2.4]), but patients who underwent opt-out testing were more likely to report that they had not been informed of HIV testing. One other study found opt-in testing associated with lower testing uptake compared with opt-out testing, but results may have been confounded by differences in who offered the testing. No study compared effects of different pre- or post-test HIV counseling methods on screening uptake or rates of followup and linkage to care.
KQ 2d. What are the adverse effects (including false-positive results and anxiety) of rapid vs. standard HIV testing in nonpregnant adolescents and adults not known to be at higher risk?
Good evidence that standard and rapid HIV testing with confirmatory Western blot are associated with high sensitivities and specificities | 5 uncontrolled screening series^‡^ Overall quality: Poor | No comparative studies | Moderate inconsistency | Prevalence of HIV infection varied | In 5 large studies of rapid testing (without a comparison with standard testing), positive predictive value was 94% in 1 study of a higher-prevalence (1.1%) setting, and varied widely (16% to 83%) in 4 studies of lower-prevalence (0.2% to 0.4%) settings. No study evaluated psychological or other harms associated with rapid vs. standard HIV testing.
KQ 2e. What are the effects of universal vs. targeted HIV screening on CD4 counts at the time of diagnosis?
No evidence | 2 cohort studies Overall quality: Poor | No RCTs; potential confounding based on who was offering testing | Consistent | Studies conducted in emergency department settings | One fair-quality study found universal testing associated with a higher median CD4 count and lower likelihood of CD4 count <0.200 × 10^9^ cells/L at the time of diagnosis compared with targeted HIV screening, but these differences were not statistically significant. No other studies directly compared effects of universal vs. targeted HIV screening, though epidemiologic data indicate temporal trends suggesting earlier diagnosis since the 2006 CDC recommendation on routine HIV screening was issued.
KQ 2f. What are the effects of universal vs. targeted HIV screening on rates of followup and linkage to care in nonpregnant adolescents and adults who screen positive?
2 uncontrolled studies found 35% to 70% of HIV-positive patients identified through universal screening in urgent care centers were linked to care. | 1 cohort study and 2 uncontrolled screening series Overall quality: Poor | Small numbers of patients diagnosed with HIV infection, only 1 controlled study | Moderate | Cohort study was conducted in an emergency department setting | The only study that directly compared universal with targeted testing reported very high rates of followup (defined as attending at least 1 HIV clinic visit) with either strategy (97% to 100%). Two other observational studies reported rates of followup or linkage to care of 75% to 82% following a new HIV diagnosis found during universal testing.
KQ 3a. To what extent does knowledge of HIV-positive status affect behaviors associated with increased risk for HIV transmission in nonpregnant adolescent and adults?
Systematic reviews found knowledge of HIV status associated with reductions in self-reported sexual risk behaviors, but the studies included in the systematic reviews had methodological shortcomings. | 4 before-after or cross-sectional studies Overall quality: Fair | Reliance on self-reported behaviors, sometimes based on retrospective recall | Consistent | 2 studies focused on high-risk populations | Four before-after studies found knowledge of HIV-positive status associated with reduced risky behaviors.
KQ 3b. To what extent does use of antiretroviral therapy affect behaviors associated with increased risk for HIV transmission in nonpregnant adolescent and adults?
1 meta-analysis found no association between use of HAART and increased likelihood of high-risk sexual behaviors, though some individual studies reported associations between HAART use and increased high-risk behaviors in some populations. | 7 observational studies Overall quality: Fair | Some studies did not adjust for confounders or had important baseline differences between groups | Some inconsistency | 3 studies focused on high-risk populations | Seven observational studies found no clear association between antiretroviral use and increase in risky behaviors, with some studies showing decreased risky behaviors.
KQ 4a. How effective is antiretroviral therapy in reducing transmission of HIV in nonpregnant adolescents and adults with chronic HIV infection?
No studies | 1 systematic review (1 RCT and 7 observational studies) Overall quality: Good | Only 1 RCT | Consistent | Some studies conducted in resource-poor settings | An RCT found immediate antiretroviral therapy in persons with a baseline CD4 count of 0.350 to 0.550 × 10^9^ cells/L associated with substantially reduced risk for transmission compared with delayed therapy (HR, 0.04 [95% CI, 0.01 to 0.27]). Observational studies were consistent with the RCT (pooled HR, 0.16 [95% CI, 0.07 to 0.35]).
KQ 4b. How effective is behavioral counseling in reducing transmission of HIV in nonpregnant adolescents and adults with chronic HIV infection?
No RCTs or controlled observational studies | 1 RCT and 1 before-after study Overall quality: Poor | Underpowered to evaluate effects on transmission | Unable to determine | No major issues | Studies identified too few cases of new HIV infection to adequately evaluate effects of counseling interventions on transmission risk.
KQ 4c. In asymptomatic, nonpregnant adolescents and adults with chronic HIV infection, what are the effects of initiating antiretroviral therapy at different CD4 counts or viral load thresholds on morbidity, mortality, and quality of life?
1 cohort study found initiation of HAART at CD4 counts >0.350 × 10^9^ cells/L associated with decreased risk for AIDS events and mortality compared with delayed initiation, but 3 others found no difference in risk | 3 RCTs and 5 large collaborative cohort studies Overall quality: Good | 1 RCT reported a subgroup analysis, some overlap in patients evaluated in the cohort studies | Some inconsistency for CD4 counts >0.500 × 10^9^ cells/L | 1 RCT evaluated CD4 count thresholds not applicable to U.S. practice in a resource-poor setting | One RCT and one subgroup analysis from an RCT found initiation of antiretroviral therapy at CD4 counts <0.250 × 10^9^ cells/L associated with substantially increased risk for death or AIDS events compared with initiation at CD4 counts >0.350 × 10^9^ cells/L. Five large observational studies also found initiation of antiretroviral therapy at CD4 counts of 0.350 to 0.500 × 10^9^ cells/L associated with decreased risk for mortality compared with deferred or no antiretroviral therapy. Four studies on initiation of antiretroviral therapy at CD4 counts >0.500 × 10^9^ cells/L did not consistently demonstrate clinical benefits.
KQ 5. What are the longer-term harms associated with antiretroviral therapy in nonpregnant adolescents and adults with chronic HIV infection?
1 large cohort study found longer duration of exposure to HAART associated with increased risk of myocardial infarction (RR, 1.3 per year of exposure [95% CI, 1.1 to 1.4]) | 4 cohort studies (reported in 6 publications) Overall quality: Good | No major limitations | Consistent | Duration of followup about 6 years | Additional followup from a large cohort study included in the prior USPSTF review found some protease inhibitors associated with increased risk for myocardial infarction (RR, 1.1 to 1.2 per year of exposure). Evidence on abacavir was mixed from four cohort studies, and there was no clear association between other antiretrovirals and increased risk for cardiovascular events.
KQ 6a. To what extent are improvements in viremia associated with reductions in HIV transmission rates in nonpregnant adolescents and adults?
7 observational studies consistently found an association between lower individual viral load and lower risk for heterosexual transmission of HIV infection | 6 observational studies Overall quality: Good | No major limitations | Consistent | Some studies conducted in resource-poor settings | Observational studies consistently found a dose-dependent association between higher viral load and risk for transmission in various settings and populations.
KQ 6b. To what extent are improvements in risky behaviors associated with reductions in HIV transmission rates in nonpregnant adolescents and adults?
2 systematic reviews of primarily heterosexual couples found consistent use of condoms associated with substantially lower (80% to 95%) risk of HIV transmission. | 2 cohort studies Overall quality: Good | No major limitations | Consistent | No study evaluated drug use behaviors; studies focused on condom use | Observational studies consistently found self-reported condom use associated with decreased risk for HIV transmission.

* “Overall quality” is based on new evidence identified for this update plus previously reviewed evidence.

† Cost-effectiveness modeling studies are not included in this summary table.

‡ One RCT compared rapid versus standard testing, but it only identified one new infection.

CDC = Centers for Disease Control and Prevention; KQ = key question; RCT = randomized, controlled trial; USPSTF = U.S. Preventive Services Task Force.

The 2005 USPSTF review found good evidence that HIV screening tests are accurate and that identification of undiagnosed HIV infection and treatment of immunologically advanced disease (CD4 count <0.200 × 10^9^ cells/L) are associated with substantial clinical benefits, but insufficient evidence to estimate effects of diagnosis and subsequent interventions on transmission risks or to estimate clinical benefits of ART in patients with less immunologically advanced disease. New studies included in this update provide strong evidence for effectiveness of initiation of ART at CD4 counts of 0.350 to 0.500 × 10^9^ cells/L,131, 132, 134-137 though evidence is less consistent for CD4 counts >0.500 × 10^9^ cells/L.132, 134, 135, 137 Recent studies indicate that about 54 percent of patients presented for initial HIV care with CD4 counts <0.350 × 10^9^ cells/L,78 and about 75 percent were diagnosed with CD4 counts <0.500 × 10^9^ cells/L,80 suggesting that a large proportion of patients identified by screening could directly benefit from immediate initiation of ART. Additional research confirms previous findings of a small but statistically significant increase in risk of long-term cardiovascular harms primarily associated with use of protease inhibitors.142-144, 146 Such long-term cardiovascular harms are an important consideration when initiating ART or selecting specific regimens, since patients will typically continue ART indefinitely. In the DAD study, the overall rate of myocardial infarction (fatal or nonfatal) after 5.8 years was 3.2 per 1,000 person-years (5.8 years median followup), with an increase in risk associated with protease inhibitors of about 10 percent per year of exposure, for an absolute increase of about 0.3 myocardial infarctions per 1,000 person-years.144 In the largest cohort study, HIV-CAUSAL, all-cause mortality after a mean of 3.3 years ranged from 28.8 per 1,000 person-years at a CD4 count of <100 × 10^9^ cells/L to 7.0 per 1,000 person-years at a CD4 count of 0.350 to <0.500 × 10^9^ cells/L, with a decrease in risk with initiation versus noninitiation of ART of 71 and 45 percent, respectively, for an absolute decrease in mortality of about 3.2 to 20 per 1,000 person-years.134 Whether current first-line protease inhibitors and other antiretrovirals are also associated with increased cardiovascular risk is not yet established. Long-term ART is also associated with other harms, including osteoporotic fractures169 and lipodystrophy,170 that were not addressed in this review.

Although direct clinical evidence showing that changes in risky behaviors as a result of knowledge of positive HIV status or that counseling interventions in HIV-positive persons reduces transmission risk is still not available, there is now strong evidence from a randomized trial as well as consistent evidence from multiple observational studies that ART use is associated with a 10- to 20-fold reduction in risk of sexual transmission.108, 109 These findings are consistent with other evidence confirming a strong association between reduced viral load (individual or community) and transmission risk.110, 155-159 The implications of these findings for reducing spread of HIV infection are substantial. Recent evidence showing that counseling interventions were relatively ineffective in reducing risky behaviors in HIV-infected persons suggest that beneficial effects of screening on transmission are likely to be driven by use of ART.171

Evidence on effects of different HIV screening strategies (such as universal vs. targeted screening, rapid vs. standard testing, opt-out vs. opt-in testing, or streamlined vs. traditional pretest counseling) on the uptake or yield of screening, CD4 count at diagnosis, linkage to care, or harms associated with screening are limited. Few studies directly compared these strategies, and in those that reported these outcomes, small numbers of HIV infection were identified, precluding reliable conclusions. Nonetheless, limited evidence suggests high rates of linkage of care following universal testing.68, 73, 76 There is insufficient evidence to estimate effects of different HIV screening strategies on rates of uptake, which may also be affected by the clinical setting, the perceived risk in the individual being offered testing, and other factors. There is also insufficient evidence to determine effects of different HIV screening strategies on CD4 count at diagnosis, though epidemiologic data indicate some recent trends toward earlier diagnosis, temporally coinciding with when the CDC recommendation for routine HIV screening was issued.60, 78, 80 Studies indicate that rapid testing is associated with higher false-alarm rates in lower-prevalence settings, though estimates varied widely.68, 73, 76, 77 The consequences of initially false-positive rapid test results have not been evaluated, but will depend on whether patients are notified prior to confirmatory testing, and are likely to be affected by other factors, such as how patients are counseled about results. Patients are unlikely to receive ART based on a false-positive result, given routine confirmation of positive test results and because use of ART depends in part on CD4 count and presence of viremia.

Modeling studies suggest that screening is likely to be cost-effective at prevalences similar to or lower than observed in the general population.9, 167 In addition, the modeling studies may underestimate cost-effectiveness, given relatively modest assumed reductions in risk of transmission (20%) relative to the results observed in the randomized trial described above.109

No clinical study has evaluated the yield of repeat HIV screening. Modeling studies suggest that repeat screening of low-risk individuals is unlikely to be associated with cost-effectiveness ratios <$100,000 per QALY compared with one-time screening, though repeat screening in high-risk individuals may be cost-effective, depending on the frequency of testing and incidence of new infections.8, 167, 168

## Limitations

We excluded nonEnglish-language articles, which could result in language bias, though we identified no nonEnglish-language studies that would have met inclusion criteria. We did not search for studies published only as abstracts and could not formally assess for publication bias with graphical or statistical methods because of small numbers of studies for each key question, and differences in study design, populations, and outcomes assessed. We included observational studies, which are more susceptible to bias and confounding than well-conducted randomized trials, though we focused on results from studies that performed statistical adjustment for potential confounding. When evidence from settings more applicable to U.S. practice and screening in low- and average-risk populations was sparse or unavailable, we included studies conducted in resource-poor and high-prevalence settings, which could limit applicability to U.S. practice.

## Emerging Issues

ART regimens and indications for initiating long-term ART continue to evolve. Since the 2005 USPSTF review, four new antiretroviral agents have been approved by the Food and Drug Administration for use in HIV-positive patients. Two represent new drug classes: the CCR5 antagonist maraviroc and the integrase inhibitor raltegravir. The other two drugs are the nonnucleoside reverse transcriptase inhibitor etravirine and the protease inhibitor darunavir. Although these medications have primarily been approved for use in patients with resistance to first-line medications, raltegravir has been approved for treatment-naive individuals. Regularly updated guidelines on selection of ART are available.52 A new CDC HIV testing algorithm is expected in 2012. Although it is believed to be at least as accurate as the prior testing algorithm, and is designed to diagnose patients sooner in the “window” period before seroconversion, studies should be performed to confirm its accuracy in clinical practice.

## Future Research

More research is needed on the effects of different HIV screening strategies on testing uptake, CD4 count at diagnosis, linkage to care, and harms. Studies should be designed with adequate statistical power to evaluate outcomes such as CD4 count at diagnosis, linkage to care, and harms, which may require collaborative efforts like those used to assess effects of initiation of ART at different CD4 count strata. Continued followup of patients taking ART is needed to further understand effects of long-term exposure to ART, as many patients are exposed for far longer than the 6 years evaluated in the longest studies to date. The Strategic Timing of Antiretroviral Treatment randomized trial, which compares initiation of ART at CD4 counts >0.500 × 10^9^ cells/L compared with deferred treatment until CD4 counts decline to <0.350 × 10^9^ cells/L, is currently in its recruitment phase and should help further clarify effects of very early initiation of ART.172

## Conclusions

Prior studies have shown that HIV screening is accurate, targeted screening misses a substantial proportion of cases, and treatments are effective in patients with advanced immunodeficiency. New evidence indicates that ART reduces risk of AIDS-defining events and mortality in persons with less advanced immunodeficiency and reduces sexual transmission. More research is needed to understand effects of different screening strategies on the uptake and yield of screening, harms, CD4 count at diagnosis, and linkage to care.