# METHODS

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,66 the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework with the key questions and the patient populations, interventions, and outcomes reviewed (Figure). The target population for HIV screening was nonpregnant adolescents and adults without signs or symptoms of HIV infection. We defined “universal” testing to mean routine testing of all persons ages 13 to 64 years, unless the prevalence of HIV infection has been documented to be <0.1 percent,6 and “targeted” screening to mean routine screening of persons with risk factors or in high-prevalence (>1%) settings.4 We defined “opt-out” testing as screening after notifying the patient that an HIV test will be performed unless the patient declines and “opt-in” testing to mean that screening is offered but only performed if the patient actively agrees to it.6

Figure Analytic Framework for Screening for HIV in Nonpregnant Adolescents and Adults

Key Questions

1. What are the benefits of universal or targeted HIV screening versus no screening or each other in asymptomatic, nonpregnant adolescents and adults on disease transmission, morbidity, mortality, and quality of life?
2. a. What is the yield (number of new diagnoses) of HIV screening at different intervals in nonpregnant adolescents and adults?
  b. What are the effects of universal versus targeted HIV screening on testing acceptability and uptake in nonpregnant adolescents and adults?
  c. What is the effect of opt-out versus opt-in testing or different pre- or post-test HIV counseling methods on screening uptake or rates of followup and linkage to care in nonpregnant adolescents and adults?
  d. What are the adverse effects (including false-positive results and anxiety) of rapid versus standard HIV testing in nonpregnant adolescents and adults not known to be at higher risk?
  e. What are the effects of universal versus targeted HIV screening on CD4 counts at the time of diagnosis?
  f. What are the effects of universal versus targeted HIV screening on rates of followup and linkage to care in nonpregnant adolescents and adults who screen positive?
3. a. To what extent does knowledge of HIV-positive status affect behaviors associated with increased risk for HIV transmission in nonpregnant adolescents and adults?
  b. To what extent does use of ART affect behaviors associated with increased risk for HIV transmission in nonpregnant adolescents and adults?
4. a. How effective is ART in reducing transmission of HIV in nonpregnant adolescents and adults with chronic HIV infection?
  b. How effective is behavioral counseling in reducing transmission of HIV in nonpregnant adolescents and adults with chronic HIV infection?
  c. In asymptomatic, nonpregnant adolescents and adults with chronic HIV infection, what are the effects of initiating ART at different CD4 counts or viral load thresholds on morbidity, mortality, and quality of life?
5. What are the longer-term harms associated with ART in nonpregnant adolescents and adults with chronic HIV infection?
6. a. To what extent are improvements in viremia associated with reductions in HIV transmission rates in nonpregnant adolescents and adults?
  b. To what extent are improvements in risky behaviors associated with reductions in HIV transmission rates in nonpregnant adolescents and adults?

Contextual Question. What is the cost-effectiveness of universal versus targeted HIV screening in low- or average-prevalence populations?

This Figure depicts the analytic framework, which outlines the evidence areas covered in the review, including populations, screening strategies, tests, interventions, and outcomes. The population includes nonpregnant adolescents and adults who are asymptomatic for HIV and screened in settings generalizable to primary care. Pregnant women and dialysis and transplant patients are excluded. There is an initial branch in the framework that splits patients into low-risk or high-risk groups after screening (key question 2a and 2b), and after testing (key question 2c) it further splits patients into HIV antibody positive and negative groups. From the corresponding areas of the framework, harms of rapid versus standard HIV testing in nonpregnant adolescents and adults not known to be at higher risk are assessed (key question 2d), as are the effects of universal versus targeted HIV screening on CD4 counts at the time of diagnosis (key question 2e) and on rates of followup and linkage to care (key question 2f). A subsequent branch splits the framework into those with low CD4 counts or high viral loads and those with high CD4 counts and low viral loads. Key questions 3a and 3b then assess whether knowledge of HIV-positive status or use of antiretroviral therapy affects behaviors, respectively. Interventions then include antiretroviral therapy (key questions 4a and 4c) and behavioral counseling (key question 4b), and an arrow assesses resulting longer-term harms of antiretroviral therapy (key question 5). Intermediate outcomes of the interventions include improved CD4 counts, viremia, and risky behaviors. Clinical health outcomes include reduced premature death and disability or spread of disease. An overarching arrow from screening to the clinical health outcomes addresses key question 1. A dotted line between the intermediate and clinical health outcomes boxes represents associations between viremia (key questions 6a) or risky behaviors (key question 6b) and transmission rates.

A contextual question was also requested by the USPSTF to help inform the report. (Contextual questions are not reviewed using systematic review methodology.)

### Key Questions

Key Question 1. What are the benefits of universal or targeted HIV screening versus no screening or each other in asymptomatic, nonpregnant adolescents and adults on disease transmission, morbidity, mortality, and quality of life?

Key Question 2a. What is the yield (number of new diagnoses) of HIV screening at different intervals in nonpregnant adolescents and adults?

Key Question 2b. What are the effects of universal versus targeted HIV screening on testing acceptability and uptake in nonpregnant adolescents and adults?

Key Question 2c. What is the effect of opt-out versus opt-in testing or different pre- or post-test HIV counseling methods on screening uptake or rates of followup and linkage to care in nonpregnant adolescents and adults?

Key Question 2d. What are the adverse effects (including false-positive results and anxiety) of rapid versus standard HIV testing in nonpregnant adolescents and adults not known to be at higher risk?

Key Question 2e. What are the effects of universal versus targeted HIV screening on CD4 counts at the time of diagnosis?

Key Question 2f. What are the effects of universal versus targeted HIV screening on rates of followup and linkage to care in nonpregnant adolescents and adults who screen positive?

Key Question 3a. To what extent does knowledge of HIV-positive status affect behaviors associated with increased risk of HIV transmission in nonpregnant adolescents and adults?

Key Question 3b. To what extent does use of ART affect behaviors associated with increased risk of HIV transmission in nonpregnant adolescents and adults?

Key Question 4a. How effective is ART in reducing transmission of HIV in nonpregnant adolescents and adults with chronic HIV infection?

Key Question 4b. How effective is behavioral counseling in reducing transmission of HIV in nonpregnant adolescents and adults with chronic HIV infection?

Key Question 4c. In asymptomatic, nonpregnant adolescents and adults with chronic HIV infection, what are the effects of initiating ART at different CD4 counts or viral load thresholds on morbidity, mortality, and quality of life?

Key Question 5. What are the longer-term harms associated with ART in nonpregnant adolescents and adults with chronic HIV infection?

Key Question 6a. To what extent are improvements in viremia associated with reductions in HIV transmission rates in nonpregnant adolescents and adults?

Key Question 6b. To what extent are improvements in risky behaviors associated with reductions in HIV transmission rates in nonpregnant adolescents and adults?

Contextual Question. What is the cost-effectiveness of universal versus targeted HIV screening in low- or average-prevalence populations?

Key question 1 focuses on direct evidence on effects of screening for HIV infection versus no screening or different screening strategies on important health outcomes. Such direct evidence on the effectiveness of screening interventions may be sparse or unavailable. Therefore, the remainder of the analytic framework (key questions 2 through 6) evaluates the chain of indirect evidence needed to link screening for HIV infection with improvement in important health outcomes. Links in the chain of indirect evidence include the performance, yield, and acceptability of the screening test and different screening strategies for identifying HIV infection, the effectiveness of interventions for improving intermediate outcomes (such as reduced risky behaviors) or clinical outcomes (such as mortality, AIDS-related events, and HIV transmission), and any harms associated with screening and subsequent interventions. Implicit in the indirect chain of evidence is that to understand benefits and harms of screening, it is not sufficient to show that patients with HIV infection can be identified; it is also necessary to show that identification leads to effective treatments, and to understand how many screen-detected patients (e.g., based on CD4 count at diagnosis) are likely to benefit from treatments.

Because this review is a targeted update that focuses on research gaps identified in the 2005 USPSTF review and subsequent update,1-3 it does not cover all aspects relevant to HIV screening. The general diagnostic accuracy of HIV testing was not re-reviewed, since it is well established as a very accurate test, and direct harms of screening compared with no screening (e.g., labeling and anxiety) were not re-reviewed, given that direct harms associated with screening were estimated as minimal to small and are likely unchanged. Similarly, the general effectiveness of ART, prophylaxis for opportunistic infections, and immunizations was not re-reviewed. Instead, this report focuses on new evidence on the effectiveness of ART in patients with less immunologically advanced disease and harms of long-term ART; the yield of repeat screening and the effects of different screening strategies on uptake of screening, linkage to care, and CD4 counts at diagnosis; the effects of knowledge of positive HIV status and subsequent interventions on risky behaviors and transmission risk; and the association between changes in risky behaviors and transmission risk. This report also addresses areas not covered in the prior report on effects of different screening methods (e.g., rapid vs. standard testing, different methods of pretest counseling, opt-out vs. opt-in testing) on uptake, CD4 count at diagnosis, linkage to followup care, and harms, in order to help inform optimal screening strategies.

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through the second quarter of 2012) and Ovid MEDLINE (2004 through June 2012) for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each key question (Appendix A2). Articles were selected for full review if they were about HIV infection in nonpregnant adolescents and adults, were relevant to a key question, and met the predefined inclusion criteria. We restricted inclusion to English-language articles and excluded studies only published as abstracts. Studies of nonhuman subjects were also excluded, and studies had to include original data.

For key questions related to screening, we included studies of nonpregnant adolescents and adults. Prenatal screening for HIV infection is covered in a separate review.5 For key questions related to interventions and behavior changes after diagnosis, we included studies of HIV-positive persons, focusing when possible on studies not specifically performed in high-risk populations (such as MSM or injection drug users) or high-prevalence populations. We excluded studies from countries with high HIV prevalence and in which management practices differ substantially from the United States, unless evidence from settings more applicable to the United States was not available. The screening interventions were standard or rapid HIV antibody testing and screening strategies included universal or targeted screening and opt-in or opt-out testing. For treatment interventions, we focused on ART and counseling and other interventions to reduce risky behaviors. Outcomes were mortality, progression to AIDS, other morbidity and quality of life, HIV transmission risk, and harms from screening (including false-positive results and anxiety) and long-term (defined as 2 or more years following initiation of treatment) cardiovascular harms associated with ART. We included randomized, controlled trials and cohort studies for all key questions. If such studies were not available, we also included uncontrolled screening series in low-risk populations. We also included recent (published since 2010) systematic reviews that met all predefined quality criteria.67 Appendix A3 shows the results of our literature search and selection process and Appendix A4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

We abstracted details about the study design, patient population, setting, screening method, interventions, analysis, followup, and results. Two investigators independently applied criteria developed by the USPSTF66 to rate the quality of each study as good, fair, or poor (Appendixes A5 and A6). Discrepancies were resolved through a consensus process.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each key question (good, fair, or poor) using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence.66 Meta-analysis was not attempted due to the inability to pool data from studies.

## External Review

The draft report was be reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners and revised prior to finalization (Appendix A7).