# INTRODUCTION

## Purpose of Review and Prior USPSTF Recommendations

The purpose of this report is to update a previous systematic review1-3 commissioned by the U.S. Preventive Services Task Force (USPSTF) on screening for asymptomatic HIV infection in nonpregnant adults and adolescents. It will be used by the USPSTF to update its 2005 recommendation on screening for HIV in nonpregnant adolescents and adults.4 A separate report updates the evidence on prenatal HIV screening.5

In 2005, based on the earlier evidence review,1-3 the USPSTF recommended screening all adolescents and adults at increased risk (defined as persons reporting HIV risk factors or evaluated in settings with an HIV infection prevalence of >1%) for HIV infection (grade A recommendation).4 The USPSTF based its recommendation on the high yield of screening in these patients, good evidence that standard and rapid HIV screening tests accurately detect HIV infection (sensitivity and specificity each >99%), and good evidence that identification and treatment of unsuspected HIV infection at immunologically advanced stages of disease (defined as CD4 counts <0.200 × 10^9^ cells/L) with antiretroviral therapy (ART) and other interventions (such as prophylaxis for opportunistic infections) results in marked reduction in risk of progression to acquired immunodeficiency syndrome (AIDS) and AIDS-related clinical events and mortality. Although the USPSTF found ART associated with short-term adverse events and increased risk of long-term cardiovascular events, it determined that estimated benefits greatly outweighed harms.

The USPSTF made no recommendation for or against routinely screening for HIV in adolescents and adults not at increased risk for HIV infection (grade C recommendation^*^).4 Because of the lower prevalence of HIV infection in persons not at increased risk, the USPSTF determined that benefits from screening would be smaller than screening in higher-risk populations, resulting in a close balance between potential benefits and harms, including false-positive results, labeling, anxiety, and adverse events associated with ART and other interventions. Importantly, the USPSTF found insufficient evidence to estimate benefits from screening in persons at less immunologically advanced stages of disease (CD4 counts >0.200 × 10^9^ cells/L) or effects of screening and subsequent interventions on risk of HIV transmission.

* The USPSTF definition of a “C” recommendation has changed since this guideline was published. In 2005, a “C” recommendation indicated that the USPSTF “makes no recommendation for or against” routinely screening this population. Now, a “C” recommendation indicates that “clinicians may provide this service to selected patients depending on individual circumstances. However, for most individuals without signs or symptoms there is likely to be only a small benefit from this service.”

In 2006, the Centers for Disease Control and Prevention (CDC) issued its revised guideline recommending routine voluntary HIV screening of all persons ages 13 to 64 years, unless the prevalence of undiagnosed HIV infection has been documented to be <0.1 percent.6 The CDC also recommended that testing be performed on an opt-out basis (screening after notifying the patient that an HIV test will be performed unless the patient declines) without a requirement for pretest prevention counseling, in order to reduce barriers to screening. A key reason for the differences between the CDC and USPSTF recommendations is evidence showing that 20 to 26 percent of patients with HIV infection report no risk factors,7 suggesting that any screening strategy based on risk factor identification will miss an important proportion of infected persons. Other reasons for the differences between the CDC and USPSTF recommendations include greater weight placed by the CDC on studies showing reductions in self-reported risky behaviors following diagnosis of HIV infection, acceptance of modeling studies to estimate effects of HIV diagnosis and reductions in risky behaviors on transmission risk, and greater weight placed on studies showing acceptable incremental cost-effectiveness ratios for screening versus no screening in very low-prevalence populations. The USPSTF subsequently commissioned a focused update of its 2005 report with the studies included in the CDC guideline,1 but found insufficient evidence to change its C recommendation on screening in persons not at higher risk.4 The USPSTF found methodological shortcomings in the studies showing reduced risky behaviors following HIV diagnosis, which made estimations of reductions in transmission risk unreliable. In addition, some evidence suggested that cost-effectiveness of HIV screening in low-prevalence populations is sensitive to transmission benefits, and the cost-effectiveness analyses did not compare universal with targeted screening in low-prevalence settings.8, 9

This report updates the prior USPSTF review on the benefits and harms of HIV screening in nonpregnant adolescents and adults, focusing on key research gaps identified in the earlier review, including the yield and outcomes of routine versus targeted screening; periodicity of screening; effects of screening, counseling, and ART use on risky behaviors and HIV transmission risk; effectiveness of treatments in HIV-infected persons with CD4 counts >0.200 × 10^9^ cells/L, and long-term harms of ART. This report also addresses areas not addressed in the prior USPSTF review, including effects of different screening methods (e.g., rapid vs. standard testing, different methods of pretest counseling, opt-out vs. opt-in testing) on uptake, CD4 count at diagnosis, linkage to followup care, and harms, in order to help inform optimal screening strategies. This report does not re-examine evidence considered to be well-established, such as the diagnostic accuracy of HIV screening tests, the effectiveness of ART in persons with CD4 counts <0.200 × 10^9^ cells/L, or the effectiveness of prophylaxis for opportunistic infections.2, 3 The review primarily focuses on evidence from studies of low- or average-risk populations, as there is strong evidence supporting screening in high-risk populations, with consensus across guidelines.4, 6

## Condition Definition

HIV is a ribonucleic acid (RNA) retrovirus that infects the immune cells of its human hosts, in particular, CD4 helper T cells, and leads to AIDS in most patients if left untreated. HIV is a communicable disease with two types: HIV-1 and HIV-2. HIV-2 infection is very uncommon in the United States, primarily affects persons from West Africa, and is less likely to progress to AIDS.10 AIDS is a life-threatening disease defined by severe immune dysfunction (CD4 T cell count ≤0.200 × 10^9^ cells/L) or one or more neoplastic conditions or opportunistic infections.11

## Prevalence and Burden of Disease

Since the first cases of AIDS were reported in 1981, an estimated 1,108,611 people in the United States have been diagnosed with AIDS and nearly 594,500 have died.12 The CDC estimates that 1.2 million people in the United States were living with HIV infection in 2008, with approximately one in five infected persons unaware of their positive status.12-14 The incidence of HIV in the United States is approximately 50,000 cases per year.12, 15 Although incidence prior to 2006 was estimated at about 40,000 cases per year,16 these data are not directly comparable with current estimates because methods for estimating incidence have changed.15 Estimates of HIV incidence were relatively stable from 2006 through 2009.^12, 15^

The groups most affected by HIV infection in the United States are gay and bisexual men, African Americans, and Hispanics/Latinos. Between 2006 and 2009, there was a 21 percent increase in HIV incidence for people ages 13 to 29 years, driven largely by a 34 percent increase in young men who have sex with men (MSM), who were the only risk group to experience a significant increase in incidence during this period (p<0.001).15 Approximately 75 percent of people living with HIV are men.17 CDC data from 40 States in 2009 estimated prevalence at 0.02 percent (19.5 cases per 100,000 persons) for 13- to 14-year-olds and 0.04 percent (39 cases per 100,000 persons) for 15- to 19-year-olds. For 20- to 24-year-olds, the prevalence was 0.13 percent. Prevalence increases through ages 40 to 49 years (0.7%), where it then decreases to 0.2 percent in ages 60 to 64 years and to 0.07 percent at age 65 years and older.18

## Etiology and Natural History

HIV is acquired through percutaneous exposure with infected bodily fluids such as blood, semen, and genital tract secretions. Factors facilitating sexual transmission include the presence of sexually transmitted diseases (STDs), high-risk sexual practices such as unprotected penile-anal intercourse, and high viral load in the infected partner.19, 20 In injection drug users, factors associated with HIV infection include increased frequency or duration of injection, sharing needles, and backloading (injecting drugs from one syringe into the back of another opened syringe).21

The primary HIV infection syndrome usually develops 2 to 4 weeks following initial exposure to HIV.22 A clinical syndrome resembling infectious mononucleosis is often associated with acute infection.23, 24 Very early after acute infection, there is rapid virus production that declines to a set point (which varies between individuals) as the host immune system responds, although continuous rapid virus production and clearance occurs at all stages of infection.25-30

Although a small proportion of untreated HIV-infected persons remain asymptomatic and show little evidence of progressive immune suppression after 10 or more years of infection, over 90 percent of untreated patients eventually develop AIDS.11 Before the highly active antiretroviral therapy (HAART) era, the median time from seroconversion to the development of AIDS was 7.7 to 11.0 years, and median survival ranged from 7.5 to 12 years.31, 32

The primary mechanism through which chronic HIV infection causes immune deficiency is through a decrease in the level and functioning of CD4+ T lymphocytes. On average, the CD4 count declines 0.050 to 0.075 × 10^9^ cells/L per year.33 Most patients with CD4 counts >0.200 × 10^9^ cells/L are either asymptomatic or have mild disease,34 though research indicates an increased risk of AIDS or death even in patients with CD4 counts >0.500 × 10^9^ cells/L.35 Patients with CD4 counts <0.200 × 10^9^ cells/L have advanced immunodeficiency and are at markedly increased risk for AIDS-related opportunistic infections and other AIDS-related complications.36-38

A higher HIV viral load is a strong independent predictor of more rapid progression to AIDS.36-41 Other predictors of more rapid progression include older age at the time of infection,31, 32, 36, 37, 40, 42, 43 more severe symptoms at the time of primary HIV infection,44 and other clinical and genetic factors. A host factor consistently associated with slow progression is the homozygous presence of the CCR5 delta32 genotype.45-49

## Risk Factors/Indicators

Persons considered to be at increased risk for HIV infection include MSM; men and women having unprotected vaginal or anal intercourse with more than one partner; men and women who exchange sex for drugs or money; people with a history of or current injection drug use; people seeking treatment for other sexually transmitted infections (STIs); people with a history of blood transfusion between 1978 and 1985; people whose past or present sex partners are HIV-infected, bisexual, or injection drug users; and people who do not report one of these risk factors but who request HIV testing. Settings in which the prevalence of HIV infection is often >1 percent include STD clinics, correctional facilities, homeless shelters, tuberculosis clinics, clinics caring predominately for MSM, and adolescent clinics with a high prevalence of STIs.3

## Rationale for Screening/Screening Strategies

Identification and treatment of asymptomatic HIV-positive individuals may lead to interventions that reduce the risk of progression to AIDS, AIDS-defining clinical events, and mortality. The 2005 USPSTF review found treatment (including ART and prophylaxis for opportunistic infections) of HIV-infected persons with immunologically advanced disease (CD4 counts ≤0.200 × 10^9^ cells/L) associated with substantially improved health outcomes.3 More evidence is now available on the effectiveness of treatments for patients with less immunologically advanced disease (see key question 4c). In addition, screening may help identify patients at higher CD4 counts before they develop severe immune deficiency or present with an AIDS-defining event. Earlier detection of asymptomatic HIV-positive patients may also help reduce the risk of transmission to others, through effects of knowledge of positive HIV serostatus or counseling interventions on behaviors, or through other interventions (such as use of ART) that may reduce the risk of transmission. It is estimated that approximately 20,000 infections per year are due to transmission of HIV by persons who are unaware that they are infected.50, 51

## Interventions/Treatment

There remains no effective vaccine to prevent HIV infection and no cure for chronic infection. Interventions for HIV-infected patients include ART, prophylaxis for opportunistic infections, immunizations, Papanicolaou testing, counseling to reduce high-risk behaviors, and routine monitoring and followup. HAART, defined as three or more antiretroviral agents used in combination (usually from at least two drug classes), is the standard of care for ART (because all currently recommended antiretroviral regimens meet criteria for HAART, this report will primarily simply refer to “antiretroviral therapy,” in accordance with current treatment guidelines).52 Of the interventions used to treat chronic HIV infection, ART has the greatest impact on clinical outcomes, including survival.53 Clinical practice has generally evolved toward earlier initiation of ART in asymptomatic individuals, though decisions are more individualized at higher CD4 counts (>0.350 × 10^9^ cells/L).52 Detailed and regularly updated guidelines for the U.S. population regarding specifically recommended antiretroviral regimens52 and chemoprophylaxis for opportunistic infections54 are available.

## Current Clinical Practice

The use of repeatedly reactive enzyme immunoassay on an office-based venipuncture specimen followed by confirmatory Western blot or immunofluorescent assay for positive tests is associated with a sensitivity and specificity >99 percent.55, 56 Rapid, point-of-care HIV antibody tests on blood or oral fluid specimens provide results in 5 to 40 minutes compared with 1 to 2 weeks for standard testing, with diagnostic accuracy comparable with standard testing.57, 58 However, initial positive results on a rapid test can represent false-positives and require confirmation. A revised CDC HIV testing algorithm is expected in 2012. The algorithm, which will utilize combination immunoassays that screen simultaneously for both the p24 antigen and HIV antibody and test for HIV RNA without requiring Western blot confirmation, is intended to detect acute HIV infection earlier and to differentiate HIV-2 from HIV-1 infection.59

About 45 percent of U.S. adults ages 18 to 64 years report ever being tested for HIV infection.60 Screening rates for HIV vary by State, age, sex, race/ethnicity, and other factors. For example, African Americans and Latinos are more likely to report testing than whites.

## Recommendations of Other Groups

As described above, in 2006 the CDC recommended routine voluntary HIV screening of all adults ages 13 to 64 years regardless of other recognized risk factors, unless the prevalence of HIV has been documented to be <0.1 percent.6 The CDC also recommended “opt-out” HIV testing, meaning that all patients should be informed about testing and tested unless they specifically decline, without a requirement for prevention counseling prior to screening in order to reduce barriers to testing. In 2009, the American College of Physicians endorsed the CDC approach.61 The Infectious Diseases Society of America recommends routine HIV screening for all sexually active adults,62 the American Congress of Obstetricians and Gynecologists recommends routine opt-out screening in all women ages 19 to 64 years and targeted screening in women with risk factors outside of that age range,63 and the American Academy of Pediatrics recommends routine HIV testing be offered to all adolescents at least once by ages 16 to 18 years when prevalence of HIV is >0.1 percent in the community and testing of all sexually active adolescents and those with risk factors in low-prevalence settings.64 In 2007, the American Academy of Family Physicians recommended screening for HIV in high-risk groups and in areas where the HIV prevalence is at least 1 percent.65