# EVIDENCE AND QUALITY TABLES

Appendix B1 Key Question 2b: Evidence Table of Studies of Acceptability/Uptake of Universal or Targeted HIV Testing

Appendix B2 Key Question 2b: Quality Assessment of a Cohort Study

Appendix B3 Key Question 2c: Evidence Table of Studies of Testing Rates of Opt-Out Versus Opt-In HIV Testing

Appendix B4 Key Question 2c: Quality Assessment of Cohort Studies

Appendix B5 Key Question 2e: Evidence Table of Studies of Universal Versus Targeted HIV Screening and CD4 Counts at Time of Diagnosis

Appendix B6 Key Question 2e: Quality Assessment of Cohort Studies

Appendix B7 Key Question 2f: Evidence Table of Studies Reporting Linkage to Care Following HIV Testing

Appendix B8 Key Question 2f: Quality Assessment of a Cohort Study

Appendix B9 Key Question 3a: Evidence Table of Studies of Effect of Knowledge of HIV-Positive Status or Use of Highly Active Antiretroviral Therapy on Risky Behaviors

Appendix B10 Key Question 3a: Quality Assessment of Cohort Studies

Appendix B11 Key Question 3b: Evidence Table of Studies of Effect of Knowledge of HIV-Positive Status or Use of Highly Active Antiretroviral Therapy on Risky Behaviors

Appendix B12 Key Question 3b: Quality Assessment of Cohort Studies

Appendix B13 Key Question 4a: Evidence Table of a Systematic Review of Effects of Counseling or Antiretroviral Therapy Use on HIV Transmission

Appendix B14 Key Question 4a: Quality Assessment of a Systematic Review

Appendix B15 Key Question 4a: Evidence Table of Studies of Effects of Counseling or Antiretroviral Therapy Use on HIV Transmission

Appendix B16 Key Question 4a: Quality Assessment of a Randomized, Controlled Trial

Appendix B17 Key Question 4a: Quality Assessment of Cohort Studies

Appendix B18 Key Question 4b: Evidence Table of Studies of Effects of Counseling or Antiretroviral Therapy Use on HIV Transmission

Appendix B19 Key Question 4b: Quality Assessment of a Randomized Controlled Trial

Appendix B20 Key Question 4b: Quality Assessment of a Cohort Study

Appendix B21 Key Question 4c: Evidence Table of Trials of Effect of Initiating Highly Active Antiretroviral Therapy at Different CD4 Counts or Viral Load Thresholds on Clinical Outcomes

Appendix B22 Key Question 4c: Quality Assessment of Randomized, Controlled Trials

Appendix B23 Key Question 4c: Evidence Table of Cohort Studies of Effects of Initiating Highly Active Antiretroviral Therapy at Different CD4 Counts or Viral Load Thresholds on Clinical Outcomes

Appendix B24 Key Question 4c: Quality Assessment of Cohort Studies

Appendix B25 Key Question 5: Evidence Table of Studies of Longer-Term Harms of Highly Active Antiretroviral Therapy Use

Appendix B26 Key Question 5: Quality Assessment of Cohort Studies

Appendix B27 Key Question 6a: Evidence Table of Studies of Effect of Viremia on HIV Transmission Rates

Appendix B28 Key Question 6a: Quality Assessment of Cohort Studies

Appendix B29 Key Question 6b: Evidence Table of Studies of Effects of Risky Behaviors on HIV Transmission Rates

Appendix B30 Key Question 6b: Quality Assessment of Cohort Studies