# DETAILED METHODS

## Appendix A1 Search Strategies

### All Key Questions

Database: EBM Reviews - Cochrane Database of Systematic Reviews
1. hiv.ti.
2. limit 1 to full systematic reviews
3. antiretroviral.mp. [mp=title, short title, abstract, full text, keywords, caption text]
4. haart.mp. [mp=title, short title, abstract, full text, keywords, caption text]
5. 3 or 4
6. 2 and 5
7. screen$.mp. [mp=title, short title, abstract, full text, keywords, caption text]
8. 2 and 7
9. test$.mp. [mp=title, short title, abstract, full text, keywords, caption text]
10. 2 and 9
11. 6 or 8 or 10
12. limit 11 to last 8 years
13. pregnan$.mp. [mp=title, short title, abstract, full text, keywords, caption text]
14. 12 not 13

### Key Questions 1 and 2a-2f

Database: Ovid MEDLINE(R) without Revisions
1. exp AIDS Serodiagnosis/
2. exp HIV Seronegativity/
3. exp HIV Antigens/
4. exp HIV/
5. exp HIV Seroprevalence/
6. exp HIV Seropositivity/
7. exp HIV Antibodies/
8. or/2-7
9. exp Mass Screening/
10. 8 and 9
11. 1 or 10
12. (hiv adj1 screen$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
13. 11 or 12
14. 13 and (200406$ or 200407$ or 200408$ or 200409$ or 20041$ or 2005$ or 2006$ or 2007$ or 2008$ or 2009$ or 2010$ or 2011$).ed.
15. limit 14 to English language
16. limit 14 to abstracts
17. 15 or 16
18. limit 17 to humans
19. universal.mp.
20. rapid.mp.
21. 19 and 20
22. or/1-8
23. 21 and 22
24. 9 and 21
25. 23 or 24
26. 18 or 25

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. exp AIDS Serodiagnosis/
2. exp HIV Seronegativity/
3. exp HIV Antigens/
4. exp HIV/
5. exp HIV Seroprevalence/
6. exp HIV Seropositivity/
7. exp HIV Antibodies/
8. or/2-7
9. exp Mass Screening/
10. 8 and 9
11. 1 or 10
12. (hiv adj1 screen$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13. 11 or 12
14. limit 13 to yr=“2004 -Current”
15. Pregnancy/
16. 14 not 15

### Key Questions 3a, 3b

Database: Ovid MEDLINE(R) without Revisions
1. HIV Seropositivity/
2. (hiv adj1 positive).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
3. 1 or 2
4. exp Anti-HIV Agents/
5. exp Antiretroviral Therapy, Highly Active/
6. haart.mp.
7. 5 or 6
8. or/3-5,7
9. Sexual Behavior/
10. Unsafe Sex/
11. Safe Sex/
12. Risk-Taking/
13. Needle Sharing/
14. or/9-13
15. 8 and 14
16. Pregnancy/
17. 15 not 16
18. limit 17 to English language
19. limit 17 to abstracts
20. 18 or 19
21. limit 20 to humans

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. HIV Seropositivity/
2. (hiv adj1 positive).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 or 2
4. exp Anti-HIV Agents/
5. exp Antiretroviral Therapy, Highly Active/
6. haart.mp.
7. 5 or 6
8. or/3-5,7
9. Sexual Behavior/
10. Unsafe Sex/
11. Safe Sex/
12. Risk-Taking/
13. Needle Sharing/
14. or/9-13
15. 8 and 14
16. Pregnancy/
17. 15 not 16
18. limit 17 to yr=“2004 -Current”

### Key Questions 4a, 4b

Database: Ovid MEDLINE(R) without Revisions
1. exp HIV Infections/dh, dt, pc, th [Diet Therapy, Drug Therapy, Prevention & Control, Therapy]
2. exp HIV Infections/tm [Transmission]
3. 1 and 2
4. (hiv adj2 (transmission or transmit)).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
5. 3 or 4
6. exp Anti-HIV Agents/tu [Therapeutic Use]
7. haart.mp. or Antiretroviral Therapy, Highly Active/
8. 6 or 7
9. 8 and (2 or 4)
10. Counseling/
11. Patient Education as Topic/
12. 10 or 11
13. 12 and (2 or 4)
14. 5 or 9 or 13
15. Pregnancy/
16. 14 not 15
17. limit 16 to English language
18. limit 16 to abstracts
19. 17 or 18
20. limit 19 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
21. limit 20 to yr=“2004 - Current”

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. exp HIV Infections/dh, dt, pc, th [Diet Therapy, Drug Therapy, Prevention & Control, Therapy]
2. exp HIV Infections/tm [Transmission]
3. 1 and 2
4. (hiv adj2 (transmission or transmit)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. 3 or 4
6. exp Anti-HIV Agents/tu [Therapeutic Use]
7. haart.mp. or Antiretroviral Therapy, Highly Active/
8. 6 or 7
9. 8 and (2 or 4)
10. Counseling/
11. Patient Education as Topic/
12. 10 or 11
13. 12 and (2 or 4)
14. 5 or 9 or 13
15. Pregnancy/
16. 14 not 15
17. limit 16 to yr=“2004 -Current”

### Key Question 4c

Database: Ovid MEDLINE(R) without Revisions
1. exp HIV Infections/dt, th [Drug Therapy, Therapy]
2. haart.mp. or Antiretroviral Therapy, Highly Active/
3. Anti-HIV Agents/ad, tu [Administration & Dosage, Therapeutic Use]
4. Anti-Retroviral Agents/ad, tu [Administration & Dosage, Therapeutic Use]
5. or/1-4
6. Viral Load/
7. CD4 Lymphocyte Count/
8. or/6-7
9. 5 and 8
10. Drug Administration Schedule/
11. (treatment adj1 (tim$ or administration)).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
12. 10 or 11
13. 9 and 12
14. Pregnancy/
15. 13 not 14
16. limit 15 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
17. limit 16 to English language
18. limit 16 to abstracts
19. 17 or 18
20. limit 19 to yr=“2004 - Current”

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. exp HIV Infections/dt, th [Drug Therapy, Therapy]
2. haart.mp. or Antiretroviral Therapy, Highly Active/
3. Anti-HIV Agents/ad, tu [Administration & Dosage, Therapeutic Use]
4. Anti-Retroviral Agents/ad, tu [Administration & Dosage, Therapeutic Use]
5. or/1-4
6. Viral Load/
7. CD4 Lymphocyte Count/
8. or/6-7
9. 5 and 8
10. Drug Administration Schedule/
11. (treatment adj1 (tim$ or administration)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
12. 10 or 11
13. 9 and 12
14. Pregnancy/
15. 13 not 14
16. limit 15 to yr=“2004 -Current”

### Key Question 4c Supplement

Database: Ovid MEDLINE(R) without Revisions
1. exp HIV Infections/dt, th [Drug Therapy, Therapy]
2. haart.mp. or Antiretroviral Therapy, Highly Active/
3. Anti-HIV Agents/ad, tu [Administration & Dosage, Therapeutic Use]
4. Anti-Retroviral Agents/ad, tu [Administration & Dosage, Therapeutic Use]
5. or/1-4
6. Viral Load/
7. CD4 Lymphocyte Count/
8. or/6-7
9. 5 and 8
10. Drug Administration Schedule/
11. (treatment adj1 (tim$ or administration)).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
12. 10 or 11
13. 9 and 12
14. Pregnancy/
15. 13 not 14
16. limit 15 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
17. limit 16 to English language
18. limit 16 to abstracts
19. 17 or 18
20. (treatment adj5 (tim$ or administration or initiation)).mp.
21. 9 and 20
22. 21 not 19
23. limit 22 to English language
24. 23 not 14
25. limit 24 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
26. Prognosis/
27. 9 and 26
28. 27 not (19 or 22)
29. limit 28 to English language
30. limit 29 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
31. 25 or 30

### Key Question 5

Database: Ovid MEDLINE(R) without Revisions
1. haart.mp. or Antiretroviral Therapy, Highly Active/
2. (ae or co or de or mo).fs.
3. 1 and 2
4. (harm$ or safe$ or adverse).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
5. 1 and 4
6. 3 or 5
7. Pregnancy/
8. 6 not 7
9. limit 8 to (“all adult (19 plus years)” or “adolescent (13 to 18 years)”)
10. limit 9 to English language
11. limit 9 to abstracts
12. 10 or 11
13. limit 12 to yr=“2004 - Current”
14. 13 not (letter or editorial or case reports).pt.

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. haart.mp. or Antiretroviral Therapy, Highly Active/
2. (ae or co or de or mo).fs.
3. 1 and 2
4. (harm$ or safe$ or adverse).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. 1 and 4
6. 3 or 5
7. Pregnancy/
8. 6 not 7
9. limit 8 to yr=“2004 -Current”

### Key Questions 6a, 6b

Database: Ovid MEDLINE(R) without Revisions
1. HIV Infections/tm [Transmission]
2. viremia.mp.
3. 1 and 2
4. Risk-Taking/
5. Sexual Behavior/
6. Unsafe Sex/
7. Safe Sex/
8. or/4-7
9. 1 and 8
10. risk reduction behavior/
11. (risk$ adj1 reduc$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
12. 10 or 11
13. 9 and 12
14. 3 or 13
15. Pregnancy/
16. 14 not 15
17. limit 16 to yr=“2004 - Current”

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. HIV Infections/tm [Transmission]
2. viremia.mp.
3. 1 and 2
4. Risk-Taking/
5. Sexual Behavior/
6. Unsafe Sex/
7. Safe Sex/
8. or/4-7
9. 1 and 8
10. risk reduction behavior/
11. (risk$ adj1 reduc$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
12. 10 or 11
13. 9 and 12
14. 3 or 13
15. Pregnancy/
16. 14 not 15
17. limit 16 to yr=“2004 -Current”

## Appendix A2 Inclusion and Exclusion Criteria per Key Question

| Include | Exclude
All Key Questions (KQs)
Settings | Primary care or other settings generalizable to primary care (e.g., family planning clinics, school-based health clinics), other health care settings in which screening is commonly performed (e.g., emergency room or urgent care). Focus on studies conducted in the United States and other developed countries, unless studies are not available in those settings. | Developing countries, unless fair- or good-quality trials and studies in the United States are lacking
KQ 1. What are the benefits of universal or targeted HIV screening vs. no screening or each other in asymptomatic, nonpregnant adolescents and adults on disease transmission, morbidity, mortality, and quality of life?
Populations | Asymptomatic adolescents and adults | Known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Outcomes | Reduction in transmission rates of HIV; morbidity and mortality related to HIV infection and quality of life
Comparisons | Universal or targeted HIV screening vs. no screening, or vs. one another
Study designs | Randomized, controlled trials and controlled observational studies | Uncontrolled observational studies
KQ 2a. What is the yield (number of new diagnoses) of HIV screening at different intervals in nonpregnant adolescents and adults?
Populations | Asymptomatic adolescents and adults | Known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Outcomes | Number of positive test results
Comparisons | Repeat HIV screening vs. one-time screening, or screening at one interval vs. another interval
Study designs | Randomized, controlled trials and controlled observational studies
KQ 2b. What are the effects of universal vs. targeted HIV screening on testing acceptability and uptake in nonpregnant adolescents and adults?
Populations | Asymptomatic adolescents and adults | Known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Outcomes | Testing acceptability and uptake
Comparisons | Universal vs. targeted HIV screening
Study designs | Any
KQ 2c. What is the effect of opt-out vs. opt-in testing or different pre- or post-test HIV counseling methods on screening uptake or rates of followup and linkage to care in nonpregnant adolescents and adults?
Populations | Asymptomatic adolescents and adults | Known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Outcomes | Testing acceptability and uptake or rates of followup
Comparisons | Opt-out vs. opt-in testing, or comparisons of different pre- or post-test HIV counseling methods
Study designs | Any
KQ 2d. What are the adverse effects (including false-positive results and anxiety) of rapid vs. standard HIV testing in nonpregnant adolescents and adults not known to be at higher risk?
Populations | Asymptomatic adolescents and adults | High-risk; known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Outcomes | False-positive results, anxiety, and effects of labeling; partner discord, abuse, or violence
Comparisons | Rapid vs. standard HIV testing
Study designs | Any
KQ 2e. What are the effects of universal vs. targeted HIV screening on CD4 counts at the time of diagnosis?
Populations | Asymptomatic adolescents and adults | Known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Outcomes | CD4 count
Comparisons | Universal or targeted HIV screening vs. no screening, or vs. one another
Study designs | Randomized, controlled trials or controlled observational studies
KQ 2f. What are the effects of universal vs. targeted HIV screening on rates of followup and linkage to care in nonpregnant adolescents and adults who screen positive?
Populations | Asymptomatic adolescents and adults | Known HIV infection, on dialysis, post-transplant, occupational exposure
Interventions | Rapid or standard HIV testing
Outcomes | Rates of followup and linkage to care
Comparisons | Universal or targeted HIV screening
Study designs | Randomized, controlled trials or controlled observational studies
KQ 3a. To what extent does knowledge of HIV-positive status affect behaviors associated with increased risk for HIV transmission in nonpregnant adolescent and adults?
Populations | Asymptomatic persons newly diagnosed with HIV infection | Already or previously taking antiretroviral therapy; acute HIV or subtypes
Comparisons | Knowledge of HIV-positive status vs. not aware
Outcomes | Risky behaviors
Study designs | Randomized, controlled trials or controlled observational studies
KQ 3b. To what extent does use of antiretroviral therapy affect behaviors associated with increased risk for HIV transmission in nonpregnant adolescent and adults?
Populations | Asymptomatic persons newly diagnosed with HIV infection | Already or previously taking antiretroviral therapy; acute HIV or subtypes
Comparisons | Use of antiretroviral therapy vs. no use of antiretroviral therapy
Outcomes | Risky behaviors
Study designs | Randomized, controlled trials or controlled observational studies
KQ 4a. How effective is antiretroviral therapy in reducing transmission of HIV in nonpregnant adolescents and adults with chronic HIV infection?
Populations | HIV-positive adolescents and adults | Acute HIV infection
Interventions | Use of antiretroviral therapy
Comparisons | Use of antiretroviral therapy vs. no use of antiretroviral therapy
Outcomes | Transmission rates
Study designs | Randomized, controlled trials or controlled observational studies
KQ 4b. How effective is behavioral counseling in reducing transmission of HIV in nonpregnant adolescents and adults with chronic HIV infection?
Populations | HIV-positive adolescents and adults | Acute HIV infection
Interventions | Behavioral counseling interventions (pre- and post-test) to reduce risky sexual behaviors or enhance protective sexual behaviors for those who are asymptomatic and identified through screening
Comparisons | Counseling vs. usual care
Outcomes | Transmission rates
Study designs | Randomized, controlled trials or controlled observational studies
KQ 4c. In asymptomatic, nonpregnant adolescents and adults with chronic HIV infection, what are the effects of initiating antiretroviral therapy at different CD4 counts or viral load thresholds on morbidity, mortality, and quality of life?
Populations | HIV-positive adolescents and adults | Acute HIV infection
Interventions | Antiretroviral regimens
Comparisons | Initiation of antiretroviral therapy earlier vs. initiation later
Outcomes | Morbidity and mortality related to HIV infection and quality of life
Study designs | Randomized, controlled trials or controlled observational studies
KQ 5. What are the longer-term harms associated with antiretroviral therapy in nonpregnant adolescents and adults with chronic HIV infection?
Populations | HIV-positive adolescents and adults | Already or previously taking antiretroviral therapy; acute HIV infection
Interventions | Antiretroviral regimens
Outcomes | Cardiovascular harms
Study designs | Any
Timing | Long-term followup defined as ≥2 years
KQ 6a. To what extent are improvements in viremia associated with reductions in HIV transmission rates in nonpregnant adolescents and adults?
Populations | HIV-positive adolescents and adults | Acute HIV or subtypes
Comparisons | Differences in improvements in viral load
Outcomes | HIV transmission rates | Risk perception
Study designs | Randomized, controlled trials or controlled observational studies
KQ 6b. To what extent are improvements in risky behaviors associated with reductions in HIV transmission rates in nonpregnant adolescents and adults?
Populations | HIV-positive adolescents and adults | Acute HIV or subtypes
Comparisons | Differences in self-reported risky behaviors
Outcomes | HIV transmission rates | Risk perception
Study designs | Randomized, controlled trials or controlled observational studies

## Appendix A3 Literature Flow Diagram

^*^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^†^ Other sources include reference lists, suggested by peer reviewers, etc.

^‡^ Some articles are included for more than one key question.

Abbreviations: RCT = randomized, controlled trial; SR = systematic review.

Appendix A3 is a flow chart that summarizes the search and selection of articles related to HIV screening in nonpregnant adolescents and adults. Citations were identified through bibliographic databases, including MEDLINE, Cochrane Central Register of Controlled Trials, and Cochrane Database of Systematic Reviews, as well as through other sources, including experts and reference lists. There were 10,297 abstracts of potentially relevant articles reviewed. After excluding 9,421 abstracts and titles of articles from other sources that were not relevant to key questions, 876 full-text articles received further review. A total of 820 full-text articles were excluded for the following reasons: wrong population (111), wrong intervention (69), wrong outcomes (393), wrong study design for key question (149), no original data (69), inadequate duration (25), and sample size too small (4). For key questions 1 and 2a, no studies were included. For key question 2b, one cohort study and two uncontrolled studies were included. For key question 2c, two cohort studies were included. For key question 2d, five uncontrolled studies were included. For key question 2e, two cohort studies were included. For key question 2f, one cohort study and two uncontrolled studies were included. For key question 3a, four uncontrolled studies were included. For key question 3b, seven observational studies were included. For key question 4a, one systematic review (consisting of one randomized, controlled trial and seven observational studies) was included. For key question 4b, one randomized, controlled trial and one observational study was included. For key question 4c, three randomized, controlled trials and five large cohort studies were included. For key question 5, four cohort studies (in six publications) were included. For key question 6a, six observational studies were included. For key question 6b, two cohort studies were included.

## Appendix A4 Excluded Studies List

### Wrong population

Antiretroviral Therapy Cohort Collaboration. Importance of baseline prognostic factors with increasing time since initiation of highly active antiretroviral therapy: collaborative analysis of cohorts of HIV-1-infected patients. J Acquir Immune Defic Syndr. 15. 2007;46(5):607-15. [pmid: 18043315].
Beckwith CG, Bazerman L, Cornwall AH, Patry E, Poshkus M, Fu J, et al. An evaluation of a routine opt-out rapid HIV testing program in a Rhode Island jail. AIDS Educ Prev. 2011;23(3 Suppl):96-109. [pmid: 21689040].
Beckwith CG, Liu T, Bazerman LB, DeLong AK, Desjardins SF, Poshkus MM, et al. HIV risk behavior before and after HIV counseling and testing in jail: a pilot study. J Acquir Immune Defic Syndr. 2010;53(4):485-90. [pmid: 20035232].
Bini EJ, Currie SL, Shen H, Brau N, Schmidt W, Anand BS, et al. National multicenter study of HIV testing and HIV seropositivity in patients with chronic hepatitis C virus infection. J Clin Gastroenterol. 2006;40(8):732-9. [pmid: 16940888].
Bower M, Weir J, Francis N, Newsom-Davis T, Powles S, Crook T, et al. The effect of HAART in 254 consecutive patients with AIDS-related Kaposi's sarcoma. AIDS. 2009;23(13):1701-6. [pmid: 19550283].
Brady MT, Oleske JM, Williams PL, Elgie C, Mofenson LM, Dankner WM, et al. Declines in mortality rates and changes in causes of death in HIV-1-infected children during the HAART era. J Acquir Immune Defic Syndr. 2010;53(1):86-94. [pmid: 20035164].
Branson BM, Peterman TA, Cannon RO, Ransom R, Zaidi AA. Group counseling to prevent sexually transmitted disease and HIV: a randomized controlled trial. Sex Transm Dis. 1998;25(10):553-60. [pmid: 9858353].
Buckle C, Castillo M. Use of diffusion-weighted imaging to evaluate the initial response of progressive multifocal leukoencephalopathy to highly active antiretroviral therapy: early experience. Am J Neuroradiol. 2010;31(6):1031-5. [pmid: 20360338].
Cabie A, Bissuel F, Abel S, Huc P, Paturel L, Pierre-Francois S. Use of HIV rapid tests in free and anonymous screening consultations in the French West Indies. Med Mal Infect. 2009;39(6):370-4. [pmid: 19346089].
Castelnuovo B, Kiragga A, Kamya MR, Manabe Y. Stavudine toxicity in women is the main reason for treatment change in a 3-year prospective cohort of adult patients started on first-line antiretroviral treatment in Uganda. J Acquir Immune Defic Syndr. 2011;56(1):59-63. [pmid: 20861741].
Casula M, Bosboom-Dobbelaer I, Smolders K, Otto S, Bakker M, de Baar MP, et al. Infection with HIV-1 induces a decrease in mtDNA. J Infect Dis. 2005;191(9):1468-71. [pmid: 15809905].
Casula M, Weverling GJ, Wit FW, Timmermans EC, Stek M, Lange JM, et al. Mitochondrial DNA and RNA increase in peripheral blood mononuclear cells from HIV-1–infected patients randomized to receive stavudine-containing or stavudine-sparing combination therapy. J Infect Dis. 2005;192(10):1794-800. [pmid: 16235179].
Cave J, Edwards SG, Miller RF, Ardeshna KM, Lee SM. Should we implement “opt-out” HIV testing for patients with lymphoma?. Clinical Medicine. 2009;9(4):320-2. [pmid: 19728502].
Celum CL, Buchbinder SP, Donnell D, Douglas JM Jr, Mayer K, Koblin B, et al. Early human immunodeficiency virus (HIV) infection in the HIV Network for Prevention Trials Vaccine Preparedness Cohort: risk behaviors, symptoms, and early plasma and genital tract virus load. J Infect Dis. 2001;183(1):23-35. [pmid: 11106536].
Centers for Disease Control and Prevention. Rapid HIV testing in emergency departments—three U.S. sites, January 2005–March 2006. MMWR Morb Mortal Wkly Rep. 2007;56(24):597-601. [pmid: 17585288].
Chen SC, Wang ST, Chen KT, Yan TR, Tang LH, Lin CC, et al. Analysis of the influence of therapy and viral suppression on high-risk sexual behaviour and sexually transmitted infections among patients infected with human immunodeficiency virus in Taiwan. Clin Microbiol Infect. 2006;12(7):660-5. [pmid: 16774563].
Claassen M, van Zyl GU, Korsman SN, Smit L, Cotton MF, Preiser W. Pitfalls with rapid HIV antibody testing in HIV-infected children in the Western Cape, South Africa. J Clin Virol. 2006;37(1):68-71. [pmid: 16875874].
Clements-Nolle K, Marx R, Pendo M, Loughran E, Estes M, Katz M. Highly active antiretroviral therapy use and HIV transmission risk behaviors among individuals who are HIV infected and were recently released from jail. Am J Public Health. 2008;98(4):661-6. [pmid: 18309132].
Clotet B, Capetti A, Soto-Ramirez LE, Gatell JM, Rowell L, Salgo M, et al. A randomized, controlled study evaluating an induction treatment strategy in which enfuvirtide was added to an oral, highly active antiretroviral therapy regimen in treatment-experienced patients: the INTENSE study. J Antimicrob Chemother. 2008;62(6):1374-8. [pmid: 18782780].
Coenen T, Lundgren J, Lazarus JV, Matic S. Optimal HIV testing and earlier care: the way forward in Europe. HIV Med. 2. 2008:1-5. [pmid: 18557862].
Cohall AT, Dini S, Senathirajah Y, Nye A, Neu N, Powell D, et al. Feasibility of using computer-assisted interviewing to enhance HIV test counseling in community settings. Public Health Rep. 3. 2008:70-7. [pmid: 19166091].
Collaboration of Observational HIV Epidemiological Research Europe Study Group, Bohlius J, Schmidlin K, Costagliola D, Fatkenheuer G, May M, et al. Prognosis of HIV-associated non-Hodgkin lymphoma in patients starting combination antiretroviral therapy. AIDS. 2009;23(15):2029-37. [pmid: 19531926].
Copenhaver M, Chowdhury S, Altice FL. Adaptation of an evidence-based intervention targeting HIV-infected prisoners transitioning to the community: the process and outcome of formative research for the Positive Living Using Safety (PLUS) intervention. AIDS Patient Care STDs. 2009;23(4):277-87. [pmid: 19260773].
Copenhaver MM, Lee IC. Examining the decay of HIV risk reduction outcomes following a community-friendly intervention targeting injection drug users in treatment. J Psychoactive Drugs. 2007;39(3):223-9. [pmid: 18159775].
Cosio D, Heckman TG, Anderson T, Heckman BD, Garske J, McCarthy J. Telephone-administered motivational interviewing to reduce risky sexual behavior in HIV-infected rural persons: a pilot randomized clinical trial. Sex Transm Dis. 2010;37(3):140-6. [pmid: 20118830].
Crepaz N, Marks G. Serostatus disclosure, sexual communication and safer sex in HIV-positive men. AIDS Care. 2003;15(3):379-87. [pmid: 12745398].
Dalal S, Lee CW, Farirai T, Schilsky A, Goldman T, Moore J, et al. Provider-initiated HIV testing and counseling: increased uptake in two public community health centers in South Africa and implications for scale-up. PLoS One. 2011;6(11):e27293. [pmid: 22114668].
Dancy BL, Crittenden KS, Talashek ML. Mothers' effectiveness as HIV risk reduction educators for adolescent daughters. J Health Care Poor Underserved. 2006;17(1):218-39. [pmid: 16520528].
De Luca A, Di Giambenedetto S, Cingolani A, Bacarelli A, Ammassari A, Cauda R. Three-year clinical outcomes of resistance genotyping and expert advice: extended follow-up of the Argenta trial. Antivir Ther. 2006;11(3):321-7. [pmid: 16759048].
Demeter LM, Jiang H, Mukherjee AL, Morse GD, DiFrancesco R, DiCenzo R, et al. A randomized trial of therapeutic drug monitoring of protease inhibitors in antiretroviral-experienced, HIV-1-infected patients. AIDS. 2009;23(3):357-68. [pmid: 19114860].
Desai MM, Rosenheck RA. HIV testing and receipt of test results among homeless persons with serious mental illness. Am J Psychiatry. 2004;161(12):2287-94. [pmid: 15569902].
Dias SF, Matos MG, Goncalves AC. AIDS-related stigma and attitudes towards AIDS-infected people among adolescents. AIDS Care. 2006;18(3):208-14. [pmid: 16546780].
Dzwonek AB, Lawson MS, Cole TJ, Novelli V. Body fat changes and lipodystrophy in HIV-infected children: impact of highly active antiretroviral therapy. J Acquir Immune Defic Syndr. 2006;43(1):121-3. [pmid: 16936560].
El-Bassel N, Gilbert L, Wu E, Witte SS, Chang M, Hill J, et al. Couple-based HIV prevention for low-income drug users from New York City: a randomized controlled trial to reduce dual risks. J Acquir Immune Defic Syndr. 2011;58(2):198-206. [pmid: 21725249].
El-Bassel N, Witte SS, Gilbert L, Wu E, Chang M, Hill J, et al. Long-term effects of an HIV/STI sexual risk reduction intervention for heterosexual couples. AIDS Behav. 2005;9(1):1-13. [pmid: 15812609].
Engsig FN, Gerstoft J, Kronborg G, Larsen CS, Pedersen G, Roge B, et al. Long-term mortality in HIV patients virally suppressed for more than three years with incomplete CD4 recovery: a cohort study. BMC Infect Dis. 2010;10:318. [pmid: 21044307].
Explore Study Group. Effects of a behavioural intervention to reduce acquisition of HIV among men who have sex with men: the Explore randomised controlled study. Lancet. 2004;364:41-50. [pmid: 15234855].
Flaks RC, Burman WJ, Gourley PJ, Rietmeijer CA, Cohn DL. HIV transmission risk behavior and its relation to antiretroviral treatment adherence. Sex Transm Dis. 2003;30(5):399-404. [pmid: 12916130].
Fregonese F, Collins IJ, Jourdain G, Lecoeur S, Cressey TR, Ngo-Giang-Houng N, et al. Predictors of 5-year mortality in HIV-infected adults starting highly active antiretroviral therapy in Thailand. J Acquir Immune Defic Syndr. 2012;60(1):91-8. [pmid: 22293548].
Grund B, Peng G, Gibert CL, Hoy JF, Isaksson RL, Shlay JC, et al. Continuous antiretroviral therapy decreases bone mineral density. AIDS. 2009;23(12):1519-29. [pmid: 19531929].
Guaraldi G, Cocchi S, Motta A, Ciaffi S, Codeluppi M, Bonora S, et al. Efficacy and safety of atazanavir in patients with end-stage liver disease. Infection. 2009;37(3):250-5. [pmid: 19471855].
Herman JS, Easterbrook PJ. The metabolic toxicities of antiretroviral therapy. Int J STD AIDS. 2001;12(9):555-64. [pmid: 11516363].
Ickovics JR, Druley JA, Grigorenko EL, Morrill AC, Beren SE, Rodin J. Long-term effects of HIV counseling and testing for women: behavioral and psychological consequences are limited at 18 months posttest. Health Psychol. 1998;17(5):395-402. [pmid: 9775997].
Katlama C, Haubrich R, Lalezari J, Lazzarin A, Madruga JV, Molina JM, et al. Efficacy and safety of etravirine in treatment-experienced, HIV-1 patients: pooled 48 week analysis of two randomized, controlled trials. AIDS. 2009;23(17):2289-300. [pmid: 19710593].
Kavasery R, Maru DS, Cornman-Homonoff J, Sylla LN, Smith D, Altice FL. Routine opt-out HIV testing strategies in a female jail setting: a prospective controlled trial. PLoS One. 2009;4(11):e7648. [pmid: 19946370].
Kavasery R, Maru DS, Sylla LN, Smith D, Altice FL. A prospective controlled trial of routine opt-out HIV testing in a men's jail. PLoS One. 2009;4(11):e8056. [pmid: 19946371].
Kawichai S, Celentano DD, Vongchak T, Beyrer C, Suriyanon V, Razak MH, et al. HIV voluntary counseling and testing and HIV incidence in male injecting drug users in northern Thailand: evidence of an urgent need for HIV prevention. J Acquir Immune Defic Syndr. 2006;41(2):186-93. [pmid: 16394851].
Kawichai S, Nelson KE, Natpratan C, Celentano DD, Khamboonruang C, Natpratan P, et al. Personal history of voluntary HIV counseling and testing (VCT) among adults aged 19–35 years living in peri-urban communities, Chiang Mai, northern Thailand. AIDS Behav. 2005;9(2):233-42. [pmid: 15933842].
Kerndt PR, Dubrow R, Aynalem G, Mayer KH, Beckwith C, Remien RH, et al. Strategies used in the detection of acute/early HIV infections: the NIMH Multisite Acute HIV Infection Study, I. AIDS Behav. 2009;13(6):1037-45. [pmid: 19495954].
Kiene SM, Bateganya M, Wanyenze R, Lule H, Nantaba H, Stein MD. Initial outcomes of provider-initiated routine HIV testing and counseling during outpatient care at a rural Ugandan hospital: risky sexual behavior, partner HIV testing, disclosure, and HIV care seeking. AIDS Patient Care STDs. 2010;24(2):117-26. [pmid: 20059356].
Kim JY, Zaoutis T, Chu J, Zhao H, Rutstein R. Effects of highly active antiretroviral therapy (HAART) on cholesterol in HIV-1 infected children: a retrospective cohort study. Pharmacoepidemiol Drug Saf. 2009;18(7):589-94. [pmid: 19402031].
Koblin B, Chesney M, Coates T, Team ES. Effects of a behavioural intervention to reduce acquisition of HIV infection among men who have sex with men: the EXPLORE randomised controlled study. Lancet. 2004;364(9428):41-50. [pmid: 15234855].
Koenig LJ, Pals SL, Chandwani S, Hodge K, Abramowitz S, Barnes W, et al. Sexual transmission risk behavior of adolescents with HIV acquired perinatally or through risky behaviors. J Acquir Immune Defic Syndr. 2010;55(3):380-90. [pmid: 20802343].
Koulinska IN, Villamor E, Chaplin B, Msamanga G, Fawzi W, Renjifo B, et al. Transmission of cell-free and cell-associated HIV-1 through breast-feeding. J Acquir Immune Defic Syndr. 2006;41(1):93-9. [pmid: 16340480].
Kuhn L, Aldrovandi GM, Sinkala M, Kankasa C, Semrau K, Kasonde P, et al. Differential effects of early weaning for HIV-free survival of children born to HIV-infected mothers by severity of maternal disease. PLoS One. 2009;4(6):e6059. [pmid: 19557167].
Kuhn L, Aldrovandi GM, Sinkala M, Kankasa C, Semrau K, Mwiya M, et al. Effects of early, abrupt weaning on HIV-free survival of children in Zambia. N Engl J Med. 2008;359(2):130-41. [pmid: 18525036].
Kuhn L, Sinkala M, Semrau K, Kankasa C, Kasonde P, Mwiya M, et al. Elevations in mortality associated with weaning persist into the second year of life among uninfected children born to HIV-infected mothers. Clin Infect Dis. 2010;50(3):437-44. [pmid: 20047479].
Kuhn L, Trabattoni D, Kankasa C, Semrau K, Kasonde P, Lissoni F, et al. Alpha-defensins in the prevention of HIV transmission among breastfed infants. J Acquir Immune Defic Syndr. 2005;39(2):138-42. [pmid: 15905728].
Kuhn L, Trabattoni D, Kankasa C, Sinkala M, Lissoni F, Ghosh M, et al. HIV-specific secretory IgA in breast milk of HIV-positive mothers is not associated with protection against HIV transmission among breast-fed infants. J Pediatr. 2006;149(5):611-6. [pmid: 17095329].
Kumar A, Kilaru KR, Forde S, Waterman I. Uptake of health care services and health status of HIV-infected women diagnosed through antenatal HIV screening in Barbados, 1996–2004. Rev Panam Salud Publica. 2007;22(6):376-82. [pmid: 18291056].
Kumar A, Rocheste E, Gibson M, Gibson T, Robinson H, Forde S. Antenatal voluntary counseling and testing for HIV in Barbados. Success and barriers to implementation. Rev Panam Salud Publica. 2004;15(4):242-8. [pmid: 15193179].
Kumar A, St White H, Carter AO. Trends in the uptake of antenatal voluntary counselling and testing for HIV and HIV prevalence among childbearing women in Barbados, 1993–2004 evidence to gauge the effectiveness of HIV prevention measures. West Indian Med J. 2007;56(1):60-5. [pmid: 17621846].
Kumwenda NI, Hoover DR, Mofenson LM, Thigpen MC, Kafulafula G, Li Q, et al. Extended antiretroviral prophylaxis to reduce breast-milk HIV-1 transmission. N Engl J Med. 2008;359(2):119-29. [pmid: 18525035].
Labarga P, Barreiro P, Martin-Carbonero L, Rodriguez-Novoa S, Solera C, Medrano J, et al. Kidney tubular abnormalities in the absence of impaired glomerular function in HIV patients treated with tenofovir. AIDS. 2009;23(6):689-96. [pmid: 19262355].
Lindsell CJ, Hart KW, Lyons MS. A simple method for estimating the prevalence of undiagnosed HIV infection in an emergency department. Ann Emerg Med. 2011;58(Suppl 1):S23-7. [pmid: 21684403].
Lindsey JC, Hughes MD, McKinney RE, Cowles MK, Englund JA, Baker CJ, et al. Treatment-mediated changes in human immunodeficiency virus (HIV) type 1 RNA and CD4 cell counts as predictors of weight growth failure, cognitive decline, and survival in HIV-infected children. J Infect Dis. 2000;182(5):1385-93. [pmid: 11010839].
Lo J, Abbara S, Shturman L, Soni A, Wei J, Rocha-Filho JA, et al. Increased prevalence of subclinical coronary atherosclerosis detected by coronary computed tomography angiography in HIV-infected men. AIDS. 2010;24(2):243-53. [pmid: 19996940].
Lyons MS, Lindsell CJ, Wayne DB, Ruffner AH, Hart KW, Fichtenbaum CJ, et al. Comparison of missed opportunities for earlier HIV diagnosis in 3 geographically proximate emergency departments. Ann Emerg Med. 2011;58(Suppl 1):S17-22. [pmid: 21684399].
Lyons MS, Raab DL, Lindsell CJ, Trott AT, Fichtenbaum CJ. A novel emergency department based prevention intervention program for people living with HIV: evaluation of early experiences. BMC Health Serv Res. 2007;7:164. [pmid: 17937817].
Maggiolo F, Ripamonti D, Callegaro A, Gregis G, Quinzan G, Suter F. Quadruple-drug induction HAART in advanced HIV infection. HIV Clinical Trials. 2005;6(1):1-4. [pmid: 15765306].
Mallolas J, Podzamczer D, Milinkovic A, Domingo P, Clotet B, Ribera E, et al. Efficacy and safety of switching from boosted lopinavir to boosted atazanavir in patients with virological suppression receiving a LPV/r-containing HAART: the ATAZIP study. J Acquir Immune Defic Syndr. 2009;51(1):29-36. [pmid: 19390327].
Martinez E, Visnegarwala F, Grund B, Thomas A, Gibert C, Shlay J, et al. The effects of intermittent, CD4-guided antiretroviral therapy on body composition and metabolic parameters. AIDS. 2010;24(3):353-63. [pmid: 20057309].
Merchant RC, Clark MA, Langan TJ, Mayer KH, Seage GR 3rd, Degruttola VG. Can computer-based feedback improve emergency department patient uptake of rapid HIV screening?. Ann Emerg Med. 2011;58(Suppl 1):S114-9. [pmid: 21684389].
Miguez-Burbano MJ, de Pool I, Hadrigan S, Jackson J Jr, Angarita I, Then EP, et al. HIV knowledge and risk behaviors among women in law enforcement in Bogota, Colombia: potential role as community educators. J Urban Health. 2005;82(3 Suppl 4):iv43-57. [pmid: 16107439].
Miranda AE, Soares RA, Prado BC, Monteiro RB, Figueiredo NC. Mother to child transmission of HIV in Vitoria, Brazil: factors associated with lack of HIV prevention. AIDS Care. 2005;17(6):721-8. [pmid: 16036258].
Mirkuzie AH, Hinderaker SG, Morkve O. Promising outcomes of a national programme for the prevention of mother-to-child HIV transmission in Addis Ababa: a retrospective study. BMC Health Serv Res. 2010;10:267. [pmid: 20828384].
Miura T, Goto M, Hosoya N, Odawara T, Kitamura Y, Nakamura T, et al. Depletion of mitochondrial DNA in HIV-1-infected patients and its amelioration by antiretroviral therapy. J Med Virol. 2003;70(4):497-505. [pmid: 12794710].
Mizuno Y, Purcell D, Borkowski TM, Knight K, et al. The life priorities of HIV-seropositive injection drug users: findings from a community-based sample. AIDS Behav. 2003;7(4):395-403. [pmid: 14707536].
Moatti JP, Prudhomme J, Traore DC, Juillet-Amari A, Akribi HA, Msellati P, et al. Access to antiretroviral treatment and sexual behaviours of HIV-infected patients aware of their serostatus in Cote d'Ivoire. AIDS. 2003;17:3. [pmid: 14565612].
Molina JM, Cohen C, Katlama C, Grinsztejn B, Timerman A, Pedro Rde J, et al. Safety and efficacy of darunavir (TMC114) with low-dose ritonavir in treatment-experienced patients: 24-week results of POWER 3. J Acquir Immune Defic Syndr. 2007;46(1):24-31. [pmid: 17621237].
Monpoux F, Pugliese P, Berthier F, Cottalorda J, Pradier C. Bridging the gap between adult and paediatric outcomes in HIV-1 vertically infected children: a single-centre comparison with adult data. Acta Paediatr. 2009;98(11):1787-92. [pmid: 19681795].
Moodie EE, Pant Pai N, Klein MB. Is antiretroviral therapy causing long-term liver damage? A comparative analysis of HIV-mono-infected and HIV/hepatitis C co-infected cohorts. PLoS One. 2009;4(2):e4517. [pmid: 19223976].
Moodley D, Esterhuizen TM, Pather T, Chetty V, Ngaleka L. High HIV incidence during pregnancy: compelling reason for repeat HIV testing. AIDS. 2009;23(10):1255-9. [pmid: 19455017].
Morisky DE, Nguyen C, Ang A, Tiglao TV. HIV/AIDS prevention among the male population: results of a peer education program for taxicab and tricycle drivers in the Philippines. Health Educ Behav. 2005;32(1):57-68. [pmid: 15642754].
Mpairwe H, Muhangi L, Namujju PB, Kisitu A, Tumusiime A, Muwanga M, et al. HIV risk perception and prevalence in a program for prevention of mother-to-child HIV transmission: comparison of women who accept voluntary counseling and testing and those tested anonymously. J Acquir Immune Defic Syndr. 2005;39(3):354-8. [pmid: 15980698].
Mustikawati DE, Morineau G, Nurhayati Irmaningrum Y, Riono P, Priohutomo S, et al. Sexual risk taking, sexually transmitted infections and HIV prevalence among four “high-risk” occupational groups of Indonesian men. Sex Transm Infect. 2009;85(5):391-6. [pmid: 19273478].
Muyingo SK, Walker AS, Reid A, Munderi P, Gibb DM, Ssali F, et al. Patterns of individual and population-level adherence to antiretroviral therapy and risk factors for poor adherence in the first year of the DART trial in Uganda and Zimbabwe. J Acquir Immune Defic Syndr. 2008;48(4):468-75. [pmid: 18614918].
Mzileni MO, Longo-Mbenza B, Chephe TJ. Mortality and causes of death in HIV-positive patients receiving antiretroviral therapy at Tshepang Clinic in Doctor George Mukhari Hospital. Pol Arch Med Wewn. 2008;118(10):548-54. [pmid: 19112815].
Nakamoto BK, McMurtray A, Davis J, Valcour V, Watters MR, Shiramizu B, et al. Incident neuropathy in HIV-infected patients on HAART. AIDS Res Hum Retroviruses. 2010;26(7):759-65. [pmid: 20624077].
Nunes EP, Santini de Oliveira M, Mercon M, Zajdenverg R, Faulhaber JC, Pilotto JH, et al. Monotherapy with lopinavir/ritonavir as maintenance after HIV-1 viral suppression: results of a 96-week randomized, controlled, open-label, pilot trial (KalMo study). HIV Clinical Trials. 2009;10(6):368-74. [pmid: 20133267].
Omer SB, Six Week Extended Dose Nevirapine (SWEN) Study Team. Twelve-month follow-up of Six Week Extended Dose Nevirapine randomized controlled trials: differential impact of extended-dose nevirapine on mother-to-child transmission and infant death by maternal CD4 cell count. AIDS. 2011;25(6):767-76. [pmid: 21330912].
Orlando G, Meraviglia P, Cordier L, Meroni L, Landonio S, Giorgi R, et al. Antiretroviral treatment and age-related comorbidities in a cohort of older HIV-infected patients. HIV Med. 2006;7(8):549-57. [pmid: 17105515].
Osih RB, Taffe P, Rickenbach M, Gayet-Ageron A, Elzi L, Fux C, et al. Outcomes of patients on dual-boosted PI regimens: experience of the Swiss HIV cohort study. AIDS Res Hum Retroviruses. 2010;26(11):1239-46. [pmid: 20929393].
Palumbo PE, Raskino C, Fiscus S, Pahwa S, Fowler MG, Spector SA, et al. Predictive value of quantitative plasma HIV RNA and CD4+ lymphocyte count in HIV-infected infants and children. JAMA. 1998;279(10):756-61. [pmid: 9508151].
Parsons JT, Schrimshaw EW, Wolitski RJ, Halkitis PN, Purcell DW, Hoff CC, et al. Sexual harm reduction practices of HIV-seropositive gay and bisexual men: serosorting, strategic positioning, and withdrawal before ejaculation. AIDS. 2005;19:1. [pmid: 15627028].
Pechansky F, Bassani DG, Diemen L, Kessler F, Leukefeld CG, Surratt HL, et al. Using thought mapping and structured stories to decrease HIV risk behaviors among cocaine injectors and crack smokers in the South of Brazil. Rev Bras Psiquiatr. 2007;29(3):233-40. [pmid: 17713693].
Puthanakit T, Oberdorfer A, Akarathum N, Kanjanavanit S, Wannarit P, Sirisanthana T, et al. Efficacy of highly active antiretroviral therapy in HIV-infected children participating in Thailand's National Access to Antiretroviral Program. Clin Infect Dis. 2005;41(1):100-7. [pmid: 15937769].
Quijano G, Drut R. Atherosclerosis and central adiposity in a pediatric patient with AIDS treated with HAART: autopsy findings. Pediatr Dev Pathol. 2006;9(6):474-9. [pmid: 17163794].
Reliquet V, Allavena C, Morineau-Le Houssine P, Mounoury O, Raffi F. Twelve-year experience of nevirapine use: benefits and convenience for long-term management in a French cohort of HIV-1-infected patients. HIV Clinical Trials. 2010;11(2):110-7. [pmid: 20542847].
Rosso R, Bernardini C, Bruzzone B, Secondo G, Icardi G, Viscoli C, et al. Efficacy and safety of darunavir and etravirine in an antiretroviral multi-experienced youth with vertically HIV-1 infection. Eur J Med Res. 2009;14(3):136-8. [pmid: 19380285].
Salazar JC, Cahn P, Yogev R, Negra MD, Castelli-Gattinara G, Fortuny C, et al. Efficacy, safety and tolerability of tipranavir coadministered with ritonavir in HIV-1-infected children and adolescents. AIDS. 2008;22(14):1789-98. [pmid: 18753862].
Samaras K, Gan SK, Peake PW, Carr A, Campbell LV. Proinflammatory markers, insulin sensitivity, and cardiometabolic risk factors in treated HIV infection. Obesity. 2009;17(1):53-9. [pmid: 19008869].
Shet A, Berry L, Mohri H, Mehandru S, Chung C, Kim A, et al. Tracking the prevalence of transmitted antiretroviral drug-resistant HIV-1: a decade of experience. J Acquir Immune Defic Syndr. 1. 2006;41(4):439-46. [pmid: 16652051].
Simpson WM, Johnstone FD, Goldberg DJ, Gormley SM, Hart GJ. Antenatal HIV testing: assessment of a routine voluntary approach. BMJ. 1999;318(7199):1660-1. [pmid: 10373168].
Sobrino-Vegas P, Garcia-San Miguel L, Caro-Murillo AM, Miro JM, Viciana P, Tural C, et al. Delayed diagnosis of HIV infection in a multicenter cohort: prevalence, risk factors, response to HAART and impact on mortality. Curr HIV Res. 2009;7(2):224-30. [pmid: 19275591].
Spielberg F, Kurth AE, Severynen A, Yu-Hsiang H, Moring-Parris D, MacKenzie S, et al. Computer-facilitated rapid HIV testing in emergency care settings: provider and patient usability and acceptability. AIDS Educ Prev. 2011;23(3):206-21. [pmid: 21696240].
Sprinz E, Neto AJ, Bargman E, Green SL, Luo MP, Sylte JR, et al. Substitution with lopinavir/ritonavir improves patient-reported outcomes including quality of life in patients who were intolerant to their antiretroviral therapy. HIV Clinical Trials. 2006;7(6):291-308. [pmid: 17197377].
Stokes SH, McMaster P, Ismail KM. Acceptability of perinatal rapid point-of-care HIV testing in an area of low HIV prevalence in the UK. Arch Dis Child. 2007;92(6):505-8. [pmid: 17293365].
Sturtevant D, Preiksaitis J, Singh A, Houston S, Gill J, Predy G, et al. The feasibility of using an “opt-out” approach to achieve universal HIV testing of tuberculosis patients in Alberta. Can J Public Health. 2009;100(2):116-20. [pmid: 19839287].
Tepper NK, Farr SL, Danner SP, Maupin R, Nesheim SR, Cohen MH, et al. Rapid human immunodeficiency virus testing in obstetric outpatient settings: the MIRIAD study. Am J Obstet Gynecol. 2009;201:1. [pmid: 19576366].
Wawer MJ, Gray RH, Sewankambo NK, Serwadda D, Li X, Laeyendecker O, et al. Rates of HIV-1 transmission per coital act, by stage of HIV-1 infection, in Rakai, Uganda. J Infect Dis. 2005;191(9):1403-9. [pmid: 15809897].
Williams BG, Lloyd-Smith JO, Gouws E, Hankins C, Getz WM, Hargrove J, et al. The potential impact of male circumcision on HIV in Sub-Saharan Africa. PLoS Med. 2006;3(7):e262. [pmid: 16822094].

### Wrong intervention

Almeda J, Casabona J, Matas L, Gonzalez V, Muga R, Sanz B, et al. Evaluation of a commercial enzyme immunoassay for HIV screening in urine. Eur J Clin Microbiol Infect Dis. 2004;23(11):831-5. [pmid: 15480885].
Anaya HD, Hoang T, Golden JF, Goetz MB, Gifford A, Bowman C, et al. Improving HIV screening and receipt of results by nurse-initiated streamlined counseling and rapid testing. J Gen Intern Med. 2008;23(6):800-7. [pmid: 18421508].
Auvert B, Taljaard D, Lagarde E, Sobngwi-Tambekou J, Sitta R, Puren A. Randomized, controlled intervention trial of male circumcision for reduction of HIV infection risk: the ANRS 1265 Trial. PLoS Med. 2005;2(11):e298. [pmid: 16231970].
Bailey RC, Moses S, Parker CB, Agot K, Maclean I, Krieger JN, et al. Male circumcision for HIV prevention in young men in Kisumu, Kenya: a randomised controlled trial. Lancet. 2007;369(9562):643-56. [pmid: 17321310].
Barin F, Meyer L, Lancar R, Deveau C, Gharib M, Laporte A, et al. Development and validation of an immunoassay for identification of recent human immunodeficiency virus type 1 infections and its use on dried serum spots. J Clin Microbiol. 2005;43(9):4441-7. [pmid: 16145089].
Barretina J, Blanco J, Bonjoch A, Llano A, Clotet B, Este JA. Immunological and virological study of enfuvirtide-treated HIV-positive patients. AIDS. 2004;18(12):1673-82. [pmid: 15280778].
Bedimo R, Westfall AO, Mugavero M, Drechsler H, Khanna N, Saag M. Hepatitis C virus coinfection and the risk of cardiovascular disease among HIV-infected patients. HIV Med. 2010;11(7):462-8. [pmid: 20163481].
Beelaert G, Fransen K. Evaluation of a rapid and simple fourth-generation HIV screening assay for qualitative detection of HIV p24 antigen and/or antibodies to HIV-1 and HIV-2. J Virol Methods. 2010;168(1-2):218-22. [pmid: 20561542].
Bourlet T, Pretis C, Pillet S, Lesenechal M, Piche J, Pozzetto B. Comparative evaluation of the VIDAS HIV DUO Ultra assay for combined detection of HIV-1 antigen and antibodies to HIV. J Virol Methods. 2005;127(2):165-7. [pmid: 15967238].
Brown NC, Taylor ED, Mulatu MS, Scott W. Demographic correlates of HIV testing, high-risk behaviors, and condom/STD consultation among a multi-ethnic sample of women. Women Health. 2007;46(2-3):59-76. [pmid: 18160370].
Byakwaga H, Zhou J, Petoumenos K, Law MG, Boyd MA, Emery S, et al. Effect of nucleoside reverse transcriptase inhibitors on CD4 T-cell recovery in HIV-1-infected individuals receiving long-term fully suppressive combination antiretroviral therapy. HIV Med. 2009;10(3):143-51. [pmid: 19207595].
Carpenter KM, Stoner SA, Mikko AN, Dhanak LP, Parsons JT. Efficacy of a web-based intervention to reduce sexual risk in men who have sex with men. AIDS Behav. 2010;14(3):549-57. [pmid: 19499321].
Carpenter LM, Kamali A, Ruberantwari A, Malamba SS, Whitworth JA. Rates of HIV-1 transmission within marriage in rural Uganda in relation to the HIV sero-status of the partners. AIDS. 1999;13(9):1083-9. [pmid: 10397539].
Castro P, Plana M, Gonzalez R, Lopez A, Vilella A, Argelich R, et al. Influence of a vaccination schedule on viral load rebound and immune responses in successfully treated HIV-infected patients. AIDS Res Hum Retroviruses. 2009;25(12):1249-59. [pmid: 19943787].
Collier AC, Ribaudo H, Mukherjee AL, Feinberg J, Fischl MA, Chesney M, et al. A randomized study of serial telephone call support to increase adherence and thereby improve virologic outcome in persons initiating antiretroviral therapy. J Infect Dis. 2005;192(8):1398-406. [pmid: 16170757].
Colon HM, Robles RR, Marrero CA, Reyes JC, Sahai H. Behavioral effects of receiving HIV test results among injecting drug users in Puerto Rico. AIDS. 1996;10(10):1163-8. [pmid: 8874635].
Darbes LA, Chakravarty D, Beougher SC, Neilands TB, Hoff CC. Partner-provided social support influences choice of risk reduction strategies in gay male couples. AIDS Behav. 2012;16(1):159-67. [pmid: 21221756].
Davey RT, Pertel PE, Benson A, Cassell DJ, Gazzard BG, Holodniy M, et al. Safety, tolerability, pharmacokinetics, and efficacy of an interleukin-2 agonist among HIV-infected patients receiving highly active antiretroviral therapy. J Interferon Cytokine Res. 2008;28(2):89-100. [pmid: 18279104].
Durier C, Capitant C, Lascaux AS, Goujard C, Oksenhendler E, Poizot-Martin I, et al. Long-term effects of intermittent interleukin-2 therapy in chronic HIV-infected patients. AIDS. 2007;21(14):1887-97. [pmid: 17721096].
Fang CT, Hsu HM, Twu SJ, Chen MY, Chang YY, Hwang JS, et al. Decreased HIV transmission after a policy of providing free access to highly active antiretroviral therapy in Taiwan. J Infect Dis. 2004;190(5):879-85. [pmid: 15295691].
Fisac C, Fumero E, Crespo M, Roson B, Ferrer E, Virgili N, et al. Metabolic benefits 24 months after replacing a protease inhibitor with abacavir, efavirenz or nevirapine. AIDS. 2005;19(9):917-25. [pmid: 15905672].
Fisher M, Pao D, Murphy G, Dean G, McElborough D, Homer G, et al. Serological testing algorithm shows rising HIV incidence in a UK cohort of men who have sex with men: 10 years application. AIDS. 2007;21(17):2309-14. [pmid: 18090279].
Fontas E, Kousignian I, Pradier C, Poizot-Martin I, Durier C, Weiss L, et al. IL-2 therapy: potential impact of the CD4 cell count at initiation on clinical efficacy—results from the ANRS CO4 cohort. J Antimicrob Chemother. 2010;65(10):2215-23. [pmid: 20702463].
Freeman AE, Sattin RW, Miller KM, Dias JK, Wilde JA. Acceptance of rapid HIV screening in a southeastern emergency department. Acad Emerg Med. 2009;16(11):1156-64. [pmid: 20053236].
Gaydos CA, Hsieh YH, Harvey L, Burah A, Won H, Jett-Goheen M, et al. Will patients “opt in” to perform their own rapid HIV test in the emergency department?. Ann Emerg Med. 2011;58(Suppl 1):S74-8. [pmid: 21684413].
Gibson DR, Flynn NM, Perales D. Effectiveness of syringe exchange programs in reducing HIV risk behavior and HIV seroconversion among injecting drug users. AIDS. 2001;15(11):1329-41. [pmid: 11504954].
Golden MR, Dombrowski JC, Wood RW, Fleming M, Harrington RD. A controlled study of the effectiveness of public health HIV partner notification services. AIDS. 2009;23(1):133-5. [pmid: 19050396].
Golden MR, Wood RW, Buskin SE, Fleming M, Harrington RD. Ongoing risk behavior among persons with HIV in medical care. AIDS Behav. 2007;11(5):726-35. [pmid: 17497217].
Gonzalez R, Vassileva J, Bechara A, Grbesic S, Sworowski L, Novak RM, et al. The influence of executive functions, sensation seeking, and HIV serostatus on the risky sexual practices of substance-dependent individuals. J Int Neuropsychol Soc. 2005;11(2):121-31. [pmid: 15962700].
Greenberg J, Lifshay J, Van Devanter N, Gonzales V, Celentano D. Preventing HIV infection: the effects of community linkages, time, and money on recruiting and retaining women in intervention groups. J Womens Health. 1998;7(5):587-96. [pmid: 9650160].
Hamlyn E, Jones V, Porter K, Fidler S. Antiretroviral treatment of primary HIV infection to reduce onward transmission. Curr Opin HIV AIDS. 2010;5(4):283-90. [pmid: 20543602].
Jackson JB, Barnett S, Piwowar-Manning E, Apuzzo L, Raines C, Hendrix C, et al. A phase I/II study of nevirapine for pre-exposure prophylaxis of HIV-1 transmission in uninfected subjects at high risk. AIDS. 2003;17(4):547-53. [pmid: 12598775].
Jewkes R, Nduna M, Levin J, Jama N, Dunkle K, Khuzwayo N, et al. A cluster randomized-controlled trial to determine the effectiveness of Stepping Stones in preventing HIV infections and promoting safer sexual behaviour amongst youth in the rural Eastern Cape, South Africa: trial design, methods and baseline findings. Trop Med Int Health. 2006;11(1):3-16. [pmid: 16398750].
Jin F, Crawford J, Prestage GP, Zablotska I, Imrie J, Kippax SC, et al. Unprotected anal intercourse, risk reduction behaviours, and subsequent HIV infection in a cohort of homosexual men. AIDS. 2009;23(2):243-52. [pmid: 19098494].
Johnson DF, Sorvillo FJ, Wohl AR, Bunch G, Harawa NT, Carruth A, et al. Frequent failed early HIV detection in a high prevalence area: implications for prevention. AIDS Patient Care STDs. 2003;17(6):277-82. [pmid: 12880491].
Joseph HA, Flores SA, Parsons JT, Purcell DW. Beliefs about transmission risk and vulnerability, treatment adherence, and sexual risk behavior among a sample of HIV-positive men who have sex with men. AIDS Care. 2010;22(1):29-39. [pmid: 20390478].
Koch O, De Silva S, Edwards S, Peake T, George B, Brough G, et al. Does using self-completed sexual history questionnaires in HIV-positive men who have sex with men affect clinical outcomes?. Int J STD AIDS. 2008;19(3):203-5. [pmid: 18397564].
Mansergh G, Marks G, Rader M, Colfax GN, Buchbinder S. Rectal use of nonoxynol-9 among men who have sex with men. AIDS. 2003;17(6):905-9. [pmid: 12660538].
Martin JN, Roland ME, Neilands TB, Krone MR, Bamberger JD, Kohn RP, et al. Use of postexposure prophylaxis against HIV infection following sexual exposure does not lead to increases in high-risk behavior. AIDS. 2004;18(5):787-92. [pmid: 15075514].
Michel L, Giorgi R, Villes V, Poizot-Martin I, Dellamonica P, Spire B, et al. Withdrawal symptoms as a predictor of mortality in patients HIV-infected through drug use and receiving highly active antiretroviral therapy (HAART). Drug Alcohol Depend. 2009;99(1-3):96-104. [pmid: 18774237].
Mohanan P, Kamath A. Family support for reducing morbidity and mortality in people with HIV/AIDS. Cochrane Database Syst Rev. 2009;(3):CD006046. [pmid: 19588378].
Molto J, Ruiz L, Romeu J, Martinez-Picado J, Negredo E, Tural C, et al. Influence of prior structured treatment interruptions on the length of time without antiretroviral treatment in chronically HIV-infected subjects. AIDS Res Hum Retroviruses. 2004;20(12):1283-8. [pmid: 15650419].
Montes de Oca Arjona M, Perez Cano R, Orozco MJ, Martin Aspas A, Guerrero F, Fernandez Gutierrez Del Alamo C, et al. Absence of favourable changes in circulating levels of interleukin-16 or beta-chemokine concentration following structured intermittent interruption treatment of chronic human immunodeficiency virus infection. Clin Microbiol Infect. 2005;11(1):57-62. [pmid: 15649305].
Morgenstern J, Bux DA, Parsons J, Hagman BT, Wainberg M, Irwin T. Randomized trial to reduce club drug use and HIV risk behaviors among men who have sex with men. J Consult Clin Psychol. 2009;77(4):645-56. [pmid: 19634958].
Munoz-Moreno JA, Fumaz CR, Prats A, Ferrer MJ, Negredo E, Perez-Alvarez N, et al. Interruptions of antiretroviral therapy in human immunodeficiency virus infection: are they detrimental to neurocognitive functioning?. J Neurovirol. 2010;16(3):208-18. [pmid: 20450380].
Murri R, Guaraldi G, Lupoli P, Crisafulli R, Marcotullio S, von Schloesser F, et al. Rate and predictors of self-chosen drug discontinuations in highly active antiretroviral therapy-treated HIV-positive individuals. AIDS Patient Care STDs. 2009;23(1):35-9. [pmid: 19183079].
Mussini C, Bedini A, Borghi V, Guaraldi G, Esposito R, Barchi E, et al. CD4 cell-monitored treatment interruption in patients with a CD4 cell count >500 × 106 cells/L. AIDS. 2005;19(3):287-94. [pmid: 15718839].
Mussini C, Pinti M, Bugarini R, Borghi V, Nasi M, Nemes E, et al. Effect of treatment interruption monitored by CD4 cell count on mitochondrial DNA content in HIV-infected patients: a prospective study. AIDS. 2005;19(15):1627-33. [pmid: 16184032].
Outlaw AY, Naar-King S, Parsons JT, Green-Jones M, Janisse H, Secord E. Using motivational interviewing in HIV field outreach with young African American men who have sex with men: a randomized clinical trial. Am J Public Health. 2010;100:1. [pmid: 20147689].
Oyugi JH, Byakika-Tusiime J, Ragland K, Laeyendecker O, Mugerwa R, Kityo C, et al. Treatment interruptions predict resistance in HIV-positive individuals purchasing fixed-dose combination antiretroviral therapy in Kampala, Uganda. AIDS. 2007;21(8):965-71. [pmid: 17457090].
Papasavvas E, Kostman JR, Mounzer K, Grant RM, Gross R, Gallo C, et al. Randomized, controlled trial of therapy interruption in chronic HIV-1 infection. PLoS Med. 2004;1(3):e64. [pmid: 15630469].
Phillips AN, Carr A, Neuhaus J, Visnegarwala F, Prineas R, Burman WJ, et al. Interruption of antiretroviral therapy and risk of cardiovascular disease in persons with HIV-1 infection: exploratory analyses from the SMART trial. Antivir Ther. 2008;13(2):177-87. [pmid: 18505169].
Pogany K, van Valkengoed IG, Prins JM, Nieuwkerk PT, van der Ende I, Kauffmann RH, et al. Effects of active treatment discontinuation in patients with a CD4+ T-cell nadir greater than 350 cells/mm^3^: 48-week Treatment Interruption in Early Starters Netherlands Study (TRIESTAN). J Acquir Immune Defic Syndr. 2007;44(4):395-400. [pmid: 17195761].
Powers AE, Marden SF, McConnell R, Leidy NK, Campbell CM, Soeken KL, et al. Effect of long-cycle structured intermittent versus continuous HAART on quality of life in patients with chronic HIV infection. AIDS. 2006;20(6):837-45. [pmid: 16549967].
Rieg G, Lewis RJ, Miller LG, Witt MD, Guerrero M, Daar ES. Asymptomatic sexually transmitted infections in HIV-infected men who have sex with men: prevalence, incidence, predictors, and screening strategies. AIDS Patient Care STDs. 2008;22(12):947-54. [pmid: 19072101].
Sakarovitch C, Rouet F, Murphy G, Minga AK, Alioum A, Dabis F, et al. Do tests devised to detect recent HIV-1 infection provide reliable estimates of incidence in Africa?. J Acquir Immune Defic Syndr. 2007;45(1):115-22. [pmid: 17460475].
Samet JH, Freedberg KA, Stein MD, Lewis R, Savetsky J, Sullivan L, et al. Trillion virion delay: time from testing positive for HIV to presentation for primary care. Arch Intern Med. 1998;158(7):734-40. [pmid: 9554679].
Schechter M, do Lago RF, Mendelsohn AB, Moreira RI, Moulton LH, Harrison LH, et al. Behavioral impact, acceptability, and HIV incidence among homosexual men with access to postexposure chemoprophylaxis for HIV. J Acquir Immune Defic Syndr. 2004;35(5):519-25. [pmid: 15021317].
Schmidt M, Pichl L, Jork C, Hourfar MK, Schottstedt V, Wagner FF, et al. Blood donor screening with cobas s 201/cobas TaqScreen MPX under routine conditions at German Red Cross institutes. Vox Sang. 2010;98(1):37-46. [pmid: 19682348].
Sena AC, Hammer JP, Wilson K, Zeveloff A, Gamble J. Feasibility and acceptability of door-to-door rapid HIV testing among Latino immigrants and their HIV risk factors in North Carolina. AIDS Patient Care STDs. 2010;24(3):165-73. [pmid: 20214484].
Smith RJ, Bodine EN, Wilson DP, Blower SM. Evaluating the potential impact of vaginal microbicides to reduce the risk of acquiring HIV in female sex workers. AIDS. 2005;19(4):413-21. [pmid: 15750395].
Stein JA, Nyamathi A, Ullman JB, Bentler PM. Impact of marriage on HIV/AIDS risk behaviors among impoverished, at-risk couples: a multilevel latent variable approach. AIDS Behav. 2007;11(1):87-98. [pmid: 16456729].
Steingrover R, Pogany K, Fernandez Garcia E, Jurriaans S, Brinkman K, Schuitemaker H, et al. HIV-1 viral rebound dynamics after a single treatment interruption depends on time of initiation of highly active antiretroviral therapy. AIDS. 2008;22(13):1583-8. [pmid: 18670217].
Tesoriero JM, Battles HB, Heavner K, Leung SY, Nemeth C, Pulver W, et al. The effect of name-based reporting and partner notification on HIV testing in New York State. Am J Public Health. 2008;98(4):728-35. [pmid: 18356570].
Vidanapathirana J, Abramson MJ, Forbes A, Fairley C. Mass media interventions for promoting HIV testing: Cochrane systematic review. Int J Epidemiol. 2006;35(2):233-4. [pmid: 16464935].
Weis SE, Foresman B, Cook PE, Matty KJ. Universal HIV screening at a major metropolitan TB clinic: HIV prevalence and high-risk behaviors among TB patients. Am J Public Health. 1999;89(1):73-5. [pmid: 9987468].
White DA, Scribner AN, Huang JV. A comparison of patient acceptance of fingerstick whole blood and oral fluid rapid HIV screening in an emergency department. J Acquir Immune Defic Syndr. 2009;52(1):75-8. [pmid: 19590430].
Wurcel A, Zaman T, Zhen S, Stone D. Acceptance of HIV antibody testing among inpatients and outpatients at a public health hospital: a study of rapid versus standard testing. AIDS Patient Care STDs. 2005;19(8):499-505. [pmid: 16124844].
Zhang S, van Sighem A, Gras L, Reiss P, Smit C, Kroon F, et al. Clinical significance of transient HIV type-1 viraemia and treatment interruptions during suppressive antiretroviral treatment. Antivir Ther. 2010;15(4):555-62. [pmid: 20587848].

### Wrong Outcomes

Adeyemi O, Rezai K, Bahk M, Badri S, Thomas-Gossain N. Metabolic syndrome in older HIV-infected patients: data from the CORE50 cohort. AIDS Patient Care STDs. 2008;22(12):941-5. [pmid: 19072100].
Akers A, Bernstein L, Henderson S, Doyle J, Corbie-Smith G. Factors associated with lack of interest in HIV testing in older at-risk women. J Womens Health. 2007;16(6):842-58. [pmid: 17678455].
Akers AY, Bernstein L, Doyle J, Corbie-Smith G. Older women and HIV testing: examining the relationship between HIV testing history, age, and lifetime HIV risk behaviors. Sex Transm Dis. 2008;(4):420-3. [pmid: 18362866].
Allen S, Meinzen-Derr J, Kautzman M, Zulu I, Trask S, Fideli U, et al. Sexual behavior of HIV discordant couples after HIV counseling and testing. AIDS. 2003;17(5):733-40. [pmid: 12646797].
Althoff KN, Gange SJ, Klein MB, Brooks JT, Hogg RS, Bosch RJ, et al. Late presentation for human immunodeficiency virus care in the United States and Canada. Clin Infect Dis. 2010;50(11):1512-20. [pmid: 20415573].
Ananworanich J, Gayet-Ageron A, Le Braz M, Prasithsirikul W, Chetchotisakd P, Kiertiburanakul S, et al. CD4-guided scheduled treatment interruptions compared with continuous therapy for patients infected with HIV-1: results of the Staccato randomised trial. Lancet. 2006;368(9534):459-65. [pmid: 16890832].
Ananworanich J, Gayet-Ageron A, Ruxrungtham K, Chetchotisakd P, Prasithsirikul W, Kiertiburanakul S, et al. Long-term efficacy and safety of first-line therapy with once-daily saquinavir/ritonavir. Antivir Ther. 2008;13(3):375-80. [pmid: 18572750].
Annan NT, Nelson M, Mandalia S, Bower M, Gazzard BG, Stebbing J. The nucleoside backbone affects durability of efavirenz- or nevirapine-based highly active antiretroviral therapy in antiretroviral-naive individuals. J Acquir Immune Defic Syndr. 2009;51(2):140-6. [pmid: 19352201].
Antiretroviral Therapy Cohort Collaboration, Mocroft A, Sterne JA, Egger M, May M, Grabar S, et al. Variable impact on mortality of AIDS-defining events diagnosed during combination antiretroviral therapy: not all AIDS-defining conditions are created equal. Clin Infect Dis. 2009;48(8):1138-51. [pmid: 19275498].
Antiretroviral Therapy Cohort Collaboration. Causes of death in HIV-1-infected patients treated with antiretroviral therapy, 1996-2006: collaborative analysis of 13 HIV cohort studies. Clin Infect Dis. 2010;50(10):1387-96. [pmid: 20380565].
Apondi R, Bunnell R, Ekwaru JP, Moore D, Bechange S, Khana K, et al. Sexual behavior and HIV transmission risk of Ugandan adults taking antiretroviral therapy: 3 year follow-up. AIDS. 2011;25(10):1317-27. [pmid: 21522005].
Apuzzo LG, Vaida F, Gallant JE, Ernstrom KB, Little SJ, Routy JP, et al. Tolerability and efficacy of PI versus NNRTI-based regimens in subjects receiving HAART during acute or early HIV infection. J Acquir Immune Defic Syndr. 2009;50(3):267-75. [pmid: 19194317].
Arasteh K, Des Jarlais DC. HIV testing and treatment among at-risk drinking injection drug users. J Int Assoc Physicians AIDS Care. 2009;8(3):196-201. [pmid: 19414827].
Arribas JR, Horban A, Gerstoft J, Fatkenheuer G, Nelson M, Clumeck N, et al. The MONET trial: darunavir/ritonavir with or without nucleoside analogues, for patients with HIV RNA below 50 copies/mL. AIDS. 2010;24(2):223-30. [pmid: 20010070].
Avants SK, Warburton LA, Margolin A. How injection drug users coped with testing HIV-seropositive: implications for subsequent health-related behaviors. AIDS Educ Prev. 2001;13(3):207-18. [pmid: 11459357].
Awad GH, Sagrestano LM, Kittleson MJ, Sarvela PD. Development of a measure of barriers to HIV testing among individuals at high risk. AIDS Educ Prev. 2004;16(2):115-25. [pmid: 15134120].
Bachmann LH, Grimley DM, Waithaka Y, Desmond R, Saag MS, Hook EW 3rd. Sexually transmitted disease/HIV transmission risk behaviors and sexually transmitted disease prevalence among HIV-positive men receiving continuing care. Sex Transm Dis. 2005;32(1):20-6. [pmid: 15614117].
Baggaley RF, White RG, Boily MC. HIV transmission risk through anal intercourse: systematic review, meta-analysis and implications for HIV prevention. Int J Epidemiol. 2010;39(4):1048-63. [pmid: 20406794].
Batterham P, Rice E, Rotheram-Borus MJ. Predictors of serostatus disclosure to partners among young people living with HIV in the pre- and post-HAART eras. AIDS Behav. 2005;9(3):281-7. [pmid: 16088367].
Beckwith CG, Atunah-Jay S, Cohen J, Macalino G, Poshkus M, Rich JD, et al. Feasibility and acceptability of rapid HIV testing in jail. AIDS Patient Care STDs. 2007;21(1):41-7. [pmid: 17263656].
Bedimo RJ, McGinnis KA, Dunlap M, Rodriguez-Barradas MC, Justice AC. Incidence of non-AIDS-defining malignancies in HIV-infected versus noninfected patients in the HAART era: impact of immunosuppression. J Acquir Immune Defic Syndr. 2009;52(2):203-8. [pmid: 19617846].
Bell DN, Martinez J, Botwinick G, Shaw K, Walker LE, Dodds S, et al. Case finding for HIV-positive youth: a special type of hidden population. J Adolesc Health. 2003;33(2 Suppl):10-22. [pmid: 12888283].
Bennett M, Strachan E, Uldall K. Development and initial validation of a brief screener for focused HIV prevention efforts. HIV Med. 2010;11(5):318-25. [pmid: 20002502].
Berenguer J, Gonzalez J, Ribera E, Domingo P, Santos J, Miralles P, et al. Didanosine, lamivudine, and efavirenz versus zidovudine, lamivudine, and efavirenz for the initial treatment of HIV type 1 infection: final analysis (48 weeks) of a prospective, randomized, noninferiority clinical trial, GESIDA 3903. Clin Infect Dis. 2008;47(8):1083-92. [pmid: 18781872].
Bernstein KT, Begier E, Burke R, Karpati A, Hogben M. HIV screening among U.S. physicians, 1999-2000. AIDS Patient Care STDs. 2008;22(8):649-56. [pmid: 18627282].
Bernstein KT, Liu KL, Begier EM, Koblin B, Karpati A, Murrill C. Same-sex attraction disclosure to health care providers among New York City men who have sex with men: implications for HIV testing approaches. Arch Intern Med. 2008;168(13):1458-64. [pmid: 18625927].
Binson D, Woods WJ, Pollack L, Sheon N. Bringing HIV/STI testing programmes to high-risk men. Int J STD AIDS. 2005;16(9):600-4. [pmid: 16176625].
Blair CR, Gill CE, Taylor HM, McGowan CC, Charles PD. Testing for HIV-1 infection in a public developmental center. Tenn Med. 2009;102(9):51-3. [pmid: 19791542].
Blanckenberg DH, Wood R, Horban A, Beniowski M, Boron-Kaczmarska A, Trocha H, et al. Evaluation of nevirapine and/or hydroxyurea with nucleoside reverse transcriptase inhibitors in treatment-naive HIV-1-infected subjects. AIDS. 2004;18(4):631-40. [pmid: 15090768].
Bogart LM, Howerton D, Lange J, Setodji CM, Becker K, Klein DJ, et al. Provider-related barriers to rapid HIV testing in U.S. urban non-profit community clinics, community-based organizations (CBOs) and hospitals. AIDS Behav. 2010;14(3):697-707. [pmid: 18770022].
Boily MC, Baggaley RF, Wang L, Masse B, White RG, Hayes RJ, et al. Heterosexual risk of HIV-1 infection per sexual act: systematic review and meta-analysis of observational studies. Lancet Infect Dis. 2009;9(2):118-29. [pmid: 19179227].
Boily MC, Bastos FI, Desai K, Masse B. Changes in the transmission dynamics of the HIV epidemic after the wide-scale use of antiretroviral therapy could explain increases in sexually transmitted infections: results from mathematical models. Sex Transm Dis. 2004;31(2):100-13. [pmid: 14743073].
Bond L, Lauby J, Batson H. HIV testing and the role of individual- and structural-level barriers and facilitators. AIDS Care. 2005;17(2):125-40. [pmid: 15763709].
Bonney EA, Crosby R, Odenat L. Repeat HIV testing among low-income minority women: a descriptive analysis of factors influencing decisional balance. Ethn Dis. 2004;14(3):330-5. [pmid: 15328933].
Boschi A, Tinelli C, Ortolani P, Arlotti M. Safety and factors predicting the duration of first and second treatment interruptions guided by CD4+ cell counts in patients with chronic HIV infection. J Antimicrob Chemother. 2006;57(3):520-6. [pmid: 16387747].
Bouhnik AD, Preau M, Schiltz MA, Lert F, Obadia Y, Spire B, et al. Unprotected sex in regular partnerships among homosexual men living with HIV: a comparison between sero-nonconcordant and seroconcordant couples (ANRS-EN12-VESPA Study). AIDS. 2007;21(Suppl 1):S43-8. [pmid: 17159586].
Bouldouyre MA, Charreau I, Marchou B, Tangre P, Katlama C, Morlat P, et al. Incidence and risk factors of thrombocytopenia in patients receiving intermittent antiretroviral therapy: a substudy of the ANRS 106-window trial. J Acquir Immune Defic Syndr. 2009;52(5):531-7. [pmid: 19855285].
Bower M, Fisher M, Hill T, Reeves I, Walsh J, Orkin C, et al. CD4 counts and the risk of systemic non-Hodgkin's lymphoma in individuals with HIV in the UK. Haematologica. 2009;94(6):875-80. [pmid: 19336735].
Braithwaite RS, Kozal MJ, Chang CC, Roberts MS, Fultz SL, Goetz MB, et al. Adherence, virological and immunological outcomes for HIV-infected veterans starting combination antiretroviral therapies. AIDS. 2007;21(12):1579-89. [pmid: 17630553].
Brewer DD, Golden MR, Handsfield HH. Unsafe sexual behavior and correlates of risk in a probability sample of men who have sex with men in the era of highly active antiretroviral therapy. Sex Transm Dis. 2006;33(4):250-5. [pmid: 16505748].
Brown J, Kuo I, Bellows J, Barry R, Bui P, Wohlgemuth J, et al. Patient perceptions and acceptance of routine emergency department HIV testing. Public Health Rep. 3. 2008:21-6. [pmid: 19172703].
Brown J, Shesser R, Simon G, Bahn M, Czarnogorski M, Kuo I, et al. Routine HIV screening in the emergency department using the new US Centers for Disease Control and Prevention guidelines: results from a high-prevalence area. J Acquir Immune Defic Syndr. 2007;46(4):395-401. [pmid: 18077831].
Burchell AN, Calzavara LM, Myers T, Schlossberg J, Millson M, Escobar M, et al. Voluntary HIV testing among inmates: sociodemographic, behavioral risk, and attitudinal correlates. J Acquir Immune Defic Syndr. 2003;32(5):534-41. [pmid: 12679706].
Butler DM, Smith DM, Cachay ER, Hightower GK, Nugent CT, Richman DD, et al. Herpes simplex virus 2 serostatus and viral loads of HIV-1 in blood and semen as risk factors for HIV transmission among men who have sex with men. AIDS. 2008;22(13):1667-71. [pmid: 18670228].
Byakwaga H, Murray JM, Petoumenos K, Kelleher AD, Law MG, Boyd MA, et al. Evolution of CD4+ T cell count in HIV-1-infected adults receiving antiretroviral therapy with sustained long-term virological suppression. AIDS Res Hum Retroviruses. 2009;25(6):756-76. [pmid: 19500017].
Bygrave H, Ford N, van Cutsem G, Hilderbrand K, Jouquet G, Goemaere E, et al. Implementing a tenofovir-based first-line regimen in rural Lesotho: clinical outcomes and toxicities after two years. J Acquir Immune Defic Syndr. 2011;56(3):e75-8. [pmid: 21164354].
Cabrero E, Griffa L, Burgos A, HIV Body Physical Changes Study Group. Prevalence and impact of body physical changes in HIV patients treated with highly active antiretroviral therapy: results from a study on patient and physician perceptions. AIDS Patient Care STDs. 2010;24(1):5-13. [pmid: 20095903].
Cade WT, Reeds DN, Mittendorfer B, Patterson BW, Powderly WG, Klein S, et al. Blunted lipolysis and fatty acid oxidation during moderate exercise in HIV-infected subjects taking HAART. Am J Physiol. 2007;292(3):e812-9. [pmid: 17106066].
Calderon Y, Leider J, Hailpern S, Haughey M, Ghosh R, Lombardi P, et al. A randomized control trial evaluating the educational effectiveness of a rapid HIV post-test counseling video. Sex Transm Dis. 2009;36(4):207-10. [pmid: 19265735].
Callegari L, Harper CC, van der Straten A, Kamba M, Chipato T, Padian NS. Consistent condom use in married Zimbabwean women after a condom intervention. Sex Transm Dis. 2008;35(6):624-30. [pmid: 18545141].
Candiani TM, Pinto J, Cardoso CA, Carvalho IR, Dias AC, Carneiro M, et al. Impact of highly active antiretroviral therapy (HAART) on the incidence of opportunistic infections, hospitalizations and mortality among children and adolescents living with HIV/AIDS in Belo Horizonte, Minas Gerais State, Brazil. Cad Saude Publica. 2007;23(Suppl 3):S414-23. [pmid: 17992347].
Carballo-Diéguez A, O'Sullivan L, Lin P, Dolezal C, Pollack L, Catania J. Awareness and attitudes regarding microbicides and nonoxynol-9 use in a probability sample of gay men. AIDS Behav. 2007;11(2):271-6. [pmid: 16775772].
Cardoso SW, Grinsztejn B, Velasque L, Veloso VG, Luz PM, Friedman RK, et al. Incidence of modifying or discontinuing first HAART regimen and its determinants in a cohort of HIV-infected patients from Rio de Janeiro, Brazil. AIDS Res Hum Retroviruses. 2010;26(8):865-74. [pmid: 20672997].
Carnicer-Pont D, de Olalla PG, Cayla JA, AIDS Working Group. HIV infection late detection in AIDS patients of an European city with increased immigration since mid 1990s. Curr HIV Res. 2009;7(2):237-43. [pmid: 19275593].
Carr A, Amin J. Efficacy and tolerability of initial antiretroviral therapy: a systematic review. AIDS. 2009;23(3):343-53. [pmid: 19114855].
Carr A, Ritzhaupt A, Zhang W, Zajdenverg R, Workman C, Gatell JM, et al. Effects of boosted tipranavir and lopinavir on body composition, insulin sensitivity and adipocytokines in antiretroviral-naive adults. AIDS. 2008;22(17):2313-21. [pmid: 18981770].
Carrico AW, Antoni MH, Duran RE, Ironson G, Penedo F, Fletcher MA, et al. Reductions in depressed mood and denial coping during cognitive behavioral stress management with HIV-positive gay men treated with HAART. Ann Behavioral Med. 2006;31(2):155-64. [pmid: 16542130].
Carrico AW, Antoni MH, Weaver KE, Lechner SC, Schneiderman N. Cognitive-behavioural stress management with HIV-positive homosexual men: mechanisms of sustained reductions in depressive symptoms. Chronic Illn. 2005;1(3):207-15. [pmid: 17152183].
Carvalho FT, Goncalves TR, Faria ER, Shoveller JA, Piccinini CA, Ramos MC, et al. Behavioral interventions to promote condom use among women living with HIV. Cochrane Database of Syst Rev. 2011;(9):CD007844. [pmid: 21901711].
Casado A, Badia X, Consiglio E. Health-related quality of life in HIV-infected naive patients treated with nelfinavir or nevirapine associated with ZDV/3TC (the COMBINE-Qol Substudy). HIV Clinical Trials. 2004;5(3):132-9. [pmid: 15248137].
Catz SL, Meredith KL, Mundy LM. Women's HIV transmission risk perceptions and behaviors in the era of potent antiretroviral therapies. AIDS Educ Prev. 2001;13(3):239-51. [pmid: 11459360].
Cesar C, Shepherd BE, Krolewiecki AJ, Fink VI, Schechter M, Tuboi SH, et al. Rates and reasons for early change of first HAART in HIV-1-infected patients in 7 sites throughout the Caribbean and Latin America. PLoS One. 2010;5(6):e10490. [pmid: 20531956].
Chandwani S, Abramowitz S, Koenig LJ, Barnes W, D'Angelo L. A multimodal behavioral intervention to impact adherence and risk behavior among perinatally and behaviorally HIV-infected youth: description, delivery, and receptivity of adolescent impact. AIDS Educ Prev. 2011;23(3):222-35. [pmid: 21696241].
Chan-Tack KM, Truffa MM, Struble KA, Birnkrant DB. Atazanavir-associated nephrolithiasis: cases from the US Food and Drug Administration's adverse event reporting system. AIDS. 2007;21(9):1215-8. [pmid: 17502736].
Cheng CY, Chen MY, Hsieh SM, Sheng WH, Sun HY, Lo YC, et al. Risk of pneumocystosis after early discontinuation of prophylaxis among HIV-infected patients receiving highly active antiretroviral therapy. BMC Infect Dis. 2010;10:126. [pmid: 20492660].
Cherry CL, Skolasky RL, Lal L, Creighton J, Hauer P, Raman SP, et al. Antiretroviral use and other risks for HIV-associated neuropathies in an international cohort. Neurology. 2006;66(6):867-73. [pmid: 16567704].
Chowers M, Gottesman BS, Leibovici L, Schapiro JM, Paul M. Nucleoside reverse transcriptase inhibitors in combination therapy for HIV patients: systematic review and meta-analysis. Eur J Clin Microbiol Infect Dis. 2010;29(7):779-86. [pmid: 20449621].
Chu H, Gange SJ, Li X, Hoover DR, Liu C, Chmiel JS, et al. The effect of HAART on HIV RNA trajectory among treatment-naive men and women: a segmental Bernoulli/lognormal random effects model with left censoring. Epidemiology. 2010;21(Suppl 4):S25-34. [pmid: 20386106].
Clark A, Mayben JK, Hartman C, Kallen MA, Giordano TP. Conspiracy beliefs about HIV infection are common but not associated with delayed diagnosis or adherence to care. AIDS Patient Care STDs. 2008;22(9):753-9. [pmid: 18754706].
Collaboration of HIV Cohorts. Nucleoside analogue use before and during highly active antiretroviral therapy and virus load rebound. J Infect Dis. 2004;190(4):675-87. [pmid: 15272393].
Collaboration of Observational HIV Epidemiological Research Europe (COHERE) Study Group, Sabin CA, Smith CJ, d'Arminio Monforte A, Battegay M, Gabiano C, et al. Response to combination antiretroviral therapy: variation by age. AIDS. 2008;22(12):1463-73. [pmid: 18614870].
Collazos J, Asensi V, Carton JA, Grupo Espanol Para El Estudio Multifactorial De La Adherencia (GEEMA). Factors associated with poor immunologic responses despite viral suppression in markedly immunosuppressed patients. AIDS Patient Care STDs. 2007;21(6):378-84. [pmid: 17594246].
Copenhaver MM, Lee IC, Margolin A, Bruce RD, Altice FL. Testing an optimized community-based human immunodeficiency virus (HIV) risk reduction and antiretroviral adherence intervention for HIV-infected injection drug users. Subst Abus. 2011;32(1):16-26. [pmid: 21302180].
Corral I, Quereda C, Moreno A, Perez-Elias MJ, Dronda F, Casado JL, et al. Cerebrovascular ischemic events in HIV-1-infected patients receiving highly active antiretroviral therapy: incidence and risk factors. Cerebrovasc Dis. 2009;27(6):559-63. [pmid: 19390181].
Crawford KW, Spritzler J, Kalayjian RC, Parsons T, Landay A, Pollard R, et al. Age-related changes in plasma concentrations of the HIV protease inhibitor lopinavir. AIDS Res Hum Retroviruses. 2010;26(6):635-43. [pmid: 20560793].
Crum-Cianflone N, Hullsiek KH, Satter E, Marconi V, Weintrob A, Ganesan A, et al. Cutaneous malignancies among HIV-infected persons. Arch Intern Med. 2009;169(12):1130-8. [pmid: 19546414].
Crum-Cianflone NF, Hullsiek KH, Marconi V, Weintrob A, Ganesan A, Barthel RV, et al. The impact of nelfinavir exposure on cancer development among a large cohort of HIV-infected patients. J Acquir Immune Defic Syndr. 2009;51(3):305-9. [pmid: 19412116].
Crystal HA, Weedon J, Holman S, Manly J, Valcour V, Cohen M, et al. Associations of cardiovascular variables and HAART with cognition in middle-aged HIV-infected and uninfected women. J Neurovirol. 2011;17(5):469-76. [pmid: 22006469].
Daher EF, Cezar LC, Silva GB Jr, Lima RS, Damasceno LS, Lopes EB, et al. Metabolic acidosis in AIDS patients. Arch Med Res. 2009;40(2):109-13. [pmid: 19237020].
d'Almeida KW, Kierzek G, de Truchis P, Le Vu S, Pateron D, Renaud B, et al. Modest public health impact of nontargeted human immunodeficiency virus screening in 29 emergency departments. Arch Intern Med. 2012;172(1):12-20. [pmid: 22025095].
Danta M, Brown D, Bhagani S, Pybus OG, Sabin CA, Nelson M, et al. Recent epidemic of acute hepatitis C virus in HIV-positive men who have sex with men linked to high-risk sexual behaviours. AIDS. 2007;21(8):983-91. [pmid: 17457092].
d'arminio Monforte A, Cozzi-Lepri A, Phillips A, De Luca A, Murri R, Mussini C, et al. Interruption of highly active antiretroviral therapy in HIV clinical practice: results from the Italian Cohort of Antiretroviral-Naive Patients. J Acquir Immune Defic Syndr. 2005;38(4):407-16. [pmid: 15764957].
Das-Douglas M, Zetola NM, Klausner JD, Colfax GN. Written informed consent and HIV testing rates: the San Francisco experience. Am J Public Health. 2008;98(9):1544-5. [pmid: 18633069].
Dave SS, Stephenson J, Mercey DE, Panahmand N, Jungmann E. Sexual behaviour, condom use, and disclosure of HIV status in HIV infected heterosexual individuals attending an inner London HIV clinic. Sex Transm Infect. 2006;82(2):117-9. [pmid: 16581734].
Davey RT, Pertel PE, Benson A, Cassell DJ, Gazzard BG, Holodniy M, et al. Safety, tolerability, pharmacokinetics, and efficacy of an interleukin-2 agonist among HIV-infected patients receiving highly active antiretroviral therapy. J Interferon Cytokine Res. 2008;28(2):89-100. [pmid: 18279104].
de Boer-van der Kolk IM, Sprangers MA, Prins JM, Smit C, de Wolf F, Nieuwkerk PT. Health-related quality of life and survival among HIV-infected patients receiving highly active antiretroviral therapy: a study of patients in the AIDS Therapy Evaluation in the Netherlands (ATHENA) Cohort. Clin Infect Dis. 2010;50(2):255-63. [pmid: 20014949].
De Luca A, Weidler J, Di Giambenedetto S, Coakley E, Cingolani A, Bates M, et al. Association of HIV-1 replication capacity with treatment outcomes in patients with virologic treatment failure. J Acquir Immune Defic Syndr. 2007;45(4):411-7. [pmid: 17554216].
de Souza Goncalves L, Souto R, Colombo AP. Detection of Helicobacter pylori, Enterococcus faecalis, and Pseudomonas aeruginosa in the subgingival biofilm of HIV-infected subjects undergoing HAART with chronic periodontitis. Eur J Clin Microbiol Infect Dis. 2009;28(11):1335-42. [pmid: 19639349].
Debattista J, Bryson G, Roudenko N, Dwyer J, Kelly M, Hogan P, et al. Pilot of non-invasive (oral fluid) testing for HIV within a clinical setting. Sex Health. 2007;4(2):105-9. [pmid: 17524288].
Degano B, Yaici A, Le Pavec J, Savale L, Jais X, Camara B, et al. Long-term effects of bosentan in patients with HIV-associated pulmonary arterial hypertension. Eur Respir J. 2009;33(1):92-8. [pmid: 18799506].
DeJesus E, McCarty D, Farthing CF, Shortino DD, Grinsztejn B, Thomas DA, et al. Once-daily versus twice-daily lamivudine, in combination with zidovudine and efavirenz, for the treatment of antiretroviral-naive adults with HIV infection: a randomized equivalence trial. Clin Infect Dis. 2004;39(3):411-8. [pmid: 15307010].
Delaugerre C, Buyck JF, Peytavin G, Viard JP, Chaix ML, Zucman D, et al. Factors predictive of successful darunavir/ritonavir-based therapy in highly antiretroviral-experienced HIV-1-infected patients (the DARWEST study). J Clin Virol. 2010;47(3):248-52. [pmid: 20097121].
Delaugerre C, Peytavin G, Dominguez S, Marcelin AG, Duvivier C, Gourlain K, et al. Virological and pharmacological factors associated with virological response to salvage therapy after an 8-week of treatment interruption in a context of very advanced HIV disease (GigHAART ANRS 097). J Med Virol. 2005;77(3):345-50. [pmid: 16173015].
Des Jarlais DC, Friedmann P, Hagan H, Friedman SR. The protective effect of AIDS-related behavioral change among injection drug users: a cross-national study. Am J Public Health. 1996;86(12):1780-5. [pmid: 9003137].
Desquilbet L, Margolick JB, Fried LP, Phair JP, Jamieson BD, Holloway M, et al. Relationship between a frailty-related phenotype and progressive deterioration of the immune system in HIV-infected men. J Acquir Immune Defic Syndr. 2009;50(3):299-306. [pmid: 19194312].
Di Giambenedetto S, Torti C, Prosperi M, Manca N, Lapadula G, Paraninfo G, et al. Effectiveness of antiretroviral regimens containing abacavir with tenofovir in treatment-experienced patients: predictors of virological response and drug resistance evolution in a multi-cohort study. Infection. 2009;37(5):438-44. [pmid: 19669091].
Di Giambenedetto S, Zazzi M, Corsi P, Gonnelli A, Di Pietro M, Giacometti A, et al. Evolution and predictors of HIV type-1 drug resistance in patients failing combination antiretroviral therapy in Italy. Antivir Ther. 2009;14(3):359-69. [pmid: 19474470].
Di Rocco A, Werner P, Bottiglieri T, Godbold J, Liu M, Tagliati M, et al. Treatment of AIDS-associated myelopathy with L-methionine: a placebo-controlled study. Neurology. 2004;63(7):1270-5. [pmid: 15477550].
Diallo DD, Moore TW, Ngalame PM, White LD, Herbst JH, Painter TM. Efficacy of a single-session HIV prevention intervention for black women: a group randomized controlled trial. AIDS Behav. 2010;14(3):518-29. [pmid: 20135214].
DiClemente RJ, Wingood GM, Del Rio C, Crosby RA. Prevention interventions for HIV positive individuals. Sex Transm Infect. 2002;78(6):393-5. [pmid: 12473796].
Dietz E, Clum GA, Chung SE, Leonard L, Murphy DA, Perez LV, et al. Adherence to scheduled appointments among HIV-infected female youth in five U.S. cities. J Adolesc Health. 2010;46(3):278-83. [pmid: 20159506].
Dilley JW, Woods WJ, Loeb L, Nelson K, Sheon N, Mullan J, et al. Brief cognitive counseling with HIV testing to reduce sexual risk among men who have sex with men: results from a randomized controlled trial using paraprofessional counselors. J Acquir Immune Defic Syndr. 2007;44(5):569-77. [pmid: 17310937].
Dilley JW, Woods WJ, Sabatino J, Lihatsh T, Adler B, Casey S, et al. Changing sexual behavior among gay male repeat testers for HIV: a randomized, controlled trial of a single-session intervention. J Acquir Immune Defic Syndr. 2002;30(2):177-86. [pmid: 12045680].
DiScenza S, Nies M, Jordan C. Effectiveness of counseling in the health promotion of HIV-positive clients in the community. Public Health Nurs. 1996;13(3):209-16. [pmid: 8677237].
Dodds JP, Mercey DE, Parry JV, Johnson AM. Increasing risk behaviour and high levels of undiagnosed HIV infection in a community sample of homosexual men. Sex Transm Infect. 2004;80(3):236-40. [pmid: 15170012].
D'Offizi G, Gioia C, Corpolongo A, Martini F, Paganelli R, Volpi I, et al. An IL-15 dependent CD8 T cell response to selected HIV epitopes is related to viral control in early-treated HIV-infected subjects. Int J Immunopathol Pharmacol. 2007;20(3):473-85. [pmid: 17880761].
Dolezal C, Meyer-Bahlburg HF, Liu X, Ehrhardt AA, Exner TM, Rabkin JG, et al. Longitudinal changes in sexual risk behavior among HIV+ and HIV- male injecting drug users. Am J Drug Alcohol Abuse. 1999;25(2):281-303. [pmid: 10395161].
Domingo P, Cabeza MC, Pruvost A, Salazar J, Gutierrez Mdel M, Mateo MG, et al. Relationship between HIV/highly active antiretroviral therapy (HAART)-associated lipodystrophy syndrome and stavudine-triphosphate intracellular levels in patients with stavudine-based antiretroviral regimens. Clin Infect Dis. 2010;50(7):1033-40. [pmid: 20192724].
Domingo P, Suarez-Lozano I, Torres F, Pomar V, Ribera E, Galindo MJ, et al. Bacterial meningitis in HIV-1-infected patients in the era of highly active antiretroviral therapy. J Acquir Immune Defic Syndr. 2009;51(5):582-7. [pmid: 19512939].
Donnell-Fink L, Reichmann WM, Arbelaez C, Case AL, Katz JN, Losina E, et al. Patient satisfaction with rapid HIV testing in the emergency department. Ann Emerg Med. 2011;58(Suppl 1):S49-52. [pmid: 21684408].
Dorrucci M, Phillips AN, Longo B, Rezza G, Italian Seroconversion Study. Changes over time in post-seroconversion CD4 cell counts in the Italian HIV-Seroconversion Study: 1985-2002. AIDS. 2005;19(3):331-5. [pmid: 15718844].
Drylewicz J, Matheron S, Lazaro E, Damond F, Bonnet F, Simon F, et al. Comparison of viro-immunological marker changes between HIV-1 and HIV-2-infected patients in France. AIDS. 2008;22(4):457-68. [pmid: 18301058].
D'Souza G, Wiley DJ, Li X, Chmiel JS, Margolick JB, Cranston RD, et al. Incidence and epidemiology of anal cancer in the multicenter AIDS cohort study. J Acquir Immune Defic Syndr. 48(4):491-9. [pmid: 18614927].
Dukers NH, Stolte IG, Albrecht N, Coutinho RA, de Wit JB. The impact of experiencing lipodystrophy on the sexual behaviour and well-being among HIV-infected homosexual men. AIDS. 2001;15(6):812-3. [pmid: 11371704].
Dunic I, Vesic S, Jevtovic DJ. Oral candidiasis and seborrheic dermatitis in HIV-infected patients on highly active antiretroviral therapy. HIV Med. 2004;5(1):50-4. [pmid: 14731170].
Duval X, Mentre F, Rey E, Auleley S, Peytavin G, Biour M, et al. Benefit of therapeutic drug monitoring of protease inhibitors in HIV-infected patients depends on PI used in HAART regimen—ANRS 111 trial. Fundam Clin Pharmacol. 2009;23(4):491-500. [pmid: 19709326].
Duvivier C, Kolta S, Assoumou L, Ghosn J, Rozenberg S, Murphy RL, et al. Greater decrease in bone mineral density with protease inhibitor regimens compared with nonnucleoside reverse transcriptase inhibitor regimens in HIV-1 infected naive patients. AIDS. 2009;23(7):817-24. [pmid: 19363330].
Ehrenkranz PD, Ahn CJ, Metlay JP, Camargo CA Jr, Holmes WC, Rothman R. Availability of rapid human immunodeficiency virus testing in academic emergency departments. Acad Emerg Med. 2008;15(2):144-50. [pmid: 18275444].
Einsiedel L, Cherry CL, Sheeran FL, Friedhuber A, Wesselingh SL, Pepe S. Mitochondrial dysfunction in CD4+ lymphocytes from stavudine-treated HIV patients. Mitochondrion. 2010;10(5):534-9. [pmid: 20685321].
Elford J. HIV treatment optimism and high-risk sexual behaviour among gay men: the attributable population risk. AIDS. 2004;18(16):2216-7. [pmid: 15577662].
Ellis RJ, Marquie-Beck J, Delaney P, Alexander T, Clifford DB, McArthur JC, et al. Human immunodeficiency virus protease inhibitors and risk for peripheral neuropathy. Ann Neurol. 2008;64(5):566-72. [pmid: 19067367].
El-Sadr WM, Mayer KH, Maslankowski L, Hoesley C, Justman J, Gai F, et al. Safety and acceptability of cellulose sulfate as a vaginal microbicide in HIV-infected women. AIDS. 2006;20(8):1109-16. [pmid: 16691061].
Ena J, Leach A, Nguyen P. Switching from suppressive protease inhibitor-based regimens to nevirapine-based regimens: a meta-analysis of randomized controlled trials. HIV Med. 2008;9(9):747-56. [pmid: 18651856].
Eron JJ, Feinberg J, Kessler HA, Horowitz HW, Witt MD, Carpio FF, et al. Once-daily versus twice-daily lopinavir/ritonavir in antiretroviral-naive HIV-positive patients: a 48-week randomized clinical trial. J Infect Dis. 2004;189(2):265-72. [pmid: 14722892].
European Partner Notification Study Group. Recently diagnosed sexually HIV-infected patients: seroconversion interval, partner notification period and a high yield of HIV diagnoses among partners. QJM. 2001;94(7):379-90. [pmid: 11435634].
Evans WJ, Kotler DP, Staszewski S, Griffin GE, Isgaard J, Gertner JM, et al. Effect of recombinant human growth hormone on exercise capacity in patients with HIV-associated wasting on HAART. AIDS Read. 2005;15(6):301-3. [pmid: 15962453].
Fabbiani M, Di Giambenedetto S, Ragazzoni E, Colafigli M, Prosperi M, Cauda R, et al. Mid-dosing interval concentration of atazanavir and virological outcome in patients treated for HIV-1 infection. HIV Med. 2010;11(5):326-33. [pmid: 20070407].
Falasca K, Ucciferri C, Mancino P, Di Iorio A, Vignale F, Pizzigallo E, et al. Cystatin C, adipokines and cardiovascular risk in HIV infected patients. Curr HIV Res. 2010;8(5):405-10. [pmid: 20426756].
Fang CT, Chang YY, Hsu HM, Twu SJ, Chen KT, Lin CC, et al. Life expectancy of patients with newly-diagnosed HIV infection in the era of highly active antiretroviral therapy. QJM. 2007;100(2):97-105. [pmid: 17277317].
Farquhar C, Kiarie JN, Richardson BA, Kabura MN, John FN, Nduati RW, et al. Antenatal couple counseling increases uptake of interventions to prevent HIV-1 transmission. J Acquir Immune Defic Syndr. 2004;37(5):1620-6. [pmid: 15577420].
Fielden SJ, Rusch ML, Yip B, Wood E, Shannon K, Levy AR, et al. Nonadherence increases the risk of hospitalization among HIV-infected antiretroviral naive patients started on HAART. J Int Assoc Physicians AIDS Care. 2008;7(5):238-44. [pmid: 18812590].
Fischl MA, Collier AC, Mukherjee AL, Feinberg JE, Demeter LM, Tebas P, et al. Randomized open-label trial of two simplified, class-sparing regimens following a first suppressive three or four-drug regimen. AIDS. 2007;21(3):325-33. [pmid: 17255739].
Fisher JD, Fisher WA, Cornman DH, Amico RK, Bryan A, Friedland GH. Clinician-delivered intervention during routine clinical care reduces unprotected sexual behavior among HIV-infected patients. J Acquir Immune Defic Syndr. 2006;41(1):44-52. [pmid: 16340472].
Fitch KV, Anderson EJ, Hubbard JL, Carpenter SJ, Waddell WR, Caliendo AM, et al. Effects of a lifestyle modification program in HIV-infected patients with the metabolic syndrome. AIDS. 2006;20(14):1843-50. [pmid: 16954725].
Flexner C, Tierney C, Gross R, Andrade A, Lalama C, Eshleman SH, et al. Comparison of once-daily versus twice-daily combination antiretroviral therapy in treatment-naive patients: results of AIDS Clinical Trials Group (ACTG) A5073, a 48-week randomized controlled trial. Clin Infect Dis. 2010;50(7):1041-52. [pmid: 20192725].
Florence E, De Wit S, Castagna A, Ribera E, Hill A, Vanaken H, et al. HIV RNA suppression rates after 24 weeks of treatment with etravirine, darunavir/ritonavir and raltegravir in the etravirine early access programme. Int J STD AIDS. 2010;21(3):224-5. [pmid: 20071441].
Florence E, Garcia F, Plana M, Fumero E, Castro P, Lopez A, et al. Long-term clinical follow-up, without antiretroviral therapy, of patients with chronic HIV-1 infection with good virological response to structured treatment interruption. Clin Infect Dis. 2004;39(4):569-74. [pmid: 15356824].
Floridia M, Bucciardini R, Fragola V, Galluzzo CM, Giannini G, Pirillo MF, et al. Risk factors and occurrence of rash in HIV-positive patients not receiving nonnucleoside reverse transcriptase inhibitor: data from a randomized study evaluating use of protease inhibitors in nucleoside-experienced patients with very low CD4 levels (<50 cells/μL). HIV Med. 2004;5(1):1-10. [pmid: 14731162].
Fogarty LA, Heilig CM, Armstrong K, Cabral R, Galavotti C, Gielen AC, et al. Long-term effectiveness of a peer-based intervention to promote condom and contraceptive use among HIV-positive and at-risk women. Public Health Rep. 2001;116(Suppl 1):103-19. [pmid: 11889279].
Foglia G, Royster GDt, Wasunna KM, Kibaya R, Malia JA, Calero EK, et al. Use of rapid and conventional testing technologies for human immunodeficiency virus type 1 serologic screening in a rural Kenyan reference laboratory. J Clin Microbiol. 2004;42(8):3850-2. [pmid: 15297547].
Foley K, Duran B, Morris P, Lucero J, Jiang Y, Baxter B, et al. Using motivational interviewing to promote HIV testing at an American Indian substance abuse treatment facility. J Psychoactive Drugs. 2005;37(3):321-9. [pmid: 16295016].
Foli A, Maserati R, Barasolo G, Castelli F, Tomasoni L, Migliorino M, et al. Strategies to decrease viral load rebound, and prevent loss of CD4 and onset of resistance during structured treatment interruptions. Antivir Ther. 2004;9(1):123-32. [pmid: 15040544].
Ford N, Darder M, Spelman T, Maclean E, Mills E, Boulle A. Early adherence to antiretroviral medication as a predictor of long-term HIV virological suppression: five-year follow up of an observational cohort. PLoS One. 2010;5(5):e10460. [pmid: 20485480].
Fox Z, Phillips A, Cohen C, Neuhaus J, Baxter J, Emery S, et al. Viral resuppression and detection of drug resistance following interruption of a suppressive non-nucleoside reverse transcriptase inhibitor-based regimen. AIDS. 2008;22(17):2279-89. [pmid: 18981767].
Franceschi S, Lise M, Clifford GM, Rickenbach M, Levi F, Maspoli M, et al. Changing patterns of cancer incidence in the early- and late-HAART periods: the Swiss HIV Cohort Study. Br J Cancer. 2010;103(3):416-22. [pmid: 20588274].
Francis SA, Lam WK, Cance JD, Hogan VK. What's the 411? Assessing the feasibility of providing African American adolescents with HIV/AIDS prevention education in a faith-based setting. J Relig Health. 2009;48(2):164-77. [pmid: 19421867].
Francisci D, Giannini S, Baldelli F, Leone M, Belfiori B, Guglielmini G, et al. HIV type 1 infection, and not short-term HAART, induces endothelial dysfunction. AIDS. 2009;23(5):589-96. [pmid: 19177019].
Frost DM, Stirratt MJ, Ouellette SC. Understanding why gay men seek HIV-seroconcordant partners: intimacy and risk reduction motivations. Cult Health Sex. 2008;10(5):513-27. [pmid: 18568873].
Fumaz CR, Munoz-Moreno JA, Molto J, Negredo E, Ferrer MJ, Sirera G, et al. Long-term neuropsychiatric disorders on efavirenz-based approaches: quality of life, psychologic issues, and adherence. J Acquir Immune Defic Syndr. 2005;38(5):560-5. [pmid: 15793366].
Gagnon H, Godin G, Alary M, Bruneau J, Otis J. A randomized trial to evaluate the efficacy of a computer-tailored intervention to promote safer injection practices among drug users. AIDS Behav. 2010;14(3):538-48. [pmid: 20033276].
Gaitan-Cepeda LA, Dominguez-Sanchez A, Pavia-Ruz N, Munoz-Hernandez R, Verdugo-Diaz R, Valles-Medina AM, et al. Oral lesions in HIV+/AIDS adolescents perinatally infected undergoing HAART. Med Oral Patol Oral Cir Bucal. 2010;15(4):e545-50. [pmid: 20173726].
Gallant JE, DeJesus E, Arribas JR, Pozniak AL, Gazzard B, Campo RE, et al. Tenofovir DF, emtricitabine, and efavirenz vs. zidovudine, lamivudine, and efavirenz for HIV. N Engl J Med. 2006;354(3):251-60. [pmid: 16421366].
Gallant JE, Moore RD. Renal function with use of a tenofovir-containing initial antiretroviral regimen. AIDS. 2009;23(15):1971-5. [pmid: 19696652].
Gallant JE, Winston JA, DeJesus E, Pozniak AL, Chen SS, Cheng AK, et al. The 3-year renal safety of a tenofovir disoproxil fumarate vs. a thymidine analogue-containing regimen in antiretroviral-naive patients. AIDS. 2008;22(16):2155-63. [pmid: 18832879].
Garcia F, Plana M, Arnedo M, Brunet M, Castro P, Gil C, et al. Effect of mycophenolate mofetil on immune response and plasma and lymphatic tissue viral load during and after interruption of highly active antiretroviral therapy for patients with chronic HIV infection: a randomized pilot study. J Acquir Immune Defic Syndr. 2004;36(3):823-30. [pmid: 15213566].
Gardner EM, Sharma S, Peng G, Hullsiek KH, Burman WJ, Macarthur RD, et al. Differential adherence to combination antiretroviral therapy is associated with virological failure with resistance. AIDS. 2008;22(1):75-82. [pmid: 18090394].
Gardner LI, Marks G, O'Daniels CM, Wilson TE, Golin C, Wright J, et al. Implementation and evaluation of a clinic-based behavioral intervention: positive steps for patients with HIV. AIDS Patient Care STDs. 2008;22(8):627-35. [pmid: 18627280].
Garrabou G, Moren C, Gallego-Escuredo JM, Milinkovic A, Villarroya F, Negredo E, et al. Genetic and functional mitochondrial assessment of HIV-infected patients developing HAART-related hyperlactatemia. J Acquir Immune Defic Syndr. 2009;52(4):443-51. [pmid: 19779356].
Gasiorowicz M, Llanas MR, DiFranceisco W, Benotsch EG, Brondino MJ, Catz SL, et al. Reductions in transmission risk behaviors in HIV-positive clients receiving prevention case management services: findings from a community demonstration project. AIDS Educ Prev. 2005;17(1 Suppl A):40-52. [pmid: 15843116].
Gaur AH, Belzer M, Britto P, Garvie PA, Hu C, Graham B, et al. Directly observed therapy (DOT) for nonadherent HIV-infected youth: lessons learned, challenges ahead. AIDS Res Hum Retroviruses. 2010;26(9):947-53. [pmid: 20707731].
Ghosn J, Flandre P, Cohen-Codar I, Girard PM, Chaix ML, Raffi F, et al. Long-term (96-week) follow-up of antiretroviral-naive HIV-infected patients treated with first-line lopinavir/ritonavir monotherapy in the MONARK trial. HIV Med. 2010;11(2):137-42. [pmid: 19682100].
Gilbert P, Ciccarone D, Gansky SA, Bangsberg DR, Clanon K, McPhee SJ, et al. Interactive “Video Doctor” counseling reduces drug and sexual risk behaviors among HIV-positive patients in diverse outpatient settings. PLoS One. 2008;3(4):e1988. [pmid: 18431475].
Giuntini R, Martinelli C, Ricci E, Vichi F, Gianelli E, Madeddu G, et al. Efficacy and safety of boosted and unboosted atazanavir-containing antiretroviral regimens in real life: results from a multicentre cohort study. HIV Med. 2010;11(1):40-5. [pmid: 19686438].
Golin CE, Davis RA, Przybyla SM, Fowler B, Parker S, Earp JA, et al. SafeTalk, a multicomponent, motivational interviewing-based, safer sex counseling program for people living with HIV/AIDS: a qualitative assessment of patients' views. AIDS Patient Care STDs. 2010;24(4):237-45. [pmid: 20377435].
Golub ET, Benning L, Sharma A, Gandhi M, Cohen MH, Young M, et al. Patterns, predictors, and consequences of initial regimen type among HIV-infected women receiving highly active antiretroviral therapy. Clin Infect Dis. 2008;46(2):305-12. [pmid: 18171267].
Greenbaum AH, Wilson LE, Keruly JC, Moore RD, Gebo KA. Effect of age and HAART regimen on clinical response in an urban cohort of HIV-infected individuals. AIDS. 2008;22(17):2331-9. [pmid: 18981772].
Griffith DM, Pichon LC, Campbell B, Allen JO. YOUR Blessed Health: a faith-based CBPR approach to addressing HIV/AIDS among African Americans. AIDS Educ Prev. 2010;22(3):203-17. [pmid: 20528129].
Grigoryan A, Hall HI, Durant T, Wei X. Late HIV diagnosis and determinants of progression to AIDS or death after HIV diagnosis among injection drug users, 33 US states, 1996–2004. PLoS One. 2009;4(2):e4445. [pmid: 19214229].
DART Virology Group and Trial Team. Virological response to a triple nucleoside/nucleotide analogue regimen over 48 weeks in HIV-1-infected adults in Africa. AIDS. 2006;20(10):1391-9. [pmid: 16791013].
Grusky O, Roberts KJ, Swanson AN. Failure to return for HIV test results: a pilot study of three community testing sites. J Int Assoc Physicians AIDS Care. 2007;6(1):47-55. [pmid: 17329504].
Gulick RM, Ribaudo HJ, Shikuma CM, Lalama C, Schackman BR, Meyer WA, et al. Three- vs four-drug antiretroviral regimens for the initial treatment of HIV-1 infection: a randomized controlled trial. JAMA. 2006;296(7):769-81. [pmid: 16905783].
Gupta RK, Hill A, Sawyer AW, Cozzi-Lepri A, von Wyl V, Yerly S, et al. Virological monitoring and resistance to first-line highly active antiretroviral therapy in adults infected with HIV-1 treated under WHO guidelines: a systematic review and meta-analysis. Lancet Infect Dis. 2009;9(7):409-17. [pmid: 19555900].
Gupta SK, Parker RA, Robbins GK, Dube MP. The effects of highly active antiretroviral therapy on albuminuria in HIV-infected persons: results from a randomized trial. Nephrol Dial Transplant. 2005;20(10):2237-42. [pmid: 16105869].
Gutierrez-Valencia A, Viciana P, Palacios R, Ruiz-Valderas R, Lozano F, Terron A, et al. Stepped-dose versus full-dose efavirenz for HIV infection and neuropsychiatric adverse events: a randomized trial. Ann Intern Med. 2009;151(3):149-56. [pmid: 19581631].
Guy RJ, Prybylski D, Fairley CK, Hellard ME, Kaldor JM. Can data from HIV voluntary counselling and testing be used to assess the impact of public health interventions? A literature review. Int J STD AIDS. 2009;20(6):378-83. [pmid: 19451320].
Gwadz MV, Cleland CM, Quiles R, Nish D, Welch J, Michaels LS, et al. CDC HIV testing guidelines and the rapid and conventional testing practices of homeless youth. AIDS Educ Prev. 2010;22(4):312-27. [pmid: 20707692].
Halkitis PN, Zade DD, Shrem M, Marmor M. Beliefs about HIV non-infection and risky sexual behavior among MSM. AIDS Educ Prev. 2004;16(5):448-58. [pmid: 15491956].
Hallett TB, Gregson S, Lewis JJ, Lopman BA, Garnett GP. Behaviour change in generalised HIV epidemics: impact of reducing cross-generational sex and delaying age at sexual debut. Sex Transm Infect. 2007;83(Suppl 1):i50-4. [pmid: 17314125].
Harding R, Bensley J, Corrigan N, Franks L, Stratman J, Waller Z, et al. Outcomes and lessons from a pilot RCT of a community-based HIV prevention multi-session group intervention for gay men. AIDS Care. 2004;16(5):581-5. [pmid: 15223527].
Harris SK, Samples CL, Keenan PM, Fox DJ, Melchiono MW, Woods ER, et al. Outreach, mental health, and case management services: can they help to retain HIV-positive and at-risk youth and young adults in care?. Maternal Child Health J. 2003;7(4):205-18. [pmid: 14682498].
Healthy Living Project Team. Effects of a behavioral intervention to reduce risk of transmission among people living with HIV: the Healthy Living Project randomized controlled study. J Acquir Immune Defic Syndr. 2007;44(2):213-21. [pmid: 17146375].
Heijman T, Geskus RB, Davidovich U, Coutinho RA, Prins M, Stolte IG. Less decrease in risk behaviour from pre-HIV to post-HIV seroconversion among MSM in the combination antiretroviral therapy era compared with the pre-combination antiretroviral therapy era. AIDS. 2012;26(4):489-95. [pmid: 22156971].
Hellinger J, Cohen C, Morris A, Sheble-Hall S, Gordon D, Foy C, et al. Pilot study of saquinavir and lopinavir/ritonavir twice daily in protease inhibitor-naive HIV-positive patients. HIV Clinical Trials. 2005;6(2):107-17. [pmid: 15983895].
Henry K, Kitch D, Dube M, Zackin R, Parker RA, Sprecher D, et al. C-reactive protein levels over time and cardiovascular risk in HIV-infected individuals suppressed on an indinavir-based regimen: AIDS Clinical Trials Group 5056s. AIDS. 2004;18(18):2434-7. [pmid: 15622323].
Herbst JH, Sherba RT, Crepaz N, Deluca JB, Zohrabyan L, Stall RD, et al. A meta-analytic review of HIV behavioral interventions for reducing sexual risk behavior of men who have sex with men. J Acquir Immune Defic Syndr. 2005;39(2):228-41. [pmid: 15905741].
Hicks C, King MS, Gulick RM, White AC, Eron JJ, Kessler HA, et al. Long-term safety and durable antiretroviral activity of lopinavir/ritonavir in treatment-naive patients: 4 year follow-up study. AIDS. 2004;18(5):775-9. [pmid: 15075512].
Hightow-Weidman LB, Jones K, Wohl AR, Futterman D, Outlaw A, Phillips G 2nd, et al. Early linkage and retention in care: findings from the outreach, linkage, and retention in care initiative among young men of color who have sex with men. AIDS Patient Care STDs. 2011;25(Suppl 1):S31-8. [pmid: 21711141].
Hoffmann CJ, Fielding KL, Johnston V, Charalambous S, Innes C, Moore RD, et al. Changing predictors of mortality over time from cART start: implications for care. J Acquir Immune Defic Syndr. 2011;58(3):269-76. [pmid: 21876447].
Howe CJ, Cole SR, Napravnik S, Eron JJ. Enrollment, retention, and visit attendance in the University of North Carolina Center for AIDS Research HIV clinical cohort, 2001-2007. AIDS Res Hum Retroviruses. 2010;26(8):875-81. [pmid: 20672995].
Huebner DM, Binson D, Dilworth SE, Neilands TB, Grinstead O, Woods WJ. Rapid vs. standard HIV testing in bathhouses: what is gained and lost?. AIDS Behav. 2010;14(3):688-96. [pmid: 18726682].
Huebner DM, Binson D, Woods WJ, Dilworth SE, Neilands TB, Grinstead O. Bathhouse-based voluntary counseling and testing is feasible and shows preliminary evidence of effectiveness. J Acquir Immune Defic Syndr. 2006;43(2):239-46. [pmid: 16951645].
Jauffret-Roustide M, Emmanuelli J, Quaglia M, Barin F, Arduin P, Laporte A, et al. Impact of a harm-reduction policy on HIV and hepatitis C virus transmission among drug users: recent French data—the ANRS-Coquelicot Study. Subst Use Misuse. 2006;41(10-12):1603-21. [pmid: 17002994].
Jayaweera DT, Kolber MA, Brill M, Tanner T, Campo R, Rodriguez A, et al. Effectiveness and tolerability of a once-daily amprenavir/ritonavir-containing highly active antiretroviral therapy regimen in antiretroviral-naive patients at risk for nonadherence: 48-week results after 24 weeks of directly observed therapy. HIV Med. 2004;5(5):364-70. [pmid: 15369512].
Jevtovic D, Vanovac V, Veselinovic M, Salemovic D, Ranin J, Stefanova E. The incidence of and risk factors for HIV-associated cognitive-motor complex among patients on HAART. Biomed Pharmacother. 2009;63(8):561-5. [pmid: 19026516].
Jevtovic DJ, Dragovic G, Salemovic D, Ranin J, Djurkovic-Djakovic O. The metabolic syndrome, an epidemic among HIV-infected patients on HAART. Biomed Pharmacother. 2009;63(5):337-42. [pmid: 18996676].
Jin F, Prestage GP, Ellard J, Kippax SC, Kaldor JM, Grulich AE. How homosexual men believe they became infected with HIV: the role of risk-reduction behaviors. J Acquir Immune Defic Syndr. 2007;46(2):245-7. [pmid: 17721400].
Johnson MO, Charlebois E, Morin SF, Remien RH, Chesney MA, National Institute of Mental Health Healthy Living Project Team. Effects of a behavioral intervention on antiretroviral medication adherence among people living with HIV: the Healthy Living Project randomized controlled study. J Acquir Immune Defic Syndr. 2007;46(5):574-80. [pmid: 18193499].
Johnson MO, Dilworth SE, Neilands TB, Chesney MA, Rotheram-Borus MJ, Remien RH, et al. Predictors of attrition among high risk HIV-infected participants enrolled in a multi-site prevention trial. AIDS Behav. 2008;12(6):974-7. [pmid: 18202908].
Johnston L, O'Bra H, Chopra M, Mathews C, Townsend L, Sabin K, et al. The associations of voluntary counseling and testing acceptance and the perceived likelihood of being HIV-infected among men with multiple sex partners in a South African township. AIDS Behav. 2010;14(4):922-31. [pmid: 18270809].
Kalayjian RC, Franceschini N, Gupta SK, Szczech LA, Mupere E, Bosch RJ, et al. Suppression of HIV-1 replication by antiretroviral therapy improves renal function in persons with low CD4 cell counts and chronic kidney disease. AIDS. 2008;22(4):481-7. [pmid: 18301060].
Kalichman SC, Cain D. Repeat HIV testing and HIV transmission risk behaviors among sexually transmitted infection clinic patients. J Clin Psychol Med Settings. 2008;15(2):127-33. [pmid: 19104976].
Kalichman SC, Cherry C, Kalichman MO, Amaral CM, White D, Pope H, et al. Integrated behavioral intervention to improve HIV/AIDS treatment adherence and reduce HIV transmission. Am J Public Health. 2011;101(3):531-8. [pmid: 21233431].
Kalichman SC, Cherry C, White D, Pope H, Cain D, Kalichman M. Altering key characteristics of a disseminated effective behavioral intervention for HIV positive adults: the “healthy relationships” experience. J Prim Prev. 2007;28(2):145-53. [pmid: 17333382].
Kamb ML, Fishbein M, Douglas JM, Rhodes F, Rogers J, Bolan G, et al. Efficacy of risk-reduction counseling to prevent human immunodeficiency virus and sexually transmitted diseases. JAMA. 1998;280(13):1161-7. [pmid: 9777816].
Kassutto S, Johnston MN, Rosenberg ES. Incomplete HIV type 1 antibody evolution and seroreversion in acutely infected individuals treated with early antiretroviral therapy. Clin Infect Dis. 2005;40(6):868-73. [pmid: 15736021].
Kaufmann GR, Khanna N, Weber R, Perrin L, Furrer H, Cavassini M, et al. Long-term virological response to multiple sequential regimens of highly active antiretroviral therapy for HIV infection. Antivir Ther. 2004;9(2):263-74. [pmid: 15134189].
Keane V, Hammond G, Keane H, Hewitt J. Quantitative evaluation of counseling associated with HIV testing. Southeast Asian J Trop Med Public Health. 2005;36(1):228-32. [pmid: 15906674].
Keiser O, Spoerri A, Brinkhof MW, Hasse B, Gayet-Ageron A, Tissot F, et al. Suicide in HIV-infected individuals and the general population in Switzerland, 1988-2008. Am J Psychiatry. 2010;167(2):143-50. [pmid: 20008942].
Keruly JC, Moore RD. Immune status at presentation to care did not improve among antiretroviral-naive persons from 1990 to 2006. Clin Infect Dis. 2007;45(10):1369-74. [pmid: 17968837].
Kesselring AM, Gras L, Wit FW, Smit C, Geerlings SE, Mulder JW, et al. Immune restoration and onset of new AIDS-defining events with combination antiretroviral therapy in HIV type-1-infected immigrants in the Netherlands. Antivir Ther. 2010;15(6):871-9. [pmid: 20834099].
Kesselring AM, Wit FW, Sabin CA, Lundgren JD, Gill MJ, Gatell JM, et al. Risk factors for treatment-limiting toxicities in patients starting nevirapine-containing antiretroviral therapy. AIDS. 2009;23(13):1689-99. [pmid: 19487907].
Klein H, Elifson KW, Sterk CE. Partner communication and HIV risk behaviors among “at risk” women. Soz Praventivmed. 2004;49(6):363-74. [pmid: 15669436].
Koegl C, Wolf E, Hanhoff N, Jessen H, Schewe K, Rausch M, et al. Treatment during primary HIV infection does not lower viral set point but improves CD4 lymphocytes in an observational cohort. Eur J Med Res. 2009;14(7):277-83. [pmid: 19661009].
Kohli R, Lo Y, Homel P, Flanigan TP, Gardner LI, Howard AA, et al. Bacterial pneumonia, HIV therapy, and disease progression among HIV-infected women in the HIV Epidemiologic Research (HER) study. Clin Infect Dis. 2006;43(1):90-8. [pmid: 16758423].
Korac M, Brmbolic B, Salemovic D, Ranin J, Stojsic Z, Jevtovic D, et al. Diagnostic esophago-gastro-duodenoscopy (EGD) in patients with AIDS-related upper gastrointestinal abnormalities. Hepato Gastroenterology. 2009;56(96):1675-8. [pmid: 20214216].
Korthuis PT, Asch SM, Anaya HD, Morgenstern H, Goetz MB, Yano EM, et al. Lipid screening in HIV-infected veterans. J Acquir Immune Defic Syndr. 2004;35(3):253-60. [pmid: 15076239].
Kourtis AP, Ellington S, Bansil P, Jamieson DJ, Posner SF. Hospitalizations for invasive pneumococcal disease among HIV-1-infected adolescents and adults in the United States in the era of highly active antiretroviral therapy and the conjugate pneumococcal vaccine. J Acquir Immune Defic Syndr. 2010;55(1):128-31. [pmid: 20622675].
Kourtis AP, Ellington S, Bansil P, Jamieson DJ, Posner SF. Hospitalizations for invasive pneumococcal disease among HIV-1-infected adolescents and adults in the United States in the era of highly active antiretroviral therapy and the conjugate pneumococcal vaccine. J Acquir Immune Defic Syndr. 2010;55(1):128-31. [pmid: 20622675].
Kousignian I, Launay O, Mayaud C, Rabaud C, Costagliola D, Abgrall S, et al. Does enfuvirtide increase the risk of bacterial pneumonia in patients receiving combination antiretroviral therapy?. J Antimicrob Chemother. 2010;65(1):138-44. [pmid: 19903719].
Kovari H, Ledergerber B, Peter U, Flepp M, Jost J, Schmid P, et al. Association of noncirrhotic portal hypertension in HIV-infected persons and antiretroviral therapy with didanosine: a nested case-control study. Clin Infect Dis. 2009;49(4):626-35. [pmid: 19589079].
Kozal MJ, Amico KR, Chiarella J, Schreibman T, Cornman D, Fisher W, et al. Antiretroviral resistance and high-risk transmission behavior among HIV-positive patients in clinical care. AIDS. 2004;18(16):2185-9. [pmid: 15577652].
Kravcik S, Victor G, Houston S, Sutherland D, Garber GE, Hawley-Foss N, et al. Effect of antiretroviral therapy and viral load on the perceived risk of HIV transmission and the need for safer sexual practices. J Acquir Immune Defic Syndr Hum Retrovirol. 1998;19(2):124-9. [pmid: 9768620].
Kreuter A, Brockmeyer NH, Weissenborn SJ, Gambichler T, Stucker M, Altmeyer P, et al. Penile intraepithelial neoplasia is frequent in HIV-positive men with anal dysplasia. J Invest Dermatol. 2008;128(9):2316-24. [pmid: 18385760].
Krishnan S, Schouten JT, Jacobson DL, Benson CA, Collier AC, Koletar SL, et al. Incidence of non-AIDS-defining cancer in antiretroviral treatment-naive subjects after antiretroviral treatment initiation: an ACTG longitudinal linked randomized trials analysis. Oncology. 2011;80(1-2):42-9. [pmid: 21606663].
Kumar PN, Rodriguez-French A, Thompson MA, Tashima KT, Averitt D, Wannamaker PG, et al. A prospective, 96-week study of the impact of trizivir, combivir/nelfinavir, and lamivudine/stavudine/nelfinavir on lipids, metabolic parameters and efficacy in antiretroviral-naive patients: effect of sex and ethnicity. HIV Med. 2006;7(2):85-98. [pmid: 16420253].
Kunavisarut P, Bijlsma WR, Pathanapitoon K, Patikulsila D, Choovuthayakorn J, Rothova A. Proliferative vitreoretinopathy in human immunodeficiency virus-infected patients in the era of highly active antiretroviral therapy. Am J Ophthalmol. 2010;150(2):218-22. [pmid: 20525529].
Lai S, Bartlett J, Lai H, Moore R, Cofrancesco J Jr, Pannu H, et al. Long-term combination antiretroviral therapy is associated with the risk of coronary plaques in African Americans with HIV infection. AIDS Patient Care STDs. 2009;23(10):815-24. [pmid: 19803679].
Lifson AR, Neuhaus J, Arribas JR, van den Berg-Wolf M, Labriola AM, Read TR, et al. Smoking-related health risks among persons with HIV in the Strategies for Management of Antiretroviral Therapy clinical trial. Am J Public Health. 2010;100(10):1896-903. [pmid: 20724677].
Lightfoot M, Rotheram-Borus MJ, Comulada WS, Reddy VS, Duan N. Efficacy of brief interventions in clinical care settings for persons living with HIV. J Acquir Immune Defic Syndr. 2010;53(3):348-56. [pmid: 19996978].
Logan TK, Cole J, Leukefeld C. Women, sex, and HIV: social and contextual factors, meta-analysis of published interventions, and implications for practice and research. Psychol Bull. 2002;128(6):851-85. [pmid: 12405135].
Lorello G, la Porte C, Pilon R, Zhang G, Karnauchow T, MacPherson P. Discordance in HIV-1 viral loads and antiretroviral drug concentrations comparing semen and blood plasma. HIV Med. 2009;10(9):548-54. [pmid: 19515092].
Louie B, Wong E, Klausner JD, Liska S, Hecht F, Dowling T, et al. Assessment of rapid tests for detection of human immunodeficiency virus-specific antibodies in recently infected individuals. J Clin Microbiol. 2008;46(4):1494-7. [pmid: 18234875].
Lowe SH, Hassink EA, van Eck-Smit BL, Borleffs JC, Lange JM, Reiss P. Stavudine but not didanosine as part of HAART contributes to peripheral lipoatrophy: a substudy from the Antiretroviral Regimen Evaluation Study (ARES). HIV Clinical Trials. 2007;8(5):337-44. [pmid: 17956835].
Lubelchek R, Kroc K, Hota B, Sharief R, Muppudi U, Pulvirenti J, et al. The role of rapid vs conventional human immunodeficiency virus testing for inpatients: effects on quality of care. Arch Intern Med. 2005;165(17):1956-60. [pmid: 16186464].
Lyons MS, Lindsell CJ, Hawkins DA, Raab DL, Trott AT, Fichtenbaum CJ. Contributions to early HIV diagnosis among patients linked to care vary by testing venue. BMC Public Health. 2008;8:220. [pmid: 18578881].
Lyons MS, Lindsell CJ, Ruffner AH, Trott AT, Fichtenbaum CJ. Relationship of self-reported prior testing history to undiagnosed HIV positivity and HIV risk. Curr HIV Res. 2009;7(6):580-8. [pmid: 19929792].
MacArthur RD, Novak RM, Peng G, Chen L, Xiang Y, Hullsiek KH, et al. A comparison of three highly active antiretroviral treatment strategies consisting of non-nucleoside reverse transcriptase inhibitors, protease inhibitors, or both in the presence of nucleoside reverse transcriptase inhibitors as initial therapy (CPCRA 058 FIRST Study): a long-term randomised trial. Lancet. 2006;368(9553):2125-35. [pmid: 17174704].
Maggiolo F, Ravasio L, Ripamonti D, Gregis G, Quinzan G, Arici C, et al. Similar adherence rates favor different virologic outcomes for patients treated with nonnucleoside analogues or protease inhibitors. Clin Infect Dis. 2005;40(1):158-63. [pmid: 15614706].
Maggiolo F, Roat E, Pinti M, Nasi M, Gibellini L, De Biasi S, et al. Mitochondrial changes during D-drug-containing once-daily therapy in HIV-positive treatment-naive patients. Antivir Ther. 2010;15(1):51-9. [pmid: 20167991].
Malan DR, Krantz E, David N, Rong Y, Mathew M, Iloeje UH, et al. 96-week efficacy and safety of atazanavir, with and without ritonavir, in a HAART regimen in treatment-naive patients. J Int Assoc Physicians AIDS Care. 2010;9(1):34-42. [pmid: 20071596].
Malan N, Su J, Mancini M, Yang R, Wirtz V, Absalon J, et al. Gastrointestinal tolerability and quality of life in antiretroviral-naive HIV-1-infected patients: data from the CASTLE study. AIDS Care. 2010;22(6):677-86. [pmid: 20467943].
Mallolas J, Blanco JL, Pich J, Arnaiz JA, Pena JM, Dalmau D, et al. A randomized trial comparing the efficacy and tolerability of two HAART strategies at two years in antiretroviral naive patients. Rev Clin Esp. 2007;207(9):427-32. [pmid: 17915162].
Margolin A, Avants SK, Warburton LA, Hawkins KA, Shi J. A randomized clinical trial of a manual-guided risk reduction intervention for HIV-positive injection drug users. Health Psychol. 2003;22(2):223-8. [pmid: 12683743].
Margot NA, Enejosa J, Cheng AK, Miller MD, McColl DJ, Study 934 Team. Development of HIV-1 drug resistance through 144 weeks in antiretroviral-naive subjects on emtricitabine, tenofovir disoproxil fumarate, and efavirenz compared with lamivudine/zidovudine and efavirenz in study GS-01-934. J Acquir Immune Defic Syndr. 2009;52(2):209-21. [pmid: 19644384].
Markham CM, Shegog R, Leonard AD, Bui TC, Paul ME. +CLICK: harnessing web-based training to reduce secondary transmission among HIV-positive youth. AIDS Care. 2009;21(5):622-31. [pmid: 19444671].
Markowitz M, Hill-Zabala C, Lang J, DeJesus E, Liao Q, Lanier ER, et al. Induction with abacavir/lamivudine/zidovudine plus efavirenz for 48 weeks followed by 48-week maintenance with abacavir/lamivudine/zidovudine alone in antiretroviral-naive HIV-1-infected patients. J Acquir Immune Defic Syndr. 2005;39(3):257-64. [pmid: 15980684].
Martin DJ, Riopelle D, Steckart MJ, Geshke N, Lin S. Support group participation, HIV viral load and sexual-risk behavior. Am J Health Behav. 2001;25(6):513-27. [pmid: 11720299].
Masciotra S, McDougal JS, Feldman J, Sprinkle P, Wesolowski L, Owen SM. Evaluation of an alternative HIV diagnostic algorithm using specimens from seroconversion panels and persons with established HIV infections. J Clin Virol. 2011;52(Suppl 1):S17-22. [pmid: 21981983].
Mausbach BT, Semple SJ, Strathdee SA, Zians J, Patterson TL. Efficacy of a behavioral intervention for increasing safer sex behaviors in HIV-positive MSM methamphetamine users: results from the EDGE study. Drug Alcohol Depend. 2007;87(2-3):249-57. [pmid: 17182196].
May M, Gompels M, Delpech V, Porter K, Post F, Johnson M, et al. Impact of late diagnosis and treatment on life expectancy in people with HIV-1: UK Collaborative HIV Cohort (UK CHIC) study. BMJ. 2011;343:d6016. [pmid: 21990260].
May MT, Sterne JA, Costagliola D, Sabin CA, Phillips AN, Justice AC, et al. HIV treatment response and prognosis in Europe and North America in the first decade of highly active antiretroviral therapy: a collaborative analysis. Lancet. 2006;368(9534):451-8. [pmid: 16890831].
McComsey GA, Kitch D, Daar ES, Tierney C, Jahed NC, Tebas P, et al. Bone mineral density and fractures in antiretroviral-naive persons randomized to receive abacavir-lamivudine or tenofovir disoproxil fumarate-emtricitabine along with efavirenz or atazanavir-ritonavir: AIDS Clinical Trials Group A5224s, a substudy of ACTG A5202. J Infect Dis. 2011;203(12):1791-801. [pmid: 21606537].
Meader N, Li R, Des Jarlais CD, Pilling S. Psychosocial interventions for reducing injection and sexual risk behaviour for preventing HIV in drug users. Cochrane Database Syst Rev. 2010;(1):CD007192. [pmid: 20091623].
Metsch LR, Feaster DJ, Gooden L, Matheson T, Mandler RN, Haynes L, et al. Implementing rapid HIV testing with or without risk-reduction counseling in drug treatment centers: results of a randomized trial. Am J Public Health. 2012;102(6):1160-7. [pmid: 22515871].
Metsch LR, Pereyra M, Messinger S, Del Rio C, Strathdee SA, Anderson-Mahoney P, et al. HIV transmission risk behaviors among HIV-infected persons who are successfully linked to care. Clin Infect Dis. 2008;47(4):577-84. [pmid: 18624629].
Miguez-Burbano MJ, Espinoza L, Lewis JE. HIV treatment adherence and sexual functioning. AIDS Behav. 2008;12(1):78-85. [pmid: 17295075].
Mikl J, Sudar Z, Smith PF, Bruckova M, Jedlicka J, Kastankova V, et al. HIV infection and high risk behavior among patients attending an STD referral clinic in Prague, Czech Republic. Sex Transm Infect. 1998;74(2):128-30. [pmid: 9634325].
Milam J, Richardson JL, McCutchan A, Stoyanoff S, Weiss J, Kemper C, et al. Effect of a brief antiretroviral adherence intervention delivered by HIV care providers. J Acquir Immune Defic Syndr. 2005;40(3):356-63. [pmid: 16249712].
Mimiaga MJ, Case P, Johnson CV, Safren SA, Mayer KH. Preexposure antiretroviral prophylaxis attitudes in high-risk Boston area men who report having sex with men: limited knowledge and experience but potential for increased utilization after education. J Acquir Immune Defic Syndr. 2009;50(1):77-83. [pmid: 19295337].
Mimiaga MJ, Reisner SL, Tetu AM, Bonafide KE, Cranston K, Bertrand T, et al. Partner notification after STD and HIV exposures and infections: knowledge, attitudes, and experiences of Massachusetts men who have sex with men. Public Health Rep. 2009;124(1):111-9. [pmid: 19413033].
Mimiaga MJ, Skeer M, Mayer KH, Safren SA. Study participation as a social group influencing sexual behaviours in an HIV-prevention trial for men who have sex with men. AIDS Care. 2008;20(3):346-55. [pmid: 18351483].
Mira JA, Lozano F, Santos J, Ramayo E, Terron A, Palacios R, et al. Gynaecomastia in HIV-infected men on highly active antiretroviral therapy: association with efavirenz and didanosine treatment. Antivir Ther. 2004;9(4):511-7. [pmid: 15456082].
Mitchell CG, Freels S, Creticos CM, Oltean A, Douglas R. Preliminary findings of an intervention integrating modified directly observed therapy and risk reduction counseling. AIDS Care. 2007;19(4):561-4. [pmid: 17453598].
Mitchell MM, Latimer WW. Unprotected casual sex and perceived risk of contracting HIV among drug users in Baltimore Maryland: evaluating the influence of non-injection versus injection drug user status. AIDS Care. 2009;21(2):221-30. [pmid: 19229692].
Mitha K, Yirsalign M, Cherner M, McCutchan A, Langford TD. Risk perception and beliefs regardng HIV infection among Ethiopian immigrants. AIDS Educ Prev. 2009;21(5):484-94. [pmid: 19842831].
Mmbaga EJ, Leyna GH, Mnyika KS, Hussain A, Klepp KI. Prevalence and predictors of failure to return for HIV-1 post-test counseling in the era of antiretroviral therapy in rural Kilimanjaro, Tanzania: challenges and opportunities. AIDS Care. 2009;21(2):160-7. [pmid: 19229684].
Mmbaga EJ, Leyna GH, Mnyika KS, Klepp KI. Sexually transmitted infections knowledge and its impact in the practice of risky sexual behaviours and HIV serostatus: results from rural Kilimanjaro, Tanzania. Sex Transm Infect. 2008;84(3):224-6. [pmid: 18283095].
Mocroft A, Ledergerber B, Viard JP, Staszewski S, Murphy M, Chiesi A, et al. Time to virological failure of 3 classes of antiretrovirals after initiation of highly active antiretroviral therapy: results from the EuroSIDA study group. J Infect Dis. 2004;190(11):1947-56. [pmid: 15529259].
Molina JM, Journot V, Furco A, Palmer P, De Castro N, Raffi F, et al. Five-year follow up of once-daily therapy with emtricitabine, didanosine and efavirenz (Montana ANRS 091 trial). Antivir Ther. 2007;12(3):417-22. [pmid: 17591032].
Molina JM, Levy Y, Fournier I, Hamonic S, Bentata M, Beck-Wirth G, et al. Interleukin-2 before antiretroviral therapy in patients with HIV infection: a randomized trial (ANRS 119). J Infect Dis. 2009;200(2):206-15. [pmid: 19508157].
Molina JM, Podsadecki TJ, Johnson MA, Wilkin A, Domingo P, Myers R, et al. A lopinavir/ritonavir-based once-daily regimen results in better compliance and is non-inferior to a twice-daily regimen through 96 weeks. AIDS Res Hum Retroviruses. 2007;23(12):1505-14. [pmid: 18160008].
Molitor F, Facer M, Ruiz JD. Safer sex communication and unsafe sexual behavior among young men who have sex with men in California. Arch Sex Behav. 1999;28(4):335-43. [pmid: 10553494].
Mondy KE, Gottdiener J, Overton ET, Henry K, Bush T, Conley L, et al. High prevalence of echocardiographic abnormalities among HIV-infected persons in the era of highly active antiretroviral therapy. Clin Infect Dis. 2011;52(5):378-86. [pmid: 21217185].
Moore RD, Keruly JC. CD4+ cell count 6 years after commencement of highly active antiretroviral therapy in persons with sustained virologic suppression. Clin Infect Dis. 2007;44(3):441-6. [pmid: 17205456].
Mootsikapun P, Chetchotisakd P, Anunnatsiri S, Boonyaprawit P. Efficacy and safety of indinavir/ritonavir 400/100 mg twice daily plus two nucleoside analogues in treatment-naive HIV-1-infected patients with CD4+ T-cell counts <200 cells/mm^3^: 96-week outcomes. Antivir Ther. 2005;10(8):911-6. [pmid: 16430196].
Morin SF, Shade SB, Steward WT, Carrico AW, Remien RH, Rotheram-Borus MJ, et al. A behavioral intervention reduces HIV transmission risk by promoting sustained serosorting practices among HIV-infected men who have sex with men. J Acquir Immune Defic Syndr. 2008;49(5):544-51. [pmid: 18989221].
Mugavero MJ, Raper JL, Reif S, Whetten K, Leserman J, Thielman NM, et al. Overload: impact of incident stressful events on antiretroviral medication adherence and virologic failure in a longitudinal, multisite human immunodeficiency virus cohort study. Psychosom Med. 2009;71(9):920-6. [pmid: 19875634].
Munoz-Laboy M, Castellanos D, Westacott R. Sexual risk behaviour, viral load, and perceptions of HIV transmission among homosexually active Latino men: an exploratory study. AIDS Care. 2005;17(1):33-45. [pmid: 15832832].
Myers JJ, Shade SB, Rose CD, Koester K, Maiorana A, Malitz FE, et al. Interventions delivered in clinical settings are effective in reducing risk of HIV transmission among people living with HIV: results from the Health Resources and Services Administration (HRSA)'s Special Projects of National Significance initiative. AIDS Behav. 2010;14(3):483-92. [pmid: 20229132].
Naar-King S, Parsons JT, Murphy DA, Chen X, Harris DR, Belzer ME. Improving health outcomes for youth living with the human immunodeficiency virus: a multisite randomized trial of a motivational intervention targeting multiple risk behaviors. Arch Pediatr Adolesc Med. 2009;163(12):1092-8. [pmid: 19996045].
Nachega JB, Chaisson RE, Goliath R, Efron A, Chaudhary MA, Ram M, et al. Randomized controlled trial of trained patient-nominated treatment supporters providing partial directly observed antiretroviral therapy. AIDS. 2010;24(9):1273-80. [pmid: 20453627].
Napravnik S, Keys JR, Quinlivan EB, Wohl DA, Mikeal OV, Eron JJ Jr. Triple-class antiretroviral drug resistance: risk and predictors among HIV-1-infected patients. AIDS. 2007;21(7):825-34. [pmid: 17415037].
Navazesh M, Mulligan R, Karim R, Mack WJ, Ram S, Seirawan H, et al. Effect of HAART on salivary gland function in the Women's Interagency HIV Study (WIHS). Oral Dis. 2009;15(1):52-60. [pmid: 19017280].
Navazesh M, Mulligan R, Pogoda J, Greenspan D, Alves M, Phelan J, et al. The effect of HAART on salivary microbiota in the Women's Interagency HIV Study (WIHS). Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2005;100(6):701-8. [pmid: 16301151].
Nittayananta W, Talungchit S, Jaruratanasirikul S, Silpapojakul K, Chayakul P, Nilmanat A, et al. Effects of long-term use of HAART on oral health status of HIV-infected subjects. J Oral Pathol Med. 2010;39(5):397-406. [pmid: 20202089].
Nugent NR, Brown LK, Belzer M, Harper GW, Nachman S, Naar-King S, et al. Youth living with HIV and problem substance use: elevated distress is associated with nonadherence and sexual risk. J Int Assoc Physicians AIDS Care. 2010;9(2):113-5. [pmid: 20133498].
Nyamathi A, Suhadev M, Swaminathan S, Fahey J. Perceptions of a community sample about participation in future HIV vaccine trials in South India. AIDS Behav. 2007;11(4):619-27. [pmid: 17016758].
Obermeyer CM, Rajkumar R. HAART and sexual risk behavior. JAMA. 2004;292(19):17. [pmid: 15547154].
Ojo O, Verbeek JH, Rasanen K, Heikkinen J, Isotalo LK, Mngoma N, et al. Interventions to reduce risky sexual behaviour for preventing HIV infection in workers in occupational settings. Cochrane Database Syst Rev. 2011;(12):CD005274. [pmid: 22161391].
Onen NF, Shacham E, Stamm KE, Overton ET. Comparisons of sexual behaviors and STD prevalence among older and younger individuals with HIV infection. AIDS Care. 2010;22(6):711-7. [pmid: 20467941].
Orrell C, Harling G, Lawn SD, Kaplan R, McNally M, Bekker LG, et al. Conservation of first-line antiretroviral treatment regimen where therapeutic options are limited. Antivir Ther. 2007;12(1):83-8. [pmid: 17503751].
Osei-Sekyere B, Karstaedt AS. Immune reconstitution inflammatory syndrome involving the skin. Clin Exp Dermatol. 2010;35(5):477-81. [pmid: 19874370].
Ostrow DG, Silverberg MJ, Cook RL, Chmiel JS, Johnson L, Li X, et al. Prospective study of attitudinal and relationship predictors of sexual risk in the multicenter AIDS cohort study. AIDS Behav. 2008;12(1):127-38. [pmid: 17410419].
Overton ET, Nurutdinova D, Freeman J, Seyfried W, Mondy KE. Factors associated with renal dysfunction within an urban HIV-infected cohort in the era of highly active antiretroviral therapy. HIV Med. 2009;10(6):343-50. [pmid: 19490182].
Parker RD, Ruutel K. Associations of high-risk behaviour and HIV status with HIV knowledge among persons in Tallinn, Estonia. Scand J Public Health. 2010;38(7):748-55. [pmid: 20823046].
Parveen Z, Acheampong E, Pomerantz RJ, Jacobson JM, Wigdahl B, Mukhtar M. Effects of highly active antiretroviral therapy on HIV-1-associated oral complications. Curr HIV Res. 2007;5(3):281-92. [pmid: 17504170].
Patel K, Hernan MA, Williams PL, Seeger JD, McIntosh K, Dyke RB, et al. Long-term effects of highly active antiretroviral therapy on CD4+ cell evolution among children and adolescents infected with HIV: 5 years and counting. Clin Infect Dis. 2008;46(11):1751-60. [pmid: 18426371].
Patel P, Taylor MM, Montoya JA, Hamburger ME, Kerndt PR, Holmberg SD. Circuit parties: sexual behaviors and HIV disclosure practices among men who have sex with men at the White Party, Palm Springs, California, 2003. AIDS Care. 2006;18(8):1046-9. [pmid: 17012098].
Patterson T, Shaw W, Semple S. Reducing the sexual risk behaviors of HIV+ individuals: outcome of a randomized controlled trial. Ann Behav Med. 2003;25(2):137-45. [pmid: 12704016].
Perez-Elias MJ, Moreno A, Casado JL, Dronda F, Antela A, Lopez D, et al. Observational study to evaluate clinical outcomes after first-line efavirenz-or lopinavir-ritonavir-based HAART in treatment-naive patients. J Int Assoc Physicians AIDS Care. 2009;8(5):308-13. [pmid: 19721095].
Powles T, Robinson D, Stebbing J, Shamash J, Nelson M, Gazzard B, et al. Highly active antiretroviral therapy and the incidence of non-AIDS-defining cancers in people with HIV infection. J Clin Oncol. 2009;27(6):884-90. [pmid: 19114688].
Prestage G, Mao L, Kippax S, Jin F, Hurley M, Grulich A, et al. Use of viral load to negotiate condom use among gay men in Sydney, Australia. AIDS Behav. 2009;13(4):645-51. [pmid: 19199021].
Centers for Disease Control and Prevention. Disparities in diagnoses of HIV infection between blacks/African Americans and other racial/ethnic populations—37 states, 2005-2008. MMWR Morb Mortal Wkly Rep. 2011;60(4):93-102. [pmid: 21293323].
Prost A, Griffiths CJ, Anderson J, Wight D, Hart GJ. Feasibility and acceptability of offering rapid HIV tests to patients registering with primary care in London (UK): a pilot study. Sex Transm Infect. 2009;85(5):326-9. [pmid: 19487214].
Purcell DW, Latka MH, Metsch LR, Latkin CA, Gomez CA, Mizuno Y, et al. Results from a randomized controlled trial of a peer-mentoring intervention to reduce HIV transmission and increase access to care and adherence to HIV medications among HIV-seropositive injection drug users. J Acquir Immune Defic Syndr. 2007;46(2):1. [pmid: 17514017].
Purcell DW, Metsch LR, Latka M, Santibanez S, Gomez CA, Eldred L, et al. Interventions for seropositive injectors-research and evaluation: an integrated behavioral intervention with HIV-positive injection drug users to address medical care, adherence, and risk reduction. J Acquir Immune Defic Syndr. 2004;37(2):1. [pmid: 15385907].
Ramos RL, Ferreira-Pinto JB, Rusch ML, Ramos ME. Pasa la voz (spread the word): using women's social networks for HIV education and testing. Public Health Rep. 2010;125(4):528-33. [pmid: 20597452].
Remien RH, Halkitis PN, O'Leary A, Wolitski RJ, Gomez CA. Risk perception and sexual risk behaviors among HIV-positive men on antiretroviral therapy. AIDS Behav. 2005;9(2):167-76. [pmid: 15933836].
Reza-Paul S, Beattie T, Syed HU, Venukumar KT, Venugopal MS, Fathima MP, et al. Declines in risk behaviour and sexually transmitted infection prevalence following a community-led HIV preventive intervention among female sex workers in Mysore, India. AIDS. 2008;22(Suppl 5):S91-100. [pmid: 19098483].
Romero EG, Teplin LA, McClelland GM, Abram KM, Welty LJ, Washburn JJ. A longitudinal study of the prevalence, development, and persistence of HIV/sexually transmitted infection risk behaviors in delinquent youth: implications for health care in the community. Pediatrics. 2007;119(5):e1126-41. [pmid: 17473083].
Ross MW, Timpson SC, Williams ML, Amos C, McCurdy S, Bowen AM, et al. Responsibility as a dimension of HIV prevention normative beliefs: measurement in three drug-using samples. AIDS Care. 2007;19(3):403-9. [pmid: 17453576].
Rosser BR, Hatfield LA, Miner MH, Ghiselli ME, Lee BR, Welles SL, et al. Effects of a behavioral intervention to reduce serodiscordant unsafe sex among HIV positive men who have sex with men: the Positive Connections randomized controlled trial study. J Behav Med. 2010;33(2):147-58. [pmid: 20101454].
Rotheram-Borus M, Lee M, Murphy D, Futterman D, Duan N, Birnbaum J, et al. Efficacy of a preventive intervention for youths living with HIV. Am J Public Health. 2001;91(3):400-5. [pmid: 11236404].
Rotheram-Borus MJ, Desmond K, Comulada WS, Arnold EM, Johnson M, Healthy Living Trial Group. Reducing risky sexual behavior and substance use among currently and formerly homeless adults living with HIV. Am J Public Health. 2009;99(6):1100-7. [pmid: 18799777].
Rutherford G, Feldman KA, Kennedy GE. Three- or four- versus two-drug antiretroviral maintenance regimens for HIV infection. Cochrane Database Syst Rev. 2000;(2):CD002037. [pmid: 10796850].
Safren SA, O'Cleirigh C, Skeer MR, Driskell J, Goshe BM, Covahey C, et al. Demonstration and evaluation of a peer-delivered, individually-tailored, HIV prevention intervention for HIV-infected MSM in their primary care setting. AIDS Behav. 2011;15(5):949-58. [pmid: 20853023].
Salami AK, Akande AA, Olokoba AB. Serum lipids and glucose abnormalities in HIV/AIDS patients on antiretroviral therapies. West Afr J Med. 2009;28(1):300-5. [pmid: 20383833].
Salawu FK, Bwala SA, Wakil MA, Bani B, Bukbuk DN, Kida I. Cognitive function in HIV-seropositive Nigerians without AIDS. J Neurol Sci. 2008;267(1-2):142-6. [pmid: 18001772].
Samaranayake A, Chen MY, McNeil J, Read TR, Hocking JS, Bradshaw CS, et al. Definitions of antiretroviral treatment failure for measuring quality outcomes. HIV Med. 2010;11(7):427-31. [pmid: 20136659].
Samet JH, Winter MR, Grant L, Hingson R. Factors associated with HIV testing among sexually active adolescents: a Massachusetts survey. Pediatrics. 1997;100(3 Pt 1):371-7. [pmid: 9282708].
San Antonio-Gaddy M, Richardson-Moore A, Burstein GR, Newman DR, Branson BM, Birkhead GS. Rapid HIV antibody testing in the New York State Anonymous HIV Counseling and Testing Program: experience from the field. J Acquir Immune Defic Syndr. 2006;43(4):446-50. [pmid: 16980908].
Sanchez-Conde M, Palacios R, Sanz J, Rodriguez-Novoa S, Rivas P, Santos J, et al. Efficacy and safety of a once daily regimen with efavirenz, lamivudine, and didanosine, with and without food, as initial therapy for HIV infection: the ELADI study. AIDS Res Hum Retroviruses. 2007;23(10):1237-41. [pmid: 17961110].
Sayana S, Prosser P, Ricaurte JC, Sanchez S, Hamwi G, Hershey-Weber J, et al. Analysis of a switch from enfuvirtide to raltegravir in patients with undetectable viral load: efficacy and quality of life at 24 weeks. J Int Assoc Physicians AIDS Care. 2009;8(2):85-6. [pmid: 19369697].
Schappert J, Wians FH Jr, Schiff E, Smalley D, Gambardella R, Lee WM, et al. Multicenter evaluation of the Bayer ADVIA Centaur HIV 1/O/2 enhanced (EHIV) assay. Clin Chim Acta. 2006;372(1-2):158-66. [pmid: 16769045].
Scheer S, Chu PL, Klausner JD, Katz MH, Schwarcz SK. Effect of highly active antiretroviral therapy on diagnoses of sexually transmitted diseases in people with AIDS. Lancet. 2001;357(9254):432-5. [pmid: 11273063].
Schiller DS, Youssef-Bessler M. Etravirine: a second-generation nonnucleoside reverse transcriptase inhibitor (NNRTI) active against NNRTI-resistant strains of HIV. Clin Ther. 2009;31(4):692-704. [pmid: 19446143].
Scott VF, Sitapati A, Martin S, Summers P, Washington M, Daniels F, et al. The Howard University Hospital experience with routineized HIV screening: a progress report. Trans Am Clin Climatol Assoc. 2009;120:429-34. [pmid: 19768195].
Semaille C, Barin F, Cazein F, Pillonel J, Lot F, Brand D, et al. Monitoring the dynamics of the HIV epidemic using assays for recent infection and serotyping among new HIV diagnoses: experience after 2 years in France. J Infect Dis. 2007;196(3):377-83. [pmid: 17597452].
Shamos SJ, Mettenbrink CJ, Subiadur JA, Mitchell BL, Rietmeijer CA. Evaluation of a testing-only “express” visit option to enhance efficiency in a busy STI clinic. Sex Transm Dis. 2008;35(4):336-40. [pmid: 18277943].
Sherman KE, Shire NJ, Cernohous P, Rouster SD, Omachi JH, Brun S, et al. Liver injury and changes in hepatitis C virus (HCV) RNA load associated with protease inhibitor-based antiretroviral therapy for treatment-naive HCV-HIV-coinfected patients: lopinavir-ritonavir versus nelfinavir. Clin Infect Dis. 2005;41(8):1186-95. [pmid: 16163639].
Shey M, Kongnyuy EJ, Shang J, Wiysonge CS. A combination drug of abacavir-lamivudine-zidovudine (trizivir) for treating HIV infection and AIDS. Cochrane Database Syst Rev. 2009;(3):CD005481. [pmid: 19588374].
Shiels MS, Cole SR, Wegner S, Armenian H, Chmiel JS, Ganesan A, et al. Effect of HAART on incident cancer and noncancer AIDS events among male HIV seroconverters. J Acquir Immune Defic Syndr. 2008;48(4):485-90. [pmid: 18614916].
Sikkema KJ, Wilson PA, Hansen NB, Kochman A, Neufeld S, Ghebremichael MS, et al. Effects of a coping intervention on transmission risk behavior among people living with HIV/AIDS and a history of childhood sexual abuse. J Acquir Immune Defic Syndr. 2008;47(4):506-13. [pmid: 18176319].
Silva A, Glick NR, Lyss SB, Hutchinson AB, Gift TL, Pealer LN, et al. Implementing an HIV and sexually transmitted disease screening program in an emergency department. Ann Emerg Med. 2007;49(5):564-72. [pmid: 17113684].
Silverman M, LaPerriere K, Haukoos JS. Rapid HIV testing in an urban emergency department: using social workers to affect risk behaviors and overcome barriers. Health Soc Work. 2009;34(4):305-8. [pmid: 19927480].
Silvestri DM, Modjarrad K, Blevins ML, Halale E, Vermund SH, McKinzie JP. A comparison of HIV detection rates using routine opt-out provider-initiated HIV testing and counseling versus a standard of care approach in a rural African setting. J Acquir Immune Defic Syndr. 2011;56(1):e9-32. [pmid: 21189483].
Smith KY, Patel P, Fine D, Bellos N, Sloan L, Lackey P, et al. Randomized, double-blind, placebo-matched, multicenter trial of abacavir/lamivudine or tenofovir/emtricitabine with lopinavir/ritonavir for initial HIV treatment. AIDS. 2009;23(12):1547-56. [pmid: 19542866].
Smith LV, Rudy ET, Javanbakht M, Uniyal A, Sy LS, Horton T, et al. Client satisfaction with rapid HIV testing: comparison between an urban sexually transmitted disease clinic and a community-based testing center. AIDS Patient Care STDs. 2006;20(10):693-700. [pmid: 17052139].
Spaulding A, Rutherford GW, Siegfried N. Stavudine or zidovudine in three-drug combination therapy for initial treatment of HIV infection in antiretroviral-naive individuals. Cochrane Database Syst Rev. 2010;(8):CD008651. [pmid: 20687097].
Spaulding A, Rutherford GW, Siegfried N. Tenofovir or zidovudine in three-drug combination therapy with one nucleoside reverse transcriptase inhibitor and one non-nucleoside reverse transcriptase inhibitor for initial treatment of HIV infection in antiretroviral-naive individuals. Cochrane Database Syst Rev. 2010;(10):CD008740. [pmid: 20927777].
Spielberg F, Branson BM, Goldbaum GM, Lockhart D, Kurth A, Rossini A, et al. Choosing HIV counseling and testing strategies for outreach settings: a randomized trial. J Acquir Immune Defic Syndr. 2005;38(3):348-55. [pmid: 15735456].
Squires KE, Young B, DeJesus E, Bellos N, Murphy D, Sutherland-Phillips DH, et al. Safety and efficacy of a 36-week induction regimen of abacavir/lamivudine and ritonavir-boosted atazanavir in HIV-infected patients. HIV Clin Trials. 2010;11(2):69-79. [pmid: 20542844].
Stefan MS, Blackwell JM, Crawford KM, Martinez J, Wu Sung S, Holliday SA, et al. Patients' attitudes toward and factors predictive of human immunodeficiency virus testing of academic medical clinics. Am J Med Sci. 2010;340(4):264-7. [pmid: 20881755].
Stein JA, Rotheram-Borus MJ, Swendeman D, Milburn NG. Predictors of sexual transmission risk behaviors among HIV-positive young men. AIDS Care. 2005;17(4):433-42. [pmid: 16036228].
Steingrover R, Garcia EF, van Valkengoed IG, Bekker V, Bezemer D, Kroon FP, et al. Transient lowering of the viral set point after temporary antiretroviral therapy of primary HIV type 1 infection. AIDS Res Hum Retroviruses. 2010;26(4):379-87. [pmid: 20377419].
Stolte IG, de Wit JB, van Eeden A, Coutinho RA, Dukers NH. Perceived viral load, but not actual HIV-1-RNA load, is associated with sexual risk behaviour among HIV-infected homosexual men. AIDS. 2004;18(14):1943-9. [pmid: 15353980].
Strategies for Management of Antiretroviral Therapy Study Group, Lundgren JD, Babiker A, El-Sadr W, Emery S, Grund B, et al. Inferior clinical outcome of the CD4+ cell count-guided antiretroviral treatment interruption strategy in the SMART study: role of CD4+ cell counts and HIV RNA levels during follow-up. J Infect Dis. 2008;197(8):1145-55. [pmid: 18476293].
Suarez TP, Kelly JA, Pinkerton SD, Stevenson YL, Hayat M, Smith MD, et al. Influence of a partner's HIV serostatus, use of highly active antiretroviral therapy, and viral load on perceptions of sexual risk behavior in a community sample of men who have sex with men. J Acquir Immune Defic Syndr. 2001;28(5):471-7. [pmid: 11744837].
Sued O, Miro JM, Alquezar A, Claramonte X, Garcia F, Plana M, et al. Primary human immunodeficiency virus type 1 infection: clinical, virological and immunological characteristics of 75 patients (1997-2003). Enferm Infecc Microbiol Clin. 2006;24(4):238-44. [pmid: 16725083].
Sullivan PS, Drake AJ, Sanchez TH. Prevalence of treatment optimism-related risk behavior and associated factors among men who have sex with men in 11 states, 2000-2001. AIDS Behav. 2007;11(1):123-9. [pmid: 16767506].
Sundaram V, Lazzeroni LC, Douglass LR, Sanders GD, Tempio P, Owens DK. A randomized trial of computer-based reminders and audit and feedback to improve HIV screening in a primary care setting. Int J STD AIDS. 2009;20(8):527-33. [pmid: 19625582].
Sundstrom A, Mortimer O, Akerlund B, Karlsson A, Flamholc L, Hakangard C, et al. Increased risk of abdominal wall hernia associated with combination anti-retroviral therapy in HIV-infected patients: results from a Swedish cohort-study. Pharmacoepidemiol Drug Saf. 2010;19(5):465-73. [pmid: 20186997].
Taiwo BO, Idoko JA, Marcelin AG, Otoh I, Reddy S, Iyaji PG, et al. Patient-selected treatment partners did not protect against drug resistance during first-line NNRTI-based HAART in a randomized trial. J Acquir Immune Defic Syndr. 2010;54(5):563-5. [pmid: 20647829].
Taiwo BO, Li X, Palella F, Jacobson LP, Margolick JB, Detels R, et al. Higher risk of AIDS or death in patients with lower CD4 cell counts after virally suppressive HAART. HIV Med. 2009;10(10):657-60. [pmid: 19601997].
Tedaldi EM, Absalon J, Thomas AJ, Shlay JC, van den Berg-Wolf M. Ethnicity, race, and gender: differences in serious adverse events among participants in an antiretroviral initiation trial—results of CPCRA 058 (FIRST Study). J Acquir Immune Defic Syndr. 2008;47(4):441-8. [pmid: 18176329].
Tenorio AR, Jiang H, Zheng Y, Bastow B, Kuritzkes DR, Bartlett JA, et al. Delaying a treatment switch in antiretroviral-treated HIV type 1-infected patients with detectable drug-resistant viremia does not have a profound effect on immune parameters: AIDS Clinical Trials Group Study A5115. AIDS Res Hum Retroviruses. 2009;25(2):135-9. [pmid: 19239354].
Thomas BE, Ramachandran R, Anitha S, Swaminathan S. Feasibility of routine HIV testing among TB patients through a voluntary counselling and testing centre. Int J Tuberc Lung Dis. 2007;11(12):1296-301. [pmid: 18034949].
Tien PC, Schneider MF, Cole SR, Levine AM, Cohen M, DeHovitz J, et al. Antiretroviral therapy exposure and insulin resistance in the Women's Interagency HIV Study. J Acquir Immune Defic Syndr. 2008;49(4):369-76. [pmid: 19186350].
Tipnis SR, Fox EF. Uptake of HIV testing in a busy South London GU medicine clinic—will we reach targets set in the National Strategy and are we testing those at risk?. Int J STD AIDS. 2006;17(7):484-5. [pmid: 16820081].
Torti C, Lapadula G, Antinori A, Quirino T, Maserati R, Castelnuovo F, et al. Hyperbilirubinemia during atazanavir treatment in 2,404 patients in the Italian atazanavir expanded access program and MASTER cohorts. Infection. 2009;37(3):244-9. [pmid: 19471856].
Tsu RC, Burm ML, Gilhooly JA, Sells CW. Telephone vs. face-to-face notification of HIV results in high-risk youth. J Adolesc Health. 2002;30(3):154-60. [pmid: 11869921].
Ulett KB, Willig JH, Lin HY, Routman JS, Abroms S, Allison J, et al. The therapeutic implications of timely linkage and early retention in HIV care. AIDS Patient Care STDs. 2009;23(1):41-9. [pmid: 19055408].
Van de Ven P, Kippax S, Knox S, Prestage G, Crawford J. HIV treatments optimism and sexual behaviour among gay men in Sydney and Melbourne. AIDS. 1999;13(16):2289-94. [pmid: 10563714].
Van de Ven P, Mao L, Fogarty A, Rawstorne P, Crawford J, Prestage G, et al. Undetectable viral load is associated with sexual risk taking in HIV serodiscordant gay couples in Sydney. AIDS. 2005;19(2):179-84. [pmid: 15668543].
Van de Ven P, Prestage G, Crawford J, Grulich A, Kippax S. Sexual risk behaviour increases and is associated with HIV optimism among HIV-negative and HIV-positive gay men in Sydney over the 4 year period to February 2000. AIDS. 2000;14(18):2951-3. [pmid: 11153682].
Van de Ven P, Rawstorne P, Nakamura T, Crawford J, Kippax S. HIV treatments optimism is associated with unprotected anal intercourse with regular and with casual partners among Australian gay and homosexually active men. Int J STD AIDS. 2002;13(3):181-3. [pmid: 11860696].
Van Den Bout-Van Den Beukel CJ, Fievez L, Michels M, Sweep FC, Hermus AR, Bosch ME, et al. Vitamin D deficiency among HIV type 1-infected individuals in the Netherlands: effects of antiretroviral therapy. AIDS Res Hum Retroviruses. 2008;24(11):1375-82. [pmid: 18928396].
van der Snoek EM, de Wit JB, Mulder PG, van der Meijden WI. Incidence of sexually transmitted diseases and HIV infection related to perceived HIV/AIDS threat since highly active antiretroviral therapy availability in men who have sex with men. Sex Transm Dis. 2005;32(3):170-5. [pmid: 15729154].
van der Straten A, Gomez CA, Saul J, Quan J, Padian N. Sexual risk behaviors among heterosexual HIV serodiscordant couples in the era of post-exposure prevention and viral suppressive therapy. AIDS. 2000;14(4):10. [pmid: 10770532].
van Lelyveld SFL, Gras L, Kesselring A, Zhang S, De Wolf F, Wensing AMJ, et al. Long-term complications in patients with poor immunological recovery despite virological successful HAART in Dutch ATHENA cohort. AIDS. 2012;26(4):465-74. [pmid: 22112603].
van Leth F, Andrews S, Grinsztejn B, Wilkins E, Lazanas MK, Lange JM, et al. The effect of baseline CD4 cell count and HIV-1 viral load on the efficacy and safety of nevirapine or efavirenz-based first-line HAART. AIDS. 2005;19(5):463-71. [pmid: 15764851].
Vanable PA, Carey MP, Blair DC, Littlewood RA. Impact of HIV-related stigma on health behaviors and psychological adjustment among HIV-positive men and women. AIDS Behav. 2006;10(5):473-82. [pmid: 16604295].
Vanable PA, Ostrow DG, McKirnan DJ, Taywaditep KJ, Hope BA. Impact of combination therapies on HIV risk perceptions and sexual risk among HIV-positive and HIV-negative gay and bisexual men. Health Psychol. 2000;19(2):134-45. [pmid: 10762097].
Vanable PA, Ostrow DG, McKirnan DJ. Viral load and HIV treatment attitudes as correlates of sexual risk behavior among HIV-positive gay men. J Psychosom Res. 2003;54(3):263-9. [pmid: 12614836].
Walensky RP, Arbelaez C, Reichmann WM, Walls RM, Katz JN, Block BL, et al. Revising expectations from rapid HIV tests in the emergency department. Ann Intern Med. 2008;149(3):153-60. [pmid: 18678842].
Walensky RP, Losina E, Malatesta L, Barton GE, O'Connor CA, Skolnik PR, et al. Effective HIV case identification through routine HIV screening at urgent care centers in Massachusetts. Am J Public Health. 2005;95(1):71-3. [pmid: 15623861].
Wand H, Calmy A, Carey DL, Samaras K, Carr A, Law MG, et al. Metabolic syndrome, cardiovascular disease and type 2 diabetes mellitus after initiation of antiretroviral therapy in HIV infection. AIDS. 2007;21(18):2445-53. [pmid: 18025881].
Weber R, Huber M, Rickenbach M, Furrer H, Elzi L, Hirschel B, et al. Uptake of and virological response to antiretroviral therapy among HIV-infected former and current injecting drug users and persons in an opiate substitution treatment programme: the Swiss HIV Cohort Study. HIV Med. 2009;10(7):407-16. [pmid: 19490174].
Wenger NS, Greenberg JM, Hilborne LH, Kusseling F, Mangotich M, Shapiro MF. Effect of HIV antibody testing and AIDS education on communication about HIV risk and sexual behavior. Ann Intern Med. 1992;117(11):905-11. [pmid: 1443951].
Wenger NS, Linn LS, Epstein M, Shapiro MF. Reduction of high-risk sexual behavior among heterosexuals undergoing HIV antibody testing: a randomized clinical trial. Am J Public Health. 1991;81(12):1580-5. [pmid: 1746653].
Whetten K, Reif S, Whetten R, Murphy-McMillan LK. Trauma, mental health, distrust, and stigma among HIV-positive persons: implications for effective care. Psychosom Med. 2008;70(5):531-8. [pmid: 18541904].
White DA, Scribner AN, Schulden JD, Branson BM, Heffelfinger JD. Results of a rapid HIV screening and diagnostic testing program in an urban emergency department. Ann Emerg Med. 2009;54(1):56-64. [pmid: 18990468].
Whyte JT, Dawson SB. The sexual behaviors of African American women living with HIV disease: is perceived HIV status altering sexual behavior?. J Assoc Nurses AIDS Care. 2001;12(2):56-65. [pmid: 11296731].
Whyte JT, Standing T, Madigan E. The relationship between HIV-related knowledge and safe sexual behavior in African American women dwelling in the rural southeast. J Assoc Nurses AIDS Care. 2004;15(2):51-8. [pmid: 15090133].
Wilson TE, Gore ME, Greenblatt R, Cohen M, Minkoff H, Silver S, et al. Changes in sexual behavior among HIV-infected women after initiation of HAART. Am J Public Health. 2004;94(7):1141-6. [pmid: 15226134].
Wilson TE, Minkoff H. Condom use consistency associated with beliefs regarding HIV disease transmission among women receiving HIV antiretroviral therapy. J Acquir Immune Defic. 2001;27(3):289-91. [pmid: 11464150].
Wohl AR, Garland WH, Valencia R, Squires K, Witt MD, Kovacs A, et al. A randomized trial of directly administered antiretroviral therapy and adherence case management intervention. Clin Infect Dis. 2006;42(11):1619-27. [pmid: 16652320].
Wolitski RJ, Gomez CA, Parsons JT. Effects of a peer-led behavioral intervention to reduce HIV transmission and promote serostatus disclosure among HIV-seropositive gay and bisexual men. AIDS. 2005;19(Suppl 1):S99-109. [pmid: 15838199].
Zapka JG, Stoddard A, Zorn M, McCusker J, Mayer KH. HIV antibody test result knowledge, risk perceptions and behavior among homosexually active men. Patient Educ Couns. 1991;18(1):9-17.
Zaric GS, Bayoumi AM, Brandeau ML, Owens DK. The cost-effectiveness of counseling strategies to improve adherence to highly active antiretroviral therapy among men who have sex with men. Med Decis Making. 2008;28(3):359-76. [pmid: 18349433].
Zhou J, Phanupak P, Kiertiburanakul S, Ditangco R, Kamarulzaman A, Pujary S, et al. Highly active antiretroviral treatment containing efavirenz or nevirapine and related toxicity in the TREAT Asia HIV Observational Database. J Infect Dis. 2006;43(4):501-3. [pmid: 17099317].
Zuniga ML, Baldwin H, Uhler D, Brennan J, Olshefsky AM, Oliver E, et al. Supporting Positive Living and Sexual Health (SPLASH): a clinician and behavioral counselor risk-reduction intervention in a university-based HIV clinic. AIDS Behav. 2007;11(5 Suppl):S58-71. [pmid: 17587172].

### Wrong study design for key question

Acar A, Kemahli S, Altunay H, Kosan E, Oncul O, Gorenek L, et al. The significance of repeat testing in Turkish blood donors screened with HBV, HCV and HIV immunoassays and the importance of S/CO ratios in the interpretation of HCV/HIV screening test results and as a determinant for further confirmatory testing. Transfus Med. 2010;20(3):152-9. [pmid: 20059750].
Adeyemi OM, Vibhakar S, Evans AT. Obesity and lymphocyte subsets in virologically suppressed HIV-infected patients. Metabolism. 2009;58(9):1285-7. [pmid: 19497596].
Andersson S, Asjo B, Jenum PA, Manner I, Njolstad G, Ragnhildstveit E, et al. Relevance of a combined HIV antigen/antibody assay to detect early HIV infections in a low prevalence population: case reports. Clin Lab. 2004;50(7-8):409-13. [pmid: 15330508].
Antiretroviral Therapy Cohort Collaboration, Zwahlen M, Harris R, May M, Hogg R, Costagliola D, et al. Mortality of HIV-infected patients starting potent antiretroviral therapy: comparison with the general population in nine industrialized countries. Int J Epidemiol. 2009;38(6):1624-33. [pmid: 19820106].
Baker JV, Peng G, Rapkin J, Krason D, Reilly C, Cavert WP, et al. Poor initial CD4+ recovery with antiretroviral therapy prolongs immune depletion and increases risk for AIDS and non-AIDS diseases. J Acquir Immune Defic Syndr. 2008;48(5):541-6. [pmid: 18645520].
Bansi L, Sabin C, Delpech V, Hill T, Fisher M, Walsh J, et al. Trends over calendar time in antiretroviral treatment success and failure in HIV clinic populations. HIV Med. 2010;11(7):432-8. [pmid: 20146736].
Bechange S, Bunnell R, Awor A, Moore D, King R, Mermin J, et al. Two-year follow-up of sexual behavior among HIV-uninfected household members of adults taking antiretroviral therapy in Uganda: no evidence of disinhibition. AIDS Behav. 2010;14(4):816-23. [pmid: 18949550].
Berkley-Patton J, Bowe-Thompson C, Bradley-Ewing A, Hawes S, Moore E, Williams E, et al. Taking It to the Pews: a CBPR-guided HIV awareness and screening project with black churches. AIDS Educ Prev. 2010;22(3):218-37. [pmid: 20528130].
Bogart LM, Howerton D, Lange J, Becker K, Setodji CM, Asch SM. Scope of rapid HIV testing in urban U.S. hospitals. Public Health Rep. 2008;123(4):494-503. [pmid: 18763412].
Bogart LM, Howerton D, Lange J, Becker K, Setodji CM, Asch SM. Scope of rapid HIV testing in private nonprofit urban community health settings in the United States. Am J Public Health. 2008;98(4):736-42. [pmid: 18309135].
Boily MC, Godin G, Hogben M, Sherr L, Bastos FI. The impact of the transmission dynamics of the HIV/AIDS epidemic on sexual behaviour: a new hypothesis to explain recent increases in risk taking-behaviour among men who have sex with men. Med Hypotheses. 2005;65(2):215-26. [pmid: 15922091].
Bokhour BG, Solomon JL, Knapp H, Asch SM, Gifford AL. Barriers and facilitators to routine HIV testing in VA primary care. J Gen Intern Med. 2009;24(10):1109-14. [pmid: 19690923].
Boodram B, Plankey MW, Cox C, Tien PC, Cohen MH, Anastos K, et al. Prevalence and correlates of elevated body mass index among HIV-positive and HIV-negative women in the Women's Interagency HIV Study. AIDS Patient Care STDs. 2009;23(12):1009-16. [pmid: 19909168].
Braithwaite RS, Roberts MS, Chang CC, Goetz MB, Gibert CL, Rodriguez-Barradas MC, et al. Influence of alternative thresholds for initiating HIV treatment on quality-adjusted life expectancy: a decision model. Ann Intern Med. 2008;148(3):178-85. [pmid: 18252681].
Brogly SB, Bruneau J, Vincelette J, Lamothe F, Franco EL. Risk behaviour change and HIV infection among injection drug users in Montreal. AIDS. 2000;14(16):2575-82. [pmid: 11101070].
Brooks RA, Landovitz RJ, Kaplan RL, Lieber E, Lee SJ, Barkley TW. Sexual risk behaviors and acceptability of HIV pre-exposure prophylaxis among HIV-negative gay and bisexual men in serodiscordant relationships: a mixed methods study. AIDS Patient Care STDs. 2012;26(2):87-94. [pmid: 22149764].
Bunnell R, Ekwaru JP, Solberg P, Wamai N, Bikaako-Kajura W, Were W, et al. Changes in sexual behavior and risk of HIV transmission after antiretroviral therapy and prevention interventions in rural Uganda. AIDS. 2006;20(1):85-92. [pmid: 16327323].
Butler DM, Smith DM. Serosorting can potentially increase HIV transmissions. AIDS. 2007;21(9):1218-20. [pmid: 17502737].
Calderon Y, Leider J, Hailpern S, Chin R, Ghosh R, Fettig J, et al. High-volume rapid HIV testing in an urban emergency department. AIDS Patient Care STDs. 2009;23(9):749-55. [pmid: 19698029].
Campos-Outcalt D, Mickey T, Weisbuch J, Jones R. Integrating routine HIV testing into a public health STD clinic. Public Health Rep. 2006;121(2):175-80. [pmid: 16528951].
Cassels S, Menza TW, Goodreau SM, Golden MR. HIV serosorting as a harm reduction strategy: evidence from Seattle, Washington. AIDS. 2009;23(18):2497-506. [pmid: 19834319].
Cecchi E, Imazio M, Pomari F, Dal Conte I, Preziosi C, Lipani F, et al. A clinical approach for cardiovascular monitoring of HIV-infected patients: results from an observational cohort study. Ital Heart J. 2005;6(12):972-6. [pmid: 16502712].
Celentano DD, Latimore AD, Mehta SH. Variations in sexual risks in drug users: emerging themes in a behavioral context. Curr HIV/AIDS Rep. 2008;5(4):212-8. [pmid: 18838061].
Centers for Disease Control and Prevention. Acute HIV infection—New York City, 2008. MMWR Morb Mortal Wkly Rep. 2009;58(46):1296-9. [pmid: 19940835].
Centers for Disease Control and Prevention. Rapid HIV testing in outreach and other community settings—United States, 2004-2006. MMWR Morb Mortal Wkly Rep. 2007;56(47):1233-7. [pmid: 18046300].
Chen SY, Moss WJ, Pipkin SS, McFarland W. A novel use of AIDS surveillance data to assess the impact of initial treatment regimen on survival. Int J STD AIDS. 2009;20(5):330-5. [pmid: 19386970].
Coffie PA, Tonwe-Gold B, Tanon AK, Amani-Bosse C, Bedikou G, Abrams EJ, et al. Incidence and risk factors of severe adverse events with nevirapine-based antiretroviral therapy in HIV-infected women: MTCT-Plus program, Abidjan, Cote d'Ivoire. BMC Inf Dis. 2010;(10):188. [pmid: 20576111].
Cohall A, Dini S, Nye A, Dye B, Neu N, Hyden C. HIV testing preferences among young men of color who have sex with men. Am J Public Health. 1961;100(10):1961-6. [pmid: 20075330].
Collins CB Jr, Hearn KD, Whittier DN, Freeman A, Stallworth JD, Phields M. Implementing packaged HIV-prevention interventions for HIV-positive individuals: considerations for clinic-based and community-based interventions. Public Health Rep. 2010;(1):55-63. [pmid: 20408388].
Crum-Cianflone N, Tejidor R, Medina S, Barahona I, Ganesan A. Obesity among patients with HIV: the latest epidemic. AIDS Patient Care STDs. 2008;22(12):925-30. [pmid: 19072098].
Dalton P, McCord A. HIV sexual transmission under HAART: Project Inform comments on 2008 Swiss Statement. Proj Inf Perspect. 2008;(46):26-8. [pmid: 19048681].
Das S, Ghanem M, Huengsberg M. Experience with efavirenz in end-stage renal disease. Int J STD AIDS. 2004;15(2):143. [pmid: 15006080].
Day S, Lakhani D, Hankins M, Rodgers CA. Improving uptake of HIV testing in patients with a confirmed STI. Int J STD AIDS. 2004;15(9):626-8. [pmid: 15339373].
De Cock KM, Gilks CF, Lo YR, Guerma T. Can antiretroviral therapy eliminate HIV transmission?. Lancet. 2009;373(9657):7-9. [pmid: 19038440].
de Wit JB, Adam PC. To test or not to test: psychosocial barriers to HIV testing in high-income countries. HIV Med. 2008;(2):20-2. [pmid: 18557865].
Del Romero J, Hernando V, Castilla J, Garcia S, Gil S, Rodriquez C. Lack of HIV heterosexual transmission attributable to HAART in serodiscordant couples. Paper presented at: XVII International AIDS Conference. August 2008. Mexico City. PMID: N/A.
Desai MM, Rosenheck RA, Desai RA. Prevalence and correlates of human immunodeficiency virus testing and posttest counseling among outpatients with serious mental illness. J Nerv Ment Dis. 2007;195(9):776-80. [pmid: 17984780].
Diamond C. HAART and sexual risk behavior. JAMA. 2004;292(19):17. [pmid: 15547155].
Dietz CA, Ablah E, Reznik D, Robbins DK. Patients' attitudes about rapid oral HIV screening in an urban, free dental clinic. AIDS Patient Care STDs. 2008;22(3):205-12. [pmid: 18290751].
Ehrenkranz PD, Pagan JA, Begier EM, Linas BP, Madison K, Armstrong K. Written informed-consent statutes and HIV testing. Am J Prev Med. 2009;37(1):57-63. [pmid: 19423271].
Erausquin JT, Duan N, Grusky O, Swanson AN, Kerrone D, Rudy ET. Increasing the reach of HIV testing to young Latino MSM: results of a pilot study integrating outreach and services. J Health Care Poor Underserved. 2009;20(3):756-65. [pmid: 19648703].
Fidler S, Fraser C, Fox J, Tamm N, Griffin JT, Weber J. Comparative potency of three antiretroviral therapy regimes in primary HIV infection. AIDS. 2006;20(2):247-52. [pmid: 16511418].
Forsyth SF, Agogo EA, Lau L, Jungmann E, Man S, Edwards SG, et al. Would offering rapid point-of-care testing or non-invasive methods improve uptake of HIV testing among high-risk genitourinary medicine clinic attendees? A patient perspective. Int J STD AIDS. 2008;19(8):550-2. [pmid: 18663043].
Freedman E, Dhaliwal K, Estcourt C, Baily G. Symptomatic HIV viraemia during a drug holiday: an argument against treatment interruption?. Int J STD AIDS. 2004;15(8):564-5. [pmid: 15307970].
Galatowitsch P, Rodriguez E. New emphasis in HIV prevention: interventions targeting HIV-positive men. Body Posit. 2001;14(4):47-8. [pmid: 11569954].
Gasiorowicz M, Stodola J. HIV prevalence estimates and alignment among recent diagnoses, targeted tests, and prevention services by demographic and racial/ethnic group in Wisconsin. AIDS Educ Prev. 2011;23(3 Suppl):7-16. [pmid: 21689033].
Goetz MB, Hoang T, Bowman C, Knapp H, Rossman B, Smith R, et al. A system-wide intervention to improve HIV testing in the Veterans Health Administration. J Gen Intern Med. 2008;28(8):1200-7. [pmid: 18452045].
Grover SA, Coupal L, Gilmore N, Mukherjee J. Impact of dyslipidemia associated with highly active antiretroviral therapy (HAART) on cardiovascular risk and life expectancy. Am J Cardiol. 2005;95(5):586-91. [pmid: 15721096].
Haukoos JS, Hopkins E, Hull A, Dean C, Donahoe K, Ruzas CM, et al. HIV testing in emergency departments in the United States: a national survey. Ann Emerg Med. 2011;58(Suppl 1):S10-6. [pmid: 21684387].
Haukoos JS, White DA, Lyons MS, Hopkins E, Calderon Y, Kalish B, et al. Operational methods of HIV testing in emergency departments: a systematic review. Ann Emerg Med. 2011;58(Suppl 1):S96-103. [pmid: 21684417].
Holstad MM. Adherence, sexual risk, and viral load in HIV-infected women prescribed antiretroviral therapy. AIDS Patient Care STDs. 2011;25(7):431-8. [pmid: 21663541].
Hoxhaj S, Davila JA, Modi P, Kachalia N, Malone K, Ruggerio MC, et al. Using nonrapid HIV technology for routine, opt-out HIV screening in a high-volume urban emergency department. Ann Emerg Med. 2011;58(Suppl 1):S79-84. [pmid: 21684414].
Hsieh YH, Jung JJ, Shahan JB, Pollack HA, Hairston HS, Moring-Parris D, et al. Outcomes and cost analysis of 3 operational models for rapid HIV testing services in an academic inner-city emergency department. Ann Emerg Med. 2011;58(Suppl 1):S133-9. [pmid: 21684392].
Jaroszewicz J, Wiercinska-Drapalo A, Lapinski TW, Prokopowicz D, Rogalska M, Parfieniuk A. Does HAART improve renal function? An association between serum cystatin C concentration, HIV viral load and HAART duration. Antivir Ther. 2006;11(5):641-5. [pmid: 16964834].
Johnson MD, Decker CF. Osteonecrosis in HIV-infected persons: radiographic findings delay clinical diagnosis. AIDS Read. 2008;18(3):124-6. [pmid: 18398979].
Kanuha VK, Mueller CW, Sullivan KM, Glancey P, Matsumoto P, Martel LD. HIV and women in Hawaii: risk and protective factors in HIV/AIDS prevention. Hawaii Med J. 2003;62(9):187-92. [pmid: 14593657].
Kapadia F, Latka MH, Hudson SM, Golub ET, Campbell JV, Bailey S, et al. Correlates of consistent condom use with main partners by partnership patterns among young adult male injection drug users from five US cities. Drug Alcohol Depend. 2007;91(Suppl 1):S56-63. [pmid: 17329041].
Keiser O, Taffe P, Zwahlen M, Battegay M, Bernasconi E, Weber R, et al. All cause mortality in the Swiss HIV Cohort Study from 1990 to 2001 in comparison with the Swiss population. AIDS. 2004;18(13):1835-43. [pmid: 15316345].
Kenagy GP, Linsk NL, Bruce D, Warnecke R, Gordon A, Wagaw F, et al. Service utilization, service barriers, and gender among HIV-positive consumers in primary care. AIDS Patient Care STDs. 2003;17(5):235-44. [pmid: 12816617].
Kendrick SR, Kroc KA, Withum D, Rydman RJ, Branson BM, Weinstein RA. Outcomes of offering rapid point-of-care HIV testing in a sexually transmitted disease clinic. J Acquir Immune Defic Syndr. 2005;38(2):142-6. [pmid: 15671798].
Kennedy CE, Medley AM, Sweat MD, O'Reilly KR. Behavioural interventions for HIV positive prevention in developing countries: a systematic review and meta-analysis. Bull World Health Organ. 1. 2010;88(8):615-23. [pmid: 20680127].
Kennedy LA, Gordin FM, Kan VL. Assessing targeted screening and low rates of HIV testing. Am J Public Health. 2010;100(9):1765-8. [pmid: 20634454].
Kirk JB, Goetz MB. Human immunodeficiency virus in an aging population, a complication of success. J Am Geriatr Soc. 2009;57(11):2129-38. [pmid: 19793157].
Klarkowski DB, Wazome JM, Lokuge KM, Shanks L, Mills CF, O'Brien DP. The evaluation of a rapid in situ HIV confirmation test in a programme with a high failure rate of the WHO HIV two-test diagnostic algorithm. PLoS One. 2009;4(e2):4351. [pmid: 19197370].
Klevens RM, Fleming PL, Neal JJ, Li J. Knowledge of partner risk and secondary transmission of HIV. Am J Prev Med. 2001;20(4):277-81. [pmid: 11331116].
Kohli R, Klein RS, Schoenbaum EE, Anastos K, Minkoff H, Sacks HS. Aging and HIV infection. J Urban Health. 2006;83(1):31-42. [pmid: 16736353].
Law MG, Prestage G, Grulich A, Van de Ven P, Kippax S. Modelling the effect of combination antiretroviral treatments on HIV incidence. AIDS. 2001;15(10):1287-94. [pmid: 11426074].
Lee MB, Leibowitz A, Rotheram-Borus MJ. Cost-effectiveness of a behavioral intervention for seropositive youth. AIDS Educ Prev. 2005;17(2):105-18. [pmid: 15899749].
Lekakis J, Ikonomidis I, Palios J, Tsiodras S, Karatzis E, Poulakou G, et al. Association of highly active antiretroviral therapy with increased arterial stiffness in patients infected with human immunodeficiency virus. Am J Hypertens. 2009;22(8):828-34. [pmid: 19556973].
Liu H, Miller LG, Hays RD, Golin CE, Wu T, Wenger NS, et al. Repeated measures longitudinal analyses of HIV virologic response as a function of percent adherence, dose timing, genotypic sensitivity, and other factors. J Acquir Immune Defic Syndr. 2006;41(3):315-22. [pmid: 16540932].
Lubelchek RJ, Kroc KA, Levine DL, Beavis KG, Roberts RR. Routine, rapid HIV testing of medicine service admissions in the emergency department. Ann Emerg Med. 2011;58(Suppl 1):S65-70. [pmid: 21684411].
Ly TD, Laperche S, Brennan C, Vallari A, Ebel A, Hunt J, et al. Evaluation of the sensitivity and specificity of six HIV combined p24 antigen and antibody assays. J Virol Method. 2004;122(2):185-94. [pmid: 15542143].
Lyons MS, Lindsell CJ, Ledyard HK, Frame PT, Trott AT. Emergency department HIV testing and counseling: an ongoing experience in a low-prevalence area. Ann Emerg Med. 2005;46(1):22-8. [pmid: 15988422].
Lyss SB, Branson BM, Kroc KA, Couture EF, Newman DR, Weinstein RA. Detecting unsuspected HIV infection with a rapid whole-blood HIV test in an urban emergency department. J Acquir Immune Defic Syndr. 2007;44(4):435-42. [pmid: 17224850].
Magnani R, Sabin K, Saidel T, Heckathorn D. Review of sampling hard-to-reach and hidden populations for HIV surveillance. AIDS. 2005;19(Suppl 2):S67-72. [pmid: 15930843].
Malm K, von Sydow M, Andersson S. Performance of three automated fourth-generation combined HIV antigen/antibody assays in large-scale screening of blood donors and clinical samples. Transfus Med. 2009;19(2):78-88. [pmid: 19320855].
Marks G, Crepaz N, Janssen RS. Estimating sexual transmission of HIV from persons aware and unaware that they are infected with the virus in the USA. AIDS. 2006;20(10):1447-50. [pmid: 16791020].
McCormick AW, Walensky RP, Lipsitch M, Losina E, Hsu H, Weinstein MC, et al. The effect of antiretroviral therapy on secondary transmission of HIV among men who have sex with men. Clin Infect Dis. 2007;44(8):1115-22. [pmid: 17366461].
McKellar MS, Jongthavorn P, Khanlou H. False-positivity of HIV-2 immunoblots in a cohort of elite suppressors infected with HIV-1. J Acquir Immune Defic Syndr. 2008;47(5):15. [pmid: 18362696].
Mehta SD, Hall J, Lyss SB, Skolnik PR, Pealer LN, Kharasch S. Adult and pediatric emergency department sexually transmitted disease and HIV screening: programmatic overview and outcomes. Acad Emerg Med. 2007;14(3):250-8. [pmid: 17331918].
Menezes BF, Williams P, Ramtahal J, Boggild M. The significance of early HIV testing. Clin Med. 2008;8(5):550-1. [pmid: 18975493].
Merchant RC, Catanzaro BM, Seage GR, Mayer KH, Clark MA, Degruttola VG, et al. Demographic variations in HIV testing history among emergency department patients: implications for HIV screening in US emergency departments. J Med Screen. 2009;16(2):60-6. [pmid: 19564517].
Merchant RC, Clark MA, Seage GR 3rd, Mayer KH, Degruttola VG, Becker BM. Emergency department patient perceptions and preferences on opt-in rapid HIV screening program components. AIDS Care. 2009;21(4):490-500. [pmid: 19283644].
Merchant RC, Seage GR, Mayer KH, Clark MA, DeGruttola VG, Becker BM. Emergency department patient acceptance of opt-in, universal, rapid HIV screening. Public Health Rep. 2008;3:27-40. [pmid: 19172704].
Miller WC, Leone PA, McCoy S, Nguyen TQ, Williams DE, Pilcher CD. Targeted testing for acute HIV infection in North Carolina. AIDS. 2009;23(7):835-43. [pmid: 19318909].
Mollen C, Lavelle J, Hawkins L, Ambrose C, Ruby B. Description of a novel pediatric emergency department-based HIV screening program for adolescents. AIDS Patient Care STDs. 2008;22(6):505-12. [pmid: 18462077].
Mugavero MJ, Pence BW, Whetten K, Leserman J, Swartz M, Stangl D, et al. Childhood abuse and initial presentation for HIV care: an opportunity for early intervention. AIDS Care. 2007;19(9):1083-7. [pmid: 18058391].
Mullins TL, Kollar LM, Lehmann C, Kahn JA. Changes in human immunodeficiency virus testing rates among urban adolescents after introduction of routine and rapid testing. Arch Pediatr Adolesc Med. 2010;164(9):870-4. [pmid: 20819970].
Mumma BE, Suffoletto BP. Less encouraging lessons from the front lines: barriers to implementation of an emergency department-based HIV screening program. Ann Emerg Med. 2011;58(Suppl 1):S44-8. [pmid: 21684407].
Murphy DA, Mitchell R, Vermund SH, Futterman D, Adolescent Medicine. HIV/AIDS Research Network. Factors associated with HIV testing among HIV-positive and HIV-negative high-risk adolescents: the REACH Study. Pediatrics. 2002;110(3):e36. [pmid: 12205286].
Myers HF, Satz P, Miller BE, Bing EG, Evans G, Richardson MA, et al. The African-American Health Project (AAHP): study overview and select findings on high risk behaviors and psychiatric disorders in African American men. Ethn Health. 1997;2(3):183-96. [pmid: 9426983].
Myers HF, Wyatt GE, Loeb TB, Carmona JV, Warda U, Longshore D, et al. Severity of child sexual abuse, post- traumatic stress and risky sexual behaviors among HIV-positive women. AIDS Behav. 2006;10(2):191-9. [pmid: 16479413].
Myers JJ, Steward WT, Charlebois E, Koester KA, Maiorana A, Morin SF. Written clinic procedures enhance delivery of HIV “prevention with positives” counseling in primary health care settings. J Acquir Immune Defic Syndr. 2004;37(Suppl 2):S95-100. [pmid: 15385905].
Nacher M, El Guedj M, Vaz T, Nasser V, Randrianjohany A, Alvarez F, et al. Risk factors for late HIV diagnosis in French Guiana. AIDS. 2005;19(7):727-9. [pmid: 15821399].
Nash D, Bennani Y, Ramaswamy C, Torian L. Estimates of HIV incidence among persons testing for HIV using the sensitive/less sensitive enzyme immunoassy, New York City, 2001. J Acquir Immune Defic Syndr. 2005;39(1):102-11. [pmid: 15851920].
Oette M, Kroidl A, Gobels K, Stabbert A, Menge M, Sagir A, et al. Predictors of short-term success of antiretroviral therapy in HIV infection. J Antimicrob Chemother. 2006;58(1):147-53. [pmid: 16687458].
Ortega-Larrocea G, Espinosa E, Reyes-Teran G. Lower incidence and severity of cytomegalovirus-associated immune recovery uveitis in HIV-infected patients with delayed highly active antiretroviral therapy. AIDS. 2005;19(7):735-8. [pmid: 15821403].
Ostrow DE, Fox KJ, Chmiel JS, Silvestre A, Visscher BR, Vanable PA, et al. Attitudes towards highly active antiretroviral therapy are associated with sexual risk taking among HIV-infected and uninfected homosexual men. AIDS. 2002;16(5):775-80. [pmid: 11964534].
Otto-Salaj LL, Stevenson LY. Influence of psychiatric diagnoses and symptoms on HIV risk behavior in adults with serious mental illness. AIDS Read. 2001;11(4):197-204. [pmid: 11392677].
Paci P, Carello R, Bernaschi M, D'Offizi G, Castiglione F. Immune control of HIV-1 infection after therapy interruption: immediate versus deferred antiretroviral therapy. BMC Infect Dis. 2009;9:172. [pmid: 19840392].
Pantazis N, Touloumi G, Vanhems P, Gill J, Bucher HC, Porter K, et al. The effect of antiretroviral treatment of different durations in primary HIV infection. AIDS. 2008;22(18):2441-50. [pmid: 19005267].
Pao D, Fisher M, Hue S, Dean G, Murphy G, Cane PA, et al. Transmission of HIV-1 during primary infection: relationship to sexual risk and sexually transmitted infections. AIDS. 2005;19(1):85-90. [pmid: 15627037].
Patterson KB, Cohn SE, Uyanik J, Hughes M, Smurzynski M, Eron JJ. Treatment responses in antiretroviral treatment-naive premenopausal and postmenopausal HIV-1-infected women: an analysis from AIDS Clinical Trials Group Studies. Clin Infect Dis. 2009;49(3):473-6. [pmid: 19555288].
Picciano JF, Roffman RA, Kalichman SC, Walker DD. Lowering obstacles to HIV prevention services: effects of a brief, telephone-based intervention using motivational enhancement therapy. Ann Behav Med. 2007;34(2):177-87. [pmid: 17927556].
Pinto Neto LF, Vieira NF, Soprani M, Cunha CB, Cabral VP, Dietze R, et al. Longitudinal comparison between plasma and seminal HIV-1 viral loads during antiretroviral treatment. Rev Soc Bras Med Trop. 2003;36:689-94. [pmid: 15049108].
Pittrof R, McLellan J. Test Not Talk screening for asymptomatic men. Int J STD AIDS. 2007;18(4):274-5. [pmid: 17509179].
Plantier JC, Lemee V, Nabias R, Sire JM, Simon F. Generic screening test for HIV infection. AIDS. 2006;20(9):1345-7. [pmid: 16816572].
Plowden KO, Fletcher A, Miller JL. Factors influencing HIV-risk behaviors among HIV-positive urban African Americans. J Assoc Nurses AIDS Care. 2005;16(1):21-8. [pmid: 15903275].
Prado G, Schwartz SJ, Pattatucci-Aragon A, Clatts M, Pantin H, Fernandez MI, et al. The prevention of HIV transmission in Hispanic adolescents. Drug Alcohol Depend. 2006;84(Suppl 1):S43-53. [pmid: 16764997].
Prestage G, Mao L, Jin F, Grulich A, Kaldor J, Kippax S. Sex work and risk behaviour among HIV-negative gay men. AIDS Care. 2007;19(7):931-4. [pmid: 17712698].
Prestage G, Mao L, McGuigan D, Crawford J, Kippax S, Kaldor J, et al. HIV risk and communication between regular partners in a cohort of HIV-negative gay men. AIDS Care. 2006;18(2):166-72. [pmid: 16338775].
Puhan MA, Van Natta ML, Palella FJ, Addessi A, Meinert C, Ocular Complications of AIDS Research Group. Excess mortality in patients with AIDS in the era of highly active antiretroviral therapy: temporal changes and risk factors. Clin Infect Dis. 2010;51(8):947-56. [pmid: 20825306].
Purcell DW, Parsons JT, Halkitis PN, Mizuno Y, Woods WJ. Substance use and sexual transmission risk behavior of HIV-positive men who have sex with men. J Subst Abuse. 2001;13(1-2):185-200. [pmid: 11547619].
Pyne JM. The psychiatry of AIDS: a guide to diagnosis and treatment. J Acquir Immune Defic Syndr. 2006;43(1):119-20. PMID: N/A.
Rakhmanina NY, Capparelli EV, van den Anker JN. Personalized therapeutics: HIV treatment in adolescents. Clin Pharmacol Ther. 2008;84(6):734-40. [pmid: 18830226].
Ramos CG, Barcelos NT. Does episodic antiretroviral therapy increase HIV transmission risk compared with continuous therapy?. J Acquir Immune Defic Syndr. 2009;51(4):1. [pmid: 19590291].
Rathbun RC, Farmer KC, Stephens JR, Lockhart SM. Impact of an adherence clinic on behavioral outcomes and virologic response in treatment of HIV infection: a prospective, randomized, controlled pilot study. Clin Ther. 2005;27(2):199-209. [pmid: 15811483].
Reilly T, Woo G. Social support and maintenance of safer sex practices among people living with HIV/AIDS. Health Soc Work. 2004;29(2):97-105. [pmid: 15156842].
Reilly T, Woodruff SI, Smith L, Clapp JD, Cade J. Unsafe sex among HIV positive individuals: cross-sectional and prospective predictors. J Comm Health. 2010;35(2):115-23. [pmid: 20012476].
Roehr B. HIV programmes reduce deaths and new infections, UNAIDS report shows. BMJ. 1099. 337:a1099. [pmid: 18676440].
Romanowski B, Campbell PJ, Preiksaitis JK, Fonseca K. Human immunodeficiency virus seroprevalence and risk behaviors in patients attending sexually transmitted disease clinics in Alberta. Sex Transm Dis. 1997;24(8):487-94. [pmid: 9293613].
Ross MW, Rosser BR, Neumaier ER, Positive Connections Team. The relationship of internalized homonegativity to unsafe sexual behavior in HIV-seropositive men who have sex with men. AIDS Educ Prev. 2008;20(6):547-57. [pmid: 19072529].
Rotheram-Borus MJ, Swendeman D, Comulada WS, Weiss RE, Lee M, Lightfoot M. Prevention for substance-using HIV-positive young people: telephone and in-person delivery. J Acquir Immune Defic Syndr. 2004;37:S68-77. [pmid: 15385902].
Rutledge SE. Single-session motivational enhancement counseling to support change toward reduction of HIV transmission by HIV positive persons. Arch Sex Behav. 2007;36(2):313-9. [pmid: 17109234].
Ryder K, Haubrich DJ, Calla D, Myers T, Burchell AN, Calzavara L. Psychosocial impact of repeat HIV-negative testing: a follow-up study. AIDS Behav. 2005;9(4):459-64. [pmid: 16328711].
Sabine C. Antiretroviral Therapy Cohort Collaboration. AIDS events among individuals initiating HAART: do some patients experience a greater benefit from HAART than others?. AIDS. 2005;19(17):1995-2000. [pmid: 16260906].
Sattin RW, Wilde JA, Freeman AE, Miller KM, Dias JK. Rapid HIV testing in a southeastern emergency department serving a semiurban-semirural adolescent and adult population. Ann Emerg Med. 2011;58(Suppl 1):S60-4. [pmid: 21684410].
Sax PE, Tierney C, Collier AC, Fischl MA, Mollan K, Peeples L, et al. Abacavir-lamivudine versus tenofovir-emtricitabine for initial HIV-1 therapy. N Engl J Med. 2009;361(23):2230-40. [pmid: 19952143].
Schrantz SJ, Babcock CA, Theodosis C, Brown S, Mercer S, Pillow MT, et al. A targeted, conventional assay, emergency department HIV testing program integrated with existing clinical procedures. Ann Emerg Med. 2011;58(Suppl 1):S85-8. [pmid: 21684415].
Scott J, Bansi L, Ivens D. HIV test uptake after introducing an opt-out screening system. Int J STD AIDS. 2006;17(3):213. [pmid: 16510018].
Semaille C, Cazein F, Pillonel J, Lot F, Le Vu S, Pinget R, et al. Four years of surveillance of recent HIV infections at country level, France, mid 2003-2006: experience and perspectives. Euro Surveill. 2008;13(7-9):17-22. [pmid: 18775291].
Semple SJ, Patterson TL, Grant I. Binge use of methamphetamine among HIV-positive men who have sex with men: pilot data and HIV prevention implications. AIDS Educ Prev. 2003;15(2):133-47. [pmid: 12739790].
Shagufta Z, Mahto M. Uptake of HIV testing in a genitourinary medicine clinic following opt-out screening method and uptake rate by individual clinicians. Int J STD AIDS. 2007;18(9):650-1. [pmid: 17785017].
Shima T, Isshiki M, Kondo M, Tsukada M, Shiomi S, Imai M. Introduction of rapid HIV tests to a public health center in Japan and evaluation of its effects [Japanese]. Nihon Koshu Eisei Zasshi. 2006;53(3):167-77. [pmid: 16689271].
Shima T, Sudo K, Kondo M, Kurai H, Sagara H, Imai M. Evaluation of new fourth-generation human immunodeficiency virus antigen and antibody detection assay with enzyme-linked fluorescent immunoassay. Kansenshogaku Zasshi. 2007;81(5):562-72. [pmid: 17966638].
Sitlinger AP, Lindsell CJ, Ruffner AH, Wayne DB, Hart KW, Trott AT, et al. Preliminary program evaluation of emergency department HIV prevention counseling. Ann Emerg Med. 2011;58(Suppl 1):S120-5. [pmid: 21684390].
Sorensen JL, Dilley J, London J, Okin RL, Delucchi KL, Phibbs CS. Case management for substance abusers with HIV/AIDS: a randomized clinical trial. Am J Drug Alcohol Abuse. 2003;29(1):133-50. [pmid: 12731685].
Spielberg F, Kurth A, Reidy W, McKnight T, Dikobe W, Wilson C. Iterative evaluation in a mobile counseling and testing program to reach people of color at risk for HIV—new strategies improve program acceptability, effectiveness, and evaluation capabilities. AIDS Educ Prev. 2011;23(3 Suppl):110-6. [pmid: 21689041].
Stekler J, Swenson PD, Wood RW, Handsfield HH, Golden MR. Targeted screening for primary HIV infection through pooled HIV-RNA testing in men who have sex with men. AIDS. 2005;19(12):1323-5. [pmid: 16052089].
Tanner AE, Muvva R, Miazad R, Johnson S, Burnett P, Olthoff G, et al. Integration of HIV testing and linkage to care by the Baltimore City Health Department. Sex Transm Dis. 2010;37(2):129-30. [pmid: 20038866].
Torres GW, Heffelfinger JD, Pollack HA, Barrera SG, Rothman RE. HIV screening programs in US emergency departments: a cross-site comparison of structure, process, and outcomes. Ann Emerg Med. 2011;58(Suppl 1):S104-13. [pmid: 21684388].
Torres GW, Yonek J, Pickreign J, Whitmore H, Hasnain-Wynia R. HIV testing and referral to care in U.S. hospitals prior to 2006: results from a national survey. Public Health Rep. 2009;124(3):400-8. [pmid: 19445416].
Walensky RP, Paltiel AD, Losina E, Morris BL, Scott CA, Rhode ER, et al. Test and Treat DC: forecasting the impact of a comprehensive HIV strategy in Washington DC. Clin Infect Dis. 2010;51(4):392-400. [pmid: 20617921].
White DA, Tran T, Dideum PJ, Vahidnia F, Gordon DM, Ng V, et al. Physician-initiated rapid HIV testing in an urban emergency department: comparison of testing using a point-of-care versus a laboratory model. Ann Emerg Med. 2011;58(Suppl 1):S53-9. [pmid: 21684409].
Wilbur L, Huffman G, Lofton S, Finnell JT. The use of a computer reminder system in an emergency department universal HIV screening program. Ann Emerg Med. 2011;58(Suppl 1):S71-3. [pmid: 21684412].
Wilkinson MJ, Bain BJ, Phelan L, Benzie A. Increased haemoglobin A2 percentage in HIV infection: disease or treatment?. AIDS. 2007;21(9):1207-8. [pmid: 17502732].
Williamson LM, Dodds JP, Mercey DE, Hart GJ, Johnson AM. Sexual risk behaviour and knowledge of HIV status among community samples of gay men in the UK. AIDS. 2008;22(9):1063-70. [pmid: 18520350].
Wilson DP, Hoare A, Regan DG, Law MG. Importance of promoting HIV testing for preventing secondary transmissions: modelling the Australian HIV epidemic among men who have sex with men. Sex Health. 2009;6(1):19-33. [pmid: 19254488].
Xia Q, Molitor F, Osmond DH, Tholandi M, Pollack LM, Ruiz JD, et al. Knowledge of sexual partner's HIV serostatus and serosorting practices in a California population-based sample of men who have sex with men. AIDS. 2006;20(16):2081-9. [pmid: 17053354].

### No original data (review article, letter, editorial, results reported elsewhere)

Attia S, Egger M, Muller M, Zwahlen M, Low N. Sexual transmission of HIV according to viral load and antiretroviral therapy: systematic review and meta-analysis. AIDS. 2009;23(11):1397-404. [pmid: 19381076].
Baggaley R, Ferguson N, Garnett G. The epidemiological impact of antiretroviral use predicted by mathematical models: a review. Emerg Themes Epidemiol. 2005;2(1):9. [pmid: 16153307].
Bassett IV, Walensky RP. Integrating HIV screening into routine health care in resource-limited settings. Clin Infect Dis. 2010;50(3):15. [pmid: 20397960].
Bhattacharya R, Barton S, Catalan J. When good news is bad news: psychological impact of false positive diagnosis of HIV. AIDS Care. 2008;20(5):560-4. [pmid: 18484325].
Branson BM. State of the art for diagnosis of HIV infection. Clin Infect Dis. 2007;45(4 Suppl):S221-5. [pmid: 18190290].
Brill IK, Macaluso M, et al. A SAS program for the computation of seroconversion rates in a prospective study of HIV discordant couples in Lusaka, Zambia. Paper presented at: 2nd International AIDS Society Conference on HIV Pathogenesis and Treatment. July 2003. Paris. PMID: N/A.
Bunnell R, Ekwaru J, King R, Bechange S, Moore D, Khana K, et al. 3-year follow-up of sexual behavior and HIV transmission risk of persons taking art in rural Uganda. Paper presented at: 15th Conference on Retroviruses and Opportunistic Infections. February 2008. Boston. PMID: N/A.
Camoni L, Dal Conte I, Regine V, Colucci A, Chiriotto M, Vullo V, et al. Sexual behaviour reported by a sample of Italian MSM before and after HIV diagnosis. Ann Ist Super Sanita. 2011;47(2):214-9. [pmid: 21709392].
Cohen MS. Thomas Parran Award Lecture: transmission and prevention of transmission of HIV-1. Sex Transm Dis. 2006;33(6):338-41. [pmid: 16721328].
Cossarizza A, Moyle G. Antiretroviral nucleoside and nucleotide analogues and mitochondria. AIDS. 2004;18(2):137-51. [pmid: 15075530].
de Vincenzi I, Mertens T. Male circumcision: a role in HIV prevention?. AIDS. 1994;8(2):153. [pmid: 8043224].
del Rio C. Report from the 13th Retrovirus Conference: more on false-positive results in rapid HIV testing. AIDS Clin Care. 2006;18(4):39. [pmid: 16718885].
Des Jarlais DC, Padian N. Strategies for universalistic and targeted HIV prevention. J Acquir Immune Defic Syndr Hum Retrovirol. 1997;16(2):127-36. [pmid: 9358108].
Dewsnap CH, McOwan A. A review of HIV point-of-care tests. Int J STD AIDS. 2006;17(6):357-9. [pmid: 16734952].
Dhawan D, Mayer KH. Microbicides to prevent HIV transmission: overcoming obstacles to chemical barrier protection. J Infect Dis. 2006;193(1):36-44. [pmid: 16323129].
Dibosa-Osadolor O, Roberts T. Economic evaluation, human immunodeficiency virus infection and screening: a review and critical appraisal of economic studies. Int J Technol Assess Health Care. 2010;26(3):301-8. [pmid: 20584359].
Dosekun O, Fox J. An overview of the relative risks of different sexual behaviours on HIV transmission. Curr Opin HIV AIDS. 2010;5(4):291-7. [pmid: 20543603].
Eaton LA, Kalichman SC, O'Connell DA, Karchner WD. A strategy for selecting sexual partners believed to pose little/no risks for HIV: serosorting and its implications for HIV transmission. AIDS Care. 2009;21(10):1279-88. [pmid: 20024704].
Elford J, Hart G. HAART, viral load and sexual risk behaviour. AIDS. 2005;19(2):205-7. [pmid: 15668547].
Fink A. A possible explanation for heterosexual male infection with AIDS. N Engl J Med. 1986;315(18):1167. [pmid: 3762636].
Franco-Paredes C, Tellez I, del Rio C. Rapid HIV testing: a review of the literature and implications for the clinician. Curr HIV/AIDS Rep. 2006;3(4):169-75. [pmid: 17032576].
Galvan FH, Brooks RA, Leibowitz AA. Rapid HIV testing: issues in implementation. AIDS Patient Care STDs. 2004;18(1):15-8. [pmid: 15006190].
Ganczak M. HIV/AIDS education as a supportive tool for premarital HIV screening. J Infect Public Health. 2009;2(3):153-4. [pmid: 20701876].
Garland PM, Valverde EE, Fagan J, Beer L, Sanders C, Hillman D, et al. HIV counseling, testing and referral experiences of persons diagnosed with HIV who have never entered HIV medical care. AIDS Educ Prev. 2011;(3):117-27. [pmid: 21689042].
Gerbert B, Danley DW, Herzig K, Clanon K, Ciccarone D, Gilbert P, et al. Reframing “prevention with positives”: incorporating counseling techniques that improve the health of HIV-positive patients. AIDS Patient Care STDs. 2006;20(1):19-29. [pmid: 16426152].
Guinn D. HIV screening and false-positive results. JAMA. 2007;297(9):947. [pmid: 17341704].
Hankins C. From a vicious circle to a virtuous circle: reinforcing strategies of risk, vulnerability, and impact reduction for HIV prevention. Lancet. 2004;364(9449):1915-6. [pmid: 15566990].
Haukoos JS, Hopkins E, Byyny RL, Conroy AA, Silverman M, Eisert S, et al. Design and implementation of a controlled clinical trial to evaluate the effectiveness and efficiency of routine opt-out rapid human immunodeficiency virus screening in the emergency department. Acad Emerg Med. 2009;16(8):800-8. [pmid: 19673717].
Haukoos JS. Rethinking how we perform HIV testing in the emergency department. Ann Emerg Med. 2011;58(Suppl 1):S160-3. [pmid: 21684396].
Holstad MM, DiIorio C, Magowe MK. Motivating HIV positive women to adhere to antiretroviral therapy and risk reduction behavior: the KHARMA Project. Online J Issues Nurs. 2006;11(1):5. [pmid: 16629499].
Holtgrave D, McGuire J. Impact of counseling in voluntary counseling and testing programs for persons at risk for or living with HIV infection. Clin Infect Dis. 2007;45(4):15. [pmid: 18190293].
Howe BE, Clutterbuck D. Targeting of HIV pretest discussion and risk-reduction interventions in a low-prevalence setting. Int J STD AIDS. 2009;20(7):470-2. [pmid: 19541888].
Johnson BT, Carey MP, Chaudoir SR, Reid AE. Sexual risk reduction for persons living with HIV: research synthesis of randomized controlled trials, 1993 to 2004. J Acquir Immune Defic Syndr. 2006;41(5):642-50. [pmid: 16652039].
Johnson BT, Scott-Sheldon LA, Smoak ND, Lacroix JM, Anderson JR, Carey MP. Behavioral interventions for African Americans to reduce sexual risk of HIV: a meta-analysis of randomized controlled trials. J Acquir Immune Defic Syndr. 2009;51(4):492-501. [pmid: 19436218].
Johnson WD, Diaz RM, Flanders WD, Goodman M, Hill AN, Holtgrave D, et al. Behavioral interventions to reduce risk for sexual transmission of HIV among men who have sex with men. Cochrane Database Syst Rev. 2008;(3):CD001230. [pmid: 18646068].
Kalichman S, Carey M, Johnson B. Prevention of sexually transmitted HIV infection: a meta-analytic review of the behavioral outcome literature. Ann Behav Med. 1996;18(1):6-15. PMID: N/A.
Kayitenkore K, Bekan B, Rufagari J, Marion-Landais S, Karita E, Allen S, et al. The impact of art on HIV transmission among HIV serodiscordant couples. Paper presented at: XVI International AIDS Conference. August 2006. Toronto. PMID: N/A.
Kennedy C, O'Reilly K, Medley A, Sweat M. The impact of HIV treatment on risk behaviour in developing countries: a systematic review. AIDS Care. 2007;19(6):707-20. [pmid: 17573590].
Klitzman R, Exner T, Correale J, Kirshenbaum SB, Remien R, Ehrhardt AA, et al. It's not just what you say: relationships of HIV dislosure and risk reduction among MSM in the post-HAART era. AIDS Care. 2007;19(6):749-56. [pmid: 17573594].
Lalani T, Hicks C. Does antiretroviral therapy prevent HIV transmission to sexual partners?. Curr HIV/AIDS Rep. 2007;4(2):80-5. [pmid: 17547829].
Lazarus JV, Sihvonen-Riemenschneider H, Laukamm-Josten U, Wong F, Liljestrand J. Systematic review of interventions to prevent the spread of sexually transmitted infections, including HIV, among young people in Europe. Croat Med J. 2010;51(1):74-84. [pmid: 20162748].
Lundgren JD, Phillips AN, Neaton J. Uncertainty as to whether the use of antiretroviral therapy for persons recently infected with HIV has a favorable risk-to-benefit ratio. Clin Infect Dis. 2009;48(8):1162. [pmid: 19292638].
Lyles CM, Kay LS, Crepaz N, Herbst JH, Passin WF, Kim AS, et al. Best-evidence interventions: findings from a systematic review of HIV behavioral interventions for US populations at high risk, 2000-2004. Am J Public Health. 2007;97(1):133-43. [pmid: 17138920].
Mehendale SM, Kishore KB, Ghate MV, Sahay S, Gamble T, Godbole SV, et al. Low HIV incidence in HIV sero-discordant couples in Pune, India. J Acquir Immune Defic Syndr. 2006;41(3):371-3. [pmid: 16540940].
Munar DE. Funding and implementing routine testing for HIV. Clin Infect Dis. 2007;45(4):15. [pmid: 18190294].
Munderi P. When to start antiretroviral therapy in adults in low- and middle-income countries: science and practice. Curr Opin HIV/AIDS. 2010;5(1):6-11. [pmid: 20046142].
Naftalin CM, Poulton M. The significance of early HIV testing. Clin Med. 2009;9(1):91-2. [pmid: 19274818].
Neaton JD, Grund B. Earlier initiation of antiretroviral therapy in treatment-naive patients: implications of results of treatment interruption trials. Curr Opin HIV/AIDS. 2008;3(2):112-7. [pmid: 19372951].
Ota E, Wariki MV, Mori R, Hori N, Shibuya K. Behavioral interventions to reduce the transmission of HIV infection among sex workers and their clients in high-income countries. Cochrane Database Syst Rev. 2011;(12):CD006045. [pmid: 22161397].
Pedlow CT, Carey MP. HIV sexual risk-reduction interventions for youth: a review and methodological critique of randomized controlled trials. Behav Modif. 2003;27(2):135-90. [pmid: 12705104].
Remien RH, Berkman A, Myer L, Bastos FI, Kagee A, El-Sadr WM. Integrating HIV care and HIV prevention: legal, policy and programmatic recommendations. AIDS. 2008;22(Suppl 2):S57-65. [pmid: 18641470].
Reynolds S, Makumbi F, Kagaayi J, Nakigozi G, Galiwongo R. ART reduced the rate of sexual tranmission of HIV among HIV-discordant couples in rural Rakai, Uganda. Paper presented at: 16th Conference on Retroviruses and Opportunistic Infections. February 2009. Montreal. PMID: N/A.
Rueda S, Park-Wyllie LY, Bayoumi A, Tynan AM, Antoniou T, Rourke S, et al. Patient support and education for promoting adherence to highly active antiretroviral therapy for HIV/AIDS. Cochrane Database Syst Rev. 2006;(3):CD001442. [pmid: 16855968].
Siegfried N, Uthman OA, Rutherford GW. Optimal time for initiation of antiretroviral therapy in asymptomatic, HIV-infected, treatment-naive adults. Cochrane Database Syst Rev. 2010;(3):CD008272. [pmid: 20238364].
Simoni JM, Pantalone DW. Secrets and safety in the age of AIDS: does HIV disclosure lead to safer sex?. Topics HIV Med. 2004;12(4):109-18. [pmid: 15516708].
Stein R, Grimes TS, Malow R, Stratford D, Spielberg F, Holtgrave DR. Introduction to special supplement: monitoring and evaluation of HIV counseling, testing and referral (CTR) and HIV testing services. AIDS Educ Prev. 2011;23(3 Suppl):1-6. [pmid: 21689032].
Stolte G, Dukers NH, de Wit JB, Fennema H, Coutinho RA. A summary report from Amsterdam: increase in sexually transmitted diseases and risky sexual behaviour among homosexual men in relation to the introduction of new anti-HIV drugs. Euro Surveill. 2002;7(2):19-22. [pmid: 12631950].
Strathdee SA, Magis-Rodriguez C. Mexico's evolving HIV epidemic. JAMA. 2008;300(5):571-3. [pmid: 18677029].
Tipranavir favored in RESIST-2. AIDS Patient Care STDs. 2005;19(1):59. [pmid: 15700396].
Tolou-Shams M, Payne N, Houck C, Pugatch D, Beausoleil N, Brown LK, et al. HIV testing among at-risk adolescents and young adults: a prospective analysis of a community sample. J Adolesc Health Care. 2007;41(6):586-93. [pmid: 18023788].
Trotter AB, Bhayani N, Florsheim R, Novak RM. Implementing universal oral HIV screening in an urban emergency department: do demographic characteristics impact acceptance of testing?. Clin Infect Dis. 2010;50(2):283. [pmid: 20034354].
Truong HM, Klausner JD. Diagnostic assays for HIV-1 infection. MLO Med Lab Obs. 2004;36(7):12-3. [pmid: 15318787].
Valdiserri RO, Holtgrave DR, West GR. Promoting early HIV diagnosis and entry into care. AIDS. 1999;13(17):2317-30. [pmid: 10597773].
van Griensven F. Non-condom use risk-reduction behaviours: can they help to contain the spread of HIV infection among men who have sex with men?. AIDS. 2009;23(2):253-5. [pmid: 19098495].
Weiss HA, Thomas SL, Munabi SK, Hayes RJ. Male circumcision and risk of syphilis, chancroid, and genital herpes: a systematic review and meta-analysis. Sex Transm Infect. 2006;82(2):101-10. [pmid: 16581731].
Wilkin TJ, Gulick RM. Antiretroviral therapy: when and what to start—an American perspective. Curr HIV/AIDS Rep. 2004;1(2):59-67. [pmid: 16091224].
Zdeb MS. HIV screening and false-positive results. JAMA. 2007;297(9):947-8. [pmid: 17341703].
Zenilman JM. Behavioral interventions: rationale, measurement, and effectiveness. Infect Dis Clin North Am. 2005;19(2):541-62. [pmid: 15963887].

### Inadequate duration

Canestri A, Sow PS, Vray M, Ngom F, M'Boup S, Kane CT, et al. Poor efficacy and tolerability of stavudine, didanosine, and efavirenz-based regimen in treatment-naive patients in Senegal. MedGenMed. 2007;9(4):7. [pmid: 18311357].
Chu KM, Boulle AM, Ford N, Goemaere E, Asselman V, Van Cutsem G. Nevirapine-associated early hepatotoxicity: incidence, risk factors, and associated mortality in a primary care ART programme in South Africa. PLoS One. 2010;5(2):e9183. [pmid: 20174653].
Cohen CJ, Kubota M, Brachman PS, Harley WB, Schneider S, Williams VC, et al. Short-term safety and tolerability of a once-daily fixed-dose abacavir-lamivudine combination versus twice-daily dosing of abacavir and lamivudine as separate components: findings from the ALOHA study. Pharmacotherapy. 2008;28(3):314-22. [pmid: 18294111].
Johnson MA, Gathe JC, Podzamczer D, Molina JM, Naylor CT, Chiu YL, et al. A once-daily lopinavir/ritonavir-based regimen provides noninferior antiviral activity compared with a twice-daily regimen. J Acquir Immune Defic Syndr. 2006;43(2):153-60. [pmid: 16951643].
Landman R, Capitant C, Descamps D, Chazallon C, Peytavin G, Katlama C, et al. Efficacy and safety of ritonavir-boosted dual protease inhibitor therapy in antiretroviral-naive HIV-1-infected patients: the 2IP ANRS 127 study. J Antimicrob Chemother. 2009;64(1):118-25. [pmid: 19420019].
Malan DR, Krantz E, David N, Wirtz V, Hammond J, McGrath D, et al. Efficacy and safety of atazanavir, with or without ritonavir, as part of once-daily highly active antiretroviral therapy regimens in antiretroviral-naive patients. J Acquir Immune Defic Syndr. 2008;47(2):161-7. [pmid: 17971713].
Martin A, Bloch M, Amin J, Baker D, Cooper DA, Emery S, et al. Simplification of antiretroviral therapy with tenofovir-emtricitabine or abacavir-lamivudine: a randomized, 96-week trial. Clin Infect Dis. 2009;49(10):1591-601. [pmid: 19842973].
McComsey G, Rightmire A, Wirtz V, Yang R, Mathew M, McGrath D. Changes in body composition with ritonavir-boosted and unboosted atazanavir treatment in combination with lamivudine and stavudine: a 96-week randomized, controlled study. Clin Infect Dis. 2009;48(9):1323-6. [pmid: 19302017].
Miiro G, Todd J, Mpendo J, Watera C, Munderi P, Nakubulwa S, et al. Reduced morbidity and mortality in the first year after initiating highly active anti-retroviral therapy (HAART) among Ugandan adults. Trop Med Int Health. 2009;14(5):556-63. [pmid: 19320871].
Mitsuyasu R, Gelman R, Cherng DW, Landay A, Fahey J, Reichman R, et al. The virologic, immunologic, and clinical effects of interleukin 2 with potent antiretroviral therapy in patients with moderately advanced human immunodeficiency virus infection: a randomized controlled clinical trial—AIDS Clinical Trials Group 328. Arch Intern Med. 2007;167(6):597-605. [pmid: 17389292].
Molina JM, Andrade-Villanueva J, Echevarria J, Chetchotisakd P, Corral J, David N, et al. Once-daily atazanavir/ritonavir versus twice-daily lopinavir/ritonavir, each in combination with tenofovir and emtricitabine, for management of antiretroviral-naive HIV-1-infected patients: 48 week efficacy and safety results of the CASTLE study. Lancet. 2008;372(9639):646-55. [pmid: 18722869].
Molina JM, Andrade-Villanueva J, Echevarria J, Chetchotisakd P, Corral J, David N, et al. Once-daily atazanavir/ritonavir compared with twice-daily lopinavir/ritonavir, each in combination with tenofovir and emtricitabine, for management of antiretroviral-naive HIV-1-infected patients: 96-week efficacy and safety results of the CASTLE study. J Acquir Immune Defic Syndr. 2010;53(3):323-32. [pmid: 20032785].
Moyle GJ, DeJesus E, Cahn P, Castillo SA, Zhao H, Gordon DN, et al. Abacavir once or twice daily combined with once-daily lamivudine and efavirenz for the treatment of antiretroviral-naive HIV-infected adults: results of the Ziagen Once Daily in Antiretroviral Combination Study. J Acquir Immune Defic Syndr. 2005;38(4):417-25. [pmid: 15764958].
Olawumi HO, Olatunji PO, Salami AK, Odeigah L, Iseniyi JO. Effect of highly active antiretroviral therapy on CD4 count and weight in AIDS patients seen at the UITH, Ilorin. Niger J Clin Pract. 2008;11(4):312-5. [pmid: 19320401].
Orkin C, Stebbing J, Nelson M, Bower M, Johnson M, Mandalia S, et al. A randomized study comparing a three- and four-drug HAART regimen in first-line therapy (QUAD study). J Antimicrob Chemother. 2005;55(2):246-51. [pmid: 15608053].
Ortiz R, Dejesus E, Khanlou H, Voronin E, van Lunzen J, Andrade-Villanueva J, et al. Efficacy and safety of once-daily darunavir/ritonavir versus lopinavir/ritonavir in treatment-naive HIV-1-infected patients at week 48. AIDS. 2008;22(12):1389-97. [pmid: 18614861].
Palacios R, Hidalgo C, Rios MJ, Rivero A, Munoz L, Lozano F, et al. Effectiveness and safety of simplification from tenofovir-lamivudine (TDF-3TC) to tenofovir-emtricitabine (TDF-FTC) co-formulation (truvada) in virologically suppressed HIV-infected patients on HAART. Eur J Clin Microbiol Infect Dis. 2009;28(4):399-402. [pmid: 18841401].
Puls RL, Srasuebkul P, Petoumenos K, Boesecke C, Duncombe C, Belloso WH, et al. Efavirenz versus boosted atazanavir or zidovudine and abacavir in antiretroviral treatment-naive, HIV-infected subjects: week 48 data from the Altair study. Clin Infect Dis. 2010;51(7):855-64. [pmid: 20735258].
Puoti M, Cozzi-Lepri A, Paraninfo G, Arici C, Moller NF, Lundgren JD, et al. Impact of lamivudine on the risk of liver-related death in 2,041 HBsAg- and HIV-positive individuals: results from an inter-cohort analysis. Antivir Ther. 2006;11(5):567-74. [pmid: 16964824].
Ribera E, Rodriguez-Pardo D, Rubio M, Soler A, Pedrol E, Blanco JL, et al. Efficacy and safety of once-daily combination therapy with didanosine, lamivudine and nevirapine in antiretroviral-naive HIV-infected patients. Antivir Ther. 2005;10(5):605-14. [pmid: 16152754].
Ruane PJ, Richmond GJ, DeJesus E, Hill-Zabala CE, Danehower SC, Liao Q, et al. Pharmacodynamic effects of zidovudine 600 mg once/day versus 300 mg twice/day in therapy-naive patients infected with human immunodeficiency virus. Pharmacotherapy. 2004;24(3):307-12. [pmid: 15040643].
Saag MS, Cahn P, Raffi F, Wolff M, Pearce D, Molina JM, et al. Efficacy and safety of emtricitabine vs stavudine in combination therapy in antiretroviral-naive patients: a randomized trial. JAMA. 2004;292(2):180-9. [pmid: 15249567].
Schurmann D, Fatkenheuer G, Reynes J, Michelet C, Raffi F, van Lier J, et al. Antiviral activity, pharmacokinetics and safety of vicriviroc, an oral CCR5 antagonist, during 14-day monotherapy in HIV-infected adults. AIDS. 2007;21(10):1293-9. [pmid: 17545705].
Shikuma CM, Zackin R, Sattler F, Mildvan D, Nyangweso P, Alston B, et al. Changes in weight and lean body mass during highly active antiretroviral therapy. Clin Infect Dis. 2004;39(8):1223-30. [pmid: 15486848].
van Vonderen MG, Lips P, van Agtmael MA, Hassink EA, Brinkman K, Geerlings SE, et al. First line zidovudine/lamivudine/lopinavir/ritonavir leads to greater bone loss compared to nevirapine/lopinavir/ritonavir. AIDS. 2009;23(11):1367-76. [pmid: 19424051].

### Sample size too small

Couzigou C, Semaille C, Le Strat Y, Pinget R, Pillonel J, Lot F, et al. Differential improvement in survival among patients with AIDS after the introduction of HAART. AIDS Care. 2007;19(4):523-31. [pmid: 17453593].
INITIO Trial International Coordinating Committee, Yeni P, Cooper DA, Aboulker JP, Babiker AG, Carey D, et al. Virological and immunological outcomes at 3 years after starting antiretroviral therapy with regimens containing non-nucleoside reverse transcriptase inhibitor, protease inhibitor, or both in INITIO: open-label randomised trial. Lancet. 2006;368(9532):287-98. [pmid: 16860698].
Jaen A, Esteve A, Miro JM, Tural C, Montoliu A, Ferrer E, et al. Determinants of HIV progression and assessment of the optimal time to initiate highly active antiretroviral therapy: PISCIS Cohort (Spain). J Acquir Immune Defic Syndr. 2008;47(2):212-20. [pmid: 18297762].
Shepherd BE, Jenkins CA, Rebeiro PF, Stinnette SE, Bebawy SS, McGowan CC, et al. Estimating the optimal CD4 count for HIV-infected persons to start antiretroviral therapy. Epidemiology. 2010;21(5):698-705. [pmid: 20585252].

## Appendix A5 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized Controlled Trials (RCTs) and Cohort Studies

Criteria
- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of ratings based on above criteria

Good: | Meets all criteria: comparable groups are assembled initially and maintained throughout the study (followup at least 80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following major limitations exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Source: Harris et al, 2001^66^

## Appendix A6 Criteria for Assessing Scientific Quality of Research Reviews

Each criterion was given an assessment of yes, no, unclear, or not applicable:

1. Was an a priori design provided? The research question and inclusion criteria should be established before the conduct of the review.
2. Was there duplicate study selection and data extraction? There should be at least two independent data extractors and a consensus procedure for disagreements should be in place.
3. Was a comprehensive literature search performed? At least two electronic sources should be searched. The report must include years and databases used (e.g., Central, EMBASE, and MEDLINE). Key words and/or MESH terms must be stated and, where feasible, the search strategy should be provided. All searches should be supplemented by consulting current contents, reviews, textbooks, specialized registers, or experts in the particular field of study, and by reviewing the references in the studies found.
4. Was the status of publication (i.e., gray literature) used as an inclusion criterion? The authors should state that they searched for reports regardless of their publication type. The authors should state whether or not they excluded any reports (from the systematic review), based on their publication status, language, etc.
5. Was a list of studies (included and excluded) provided? A list of included and excluded studies should be provided.
6. Were the characteristics of the included studies provided? In an aggregated form, such as a table, data from the original studies should be provided on the participants, interventions, and outcomes. The ranges of characteristics in the studies analyzed, such as age, race, sex, relevant socioeconomic data, disease status, duration, severity, or other diseases, should be reported.
7. Was the scientific quality of the included studies assessed and documented? A priori methods of assessment should be provided (e.g., for effectiveness studies if the authors chose to include only randomized, double-blind, placebo controlled studies, or allocation concealment as inclusion criteria); for other types of studies, alternative items will be relevant.
8. Was the scientific quality of the included studies used appropriately in formulating conclusions? The results of the methodological rigor and scientific quality should be considered in the analysis and the conclusions of the review, and explicitly stated in formulating the recommendations.
9. Were the methods used to combine the findings of studies appropriate? Reviews should not combine or pool dissimilar studies. If studies are pooled using a fixed effects model, there should be a clear rationale for doing so. A test should be done to assess for statistical heterogeneity (i.e., chi-square test for homogeneity, I^2^).
10. Was the likelihood of publication bias assessed? An assessment of publication bias should include a combination of graphical aids (e.g., funnel plot, other available tests) and/or statistical tests (e.g., Egger regression test). If assessment of publication bias is not possible, the review should provide justification (e.g., small numbers of studies, too much heterogeneity, poor quality).
11. Was the conflict of interest stated? Potential sources of support should be clearly acknowledged in both the systematic review and the included studies.

Definition of ratings based on above criteria:

Good: Recent, comprehensive review that uses explicit criteria to identify and select studies for inclusion, uses appropriate methods to assess quality of primary studies appropriately, and uses appropriate methods for synthesizing or combining results.

Fair: Systematic methods for identifying studies but does not meet one or more of the criteria listed above.

Poor: No systematic methods for identifying studies, major selection bias, or inappropriate methods for combining or pooling data.

Source: Harris et al, 2001^66^

## Appendix A7 Expert Reviewers of the Draft Report

Bernie Branson, MD

Medical Epidemiologist

Division of HIV/AIDS Prevention

Centers for Disease Control and Prevention

Grant Colfax, MD

Director of HIV Prevention and Research

San Francisco Department of Public Health

Timothy Dondero, MD

Division of HIV/AIDS Prevention

Centers for Disease Control and Prevention

Linda Kinsinger, MD, MPH

Chief Consultant for Preventive Medicine

Office of Patient Care Services

Veterans Health Administration, National Center for Health Promotion and Disease Prevention

Lisa Metsch, PhD

Professor of Epidemiology and Public Health, Director of Division of Health Services Research and Policy

University of Miami