# References

1 Leipzig RM, Whitlock EP, Wolff TA, Barton MB, Michael YL, Harris R, et al. U.S. Preventive Services Task Force Geriatric Workgroup. Reconsidering the approach to prevention recommendations for older adults. Ann Intern Med. 2010;153(12):809-14. [pmid: 21173415].
2 Rubenstein LZ, Stuck AE, Siu AL, Wieland D. Impacts of geriatric evaluation and management programs on defined outcomes: overview of the evidence. J Am Geriatr Soc. 1991;39(9 Pt 2):8S-16S. [pmid: 1832179].
3 Michael YL, Whitlock EP, Lin JS, Fu R, O’Connor EA, Gold R. Primary care-relevant interventions to prevent falling in older adults: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2010;153(12):815-25. [pmid: 21173416].
4 Beswick AD, Rees K, Dieppe P, Ayis S, Gooberman-Hill R, Horwood J, et al. Complex interventions to improve physical function and maintain independent living in elderly people: a systematic review and meta-analysis. Lancet. 2008;371(9614):725-35. [pmid: 18313501].
5 Bouman A, van Rossum E, Ambergen T, Kempen G, Knipschild P. Effects of a home visiting program for older people with poor health status: a randomized, clinical trial in the Netherlands. J Am Geriatr Soc. 2008;56(3):397-404. [pmid: 18179482].
6 Gates S, Fisher JD, Cooke MW, Carter YH, Lamb SE. Multifactorial assessment and targeted intervention for preventing falls and injuries among older people in community and emergency care settings: systematic review and meta-analysis. BMJ. 2008;336(7636):130-33. [pmid: 18089892].
7 Huss A, Stuck AE, Rubenstein LZ, Egger M, Clough-Gorr KM. Multidimensional preventive home visit programs for community-dwelling older adults: a systematic review and meta-analysis of randomized controlled trials. J Gerontol A Biol Sci Med Sci. 2008;63(3):298-307. [pmid: 18375879].
8 Stuck AE, Siu AL, Wieland GD, Adams J, Rubenstein LZ. Comprehensive geriatric assessment: a meta-analysis of controlled trials. Lancet. 1993;342(8878):1032-36. [pmid: 8105269].
9 Harris R, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Methods Work Group, Third U.S. Preventive Services Task Force. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
10 Liu GF, Lu K, Mogg R, Mallick M, Mehrotra DV. Should baseline be a covariate or dependent variable in analyses of change from baseline in clinical trials?. Stat Med. 2009;28(20):2509-30. [pmid: 19610129].
11 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
12 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
13 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. 2005;58(9):894-901. [pmid: 16085192].
14 Stuck AE, Aronow HU, Steiner A, Alessi CA, Büla CJ, Gold MN, et al. A trial of annual in-home comprehensive geriatric assessments for elderly people living in the community. N Engl J Med. 1995;333(18):1184-89. [pmid: 7565974].
15 Wallace JI, Buchner DM, Grothaus L, Leveille S, Tyll L, LaCroix AZ, et al. Implementation and effectiveness of a community-based health promotion program for older adults. J Gerontol A Biol Sci Med Sci. 1998;53(4):M301-6. [pmid: 18314570].
16 Shumway-Cook A, Silver IF, LeMier M, York S, Cummings P, Koepsell TD. Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. J Gerontol A Biol Sci Med Sci. 2007;62(12):1420-27. [pmid: 18166695].
17 Dyer CA, Taylor GJ, Reed M, Dyer CA, Robertson DR, Harrington R. Falls prevention in residential care homes: a randomised controlled trial. Age Ageing. 2004;33(6):596-602. [pmid: 15381507].
18 Byles JE, Tavener M, O’Connell RL, Nair BR, Higginbotham NH, Jackson CL, et al. Randomised controlled trial of health assessments for older Australian veterans and war widows. Med J Aust. 2004;181(4):186-90. [pmid: 15310251].
19 Hendriksen C, Lund E, Strømgård E. Consequences of assessment and intervention among elderly people: a three year randomised controlled trial. Br Med J (Clin Res Ed). 1984;289(6457):1522-24.
20 Newbury JW, Marley JE, Beilby JJ. A randomised controlled trial of the outcome of health assessment of people aged 75 years and over. Med J Aust. 2001;175(2):104-07. [pmid: 11556409].
21 Sahlen KG, Dahlgren L, Hellner BM, Stenlund H, Lindholm L. Preventive home visits postpone mortality—a controlled trial with time-limited results. BMC Public Health. 2006;6:220. [pmid: 16945128].
22 Harari D, Iliffe S, Kharicha K, Egger M, Gillmann G, von Renteln-Kruse W, et al. Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing. 2008;37(5):565-71. [pmid: 18755784].
23 Peri K, Kerse N, Robinson E, Parsons M, Parsons J, Latham N. Does functionally based activity make a difference to health status and mobility? A randomised controlled trial in residential care facilities (The Promoting Independent Living Study; PILS). Age Ageing. 2008;37(1):57-63. [pmid: 17965045].
24 Carpenter GI, Demopoulos GR. Screening the elderly in the community: controlled trial of dependency surveillance using a questionnaire administered by volunteers. BMJ. 1990;300(6734):1253-56. [pmid: 2354297].
25 Vetter NJ, Jones DA, Victor CR. Effect of health visitors working with elderly patients in general practice: a randomised controlled trial. Br Med J (Clin Res Ed). 1984;288(6414):369-72.
26 van Rossum E, Frederiks CM, Philipsen H, Portengen K, Wiskerke J, Knipschild P. Effects of preventive home visits to elderly people. BMJ. 1993;307(6895):27-32. [pmid: 8343668].
27 Stuck AE, Minder CE, Peter-Wüest I, Gillmann G, Egli C, Kesselring A, et al. A randomized trial of in-home visits for disability prevention in community-dwelling older people at low and high risk for nursing home admission. Arch Intern Med. 2000;160(7):977-86. [pmid: 10761963].
28 Chi I, Chou KL, Kwan CW, Lam EK, Lam TP. Use of the Minimum Data Set-Home Care: a cluster randomized controlled trial among the Chinese older adults. Aging Ment Health. 2006;10(1):33-39. [pmid: 16338812].
29 Richardson J, Chan D, Risdon K, Giles C, Mulveney S, Cripps D. Does monitoring change in function in community-dwelling older adults alter outcome? A randomized controlled trial. Clin Rehabil. 2008;22(12):1061-70. [pmid: 19052245].
30 Epstein AM, Hall JA, Fretwell M, Feldstein M, DeCiantis ML, Tognetti J, et al. Consultative geriatric assessment for ambulatory patients: a randomized trial in a health maintenance organization. JAMA. 1990;263(4):538-44. [pmid: 2294326].
31 Gill TM, Baker DI, Gottschalk M, Peduzzi PN, Allore H, Byers A. A program to prevent functional decline in physically frail, elderly persons who live at home. N Engl J Med. 2002;347(14):1068-74. [pmid: 12362007].
32 van Haastregt JC, Diederiks JP, van Rossum E, de Witte LP, Voorhoeve PM, Crebolder HF. Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321(7267):994-98. [pmid: 11039967].
33 Burns R, Nichols LO, Martindale-Adams J, Graney MJ. Interdisciplinary geriatric primary care evaluation and management: two-year outcomes. J Am Geriatr Soc. 2000;48(1):8-13. [pmid: 10642014].
34 Cohen HJ, Feussner JR, Weinberger M, Carnes M, Hamdy RC, Hsieh F, et al. A controlled trial of inpatient and outpatient geriatric evaluation and management. N Engl J Med. 2002;346(12):905-12. [pmid: 11907291].
35 Dalby DM, Sellors JW, Fraser FD, Fraser C, van Ineveld C, Howard M. Effect of preventive home visits by a nurse on the outcomes of frail elderly people in the community: a randomized controlled trial. CMAJ. 2000;162(4):497-500. [pmid: 10701382].
36 Caplan GA, Williams AJ, Daly B, Abraham K. A randomized, controlled trial of comprehensive geriatric assessment and multidisciplinary intervention after discharge of elderly from the emergency department—the DEED II study. J Am Geriatr Soc. 2004;52(9):1417-23. [pmid: 15341540].
37 Gagnon AJ, Schein C, McVey L, Bergman H. Randomized controlled trial of nurse case management of frail older people. J Am Geriatr Soc. 1999;47(9):1118-24. [pmid: 10484257].
38 Mahoney JE, Shea TA, Przybelski R, Jaros L, Gangnon R, Cech S, et al. Kenosha County falls prevention study: a randomized, controlled trial of an intermediate-intensity, community-based multifactorial falls intervention. J Am Geriatr Soc. 2007;55(4):489-98. [pmid: 17397425].
39 Tinetti ME, Baker DI, McAvay G, Claus EB, Garrett P, Gottschalk M, et al. A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331(13):821-27. [pmid: 8078528].
40 Close J, Ellis M, Hooper R, Glucksman E, Jackson S, Swift C. Prevention of Falls in the Elderly Trial (PROFET): a randomised controlled trial. Lancet. 1999;353(9147):93-7. [pmid: 10023893].
41 Davison J, Bond J, Dawson P, Steen IN, Kenny RA. Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention—a randomised controlled trial. Age Ageing. 2005;34(2):162-68. [pmid: 15716246].
42 Elley CR, Robertson MC, Garrett S, Kerse NM, McKinlay E, Lawton B, et al. Effectiveness of a falls-and-fracture nurse coordinator to reduce falls: a randomized, controlled trial of at-risk older adults. J Am Geriatr Soc. 2008;56(8):1383-89. [pmid: 18808597].
43 Gallagher EM. Head over heels: impact of a health promotion program to reduce falls in the elderly. Can J Aging. 1996;15:84-96.
44 Hendriks MR, Bleijlevens MH, van Haastregt JC, Crebolder HF, Diederiks JP, Evers SM, et al. Lack of effectiveness of a multidisciplinary fall-prevention program in elderly people at risk: a randomized, controlled trial. J Am Geriatr Soc. 2008;56(8):1390-7. [pmid: 18662214].
45 Hogan DB, MacDonald FA, Betts J, Bricker S, Ebly EM, Delarue B, et al. A randomized controlled trial of a community-based consultation service to prevent falls. CMAJ. 2001;165(5):537-43. [pmid: 11563205].
46 Lightbody E, Watkins C, Leathley M, Sharma A, Lye M. Evaluation of a nurse-led falls prevention programme versus usual care: a randomized controlled trial. Age Ageing. 2002;31(3):203-10. [pmid: 12006310].
47 Lord SR, Tiedemann A, Chapman K, Munro B, Murray SM, Sherrington C. The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(8):1296-304. [pmid: 16078954].
48 Langhammer B, Lindmark B, Stanghelle JK. Living with stroke: exercising for life—7th World Congress on Aging and Physical Activity. J Aging Phys Act. 2008;16:S80.
49 Vaapio S, Salminen M, Vahlberg T, Sjösten N, Isoaho R, Aarnio P, et al. Effects of risk-based multifactorial fall prevention on health-related quality of life among the community-dwelling aged: a randomized controlled trial. Health Qual Life Outcomes. 2007;5:20. [pmid: 17462083].
50 Vind AB, Andersen HE, Pedersen KD, Joergensen T, Schwarz P. The effect of a program of multifactorial fall prevention on health related quality of life, functional ability, fear of falling and psychological well-being: a randomized controlled trial. Aging Clin Exp Res. 2009;22(3):249-54. [pmid: 19934621].
51 Logan PA, Coupland CA, Gladman JR, Sahota O, Stoner-Hobbs V, Robertson K, et al. Community falls prevention for people who call an emergency ambulance after a fall: randomised controlled trial. BMJ. 2010;340:c2102. [pmid: 20460331].
52 Boult C, Boult LB, Morishita L, Dowd B, Kane RL, Urdangarin CF. A randomized clinical trial of outpatient geriatric evaluation and management. J Am Geriatr Soc. 2001;49(4):351-9. [pmid: 11347776].
53 Coleman EA, Grothaus LC, Sandhu N, Wagner EH. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc. 1999;47(7):775-83. [pmid: 10404919].
54 Reuben DB, Frank JC, Hirsch SH, McGuigan KA, Maly RC. A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations. J Am Geriatr Soc. 1999;47(3):269-76. [pmid: 10078887].
55 Leveille SG, Wagner EH, Davis C, Grothaus L, Wallace J, LoGerfo M, et al. Preventing disability and managing chronic illness in frail older adults: a randomized trial of a community-based partnership with primary care. J Am Geriatr Soc. 1998;46(10):1191-8. [pmid: 9777899].
56 Sommers LS, Marton KI, Barbaccia JC, Randolph J. Physician, nurse, and social worker collaboration in primary care for chronically ill seniors. Arch Intern Med. 2000;160(12):1825-33. [pmid: 10871977].
57 Yamada Y, Ikegami N. Preventive home visits for community-dwelling frail elderly people based on Minimum Data Set-Home Care: randomized controlled trial. Geriatr Gerontol Int. 2003;3:236-42.
58 Hébert R, Robichaud L, Roy PM, Bravo G, Voyer L. Efficacy of a nurse-led multidimensional preventive programme for older people at risk of functional decline: a randomized controlled trial. Age Ageing. 2001;30(2):147-53. [pmid: 11395345].
59 Ploeg J, Brazil K, Hutchison B, Kaczorowski J, Dalby DM, Goldsmith CH, et al. Effect of preventive primary care outreach on health related quality of life among older adults at risk of functional decline: randomised controlled trial. BMJ. 2010;340:c1480. [pmid: 20400483].
60 Toseland RW, O’Donnell JC, Engelhardt JB, Hendler SA, Richie JT, Jue D. Outpatient geriatric evaluation and management: results of a randomized trial. Med Care. 1996;34(6):624-40. [pmid: 8656727].
61 Alkema GE, Wilber KH, Shannon GR, Allen D. Reduced mortality: the unexpected impact of a telephone-based care management intervention for older adults in managed care. Health Serv Res. 2007;42(4):1632-50. [pmid: 17610441].
62 Counsell SR, Callahan CM, Clark DO, Tu W, Buttar AB, Stump TE, et al. Geriatric care management for low-income seniors: a randomized controlled trial. JAMA. 2007;298(22):2623-33. [pmid: 18073358].
63 Thomas R, Worrall G, Elgar F, Knight J. Can they keep going on their own? A four-year randomized trial of functional assessments of community residents. Can J Aging. 2007;26(4):379-90. [pmid: 18669005].
64 Kono A, Kai I, Sakato C, Harker JO, Rubenstein LZ. Effect of preventive home visits for ambulatory housebound elders in Japan: a pilot study. Aging Clin Exp Res. 2004;16(4):293-9. [pmid: 15575123].
65 Holland SK, Greenberg J, Tidwell L, Malone J, Mullan J, Newcomer R. Community-based health coaching, exercise, and health service utilization. J Aging Health. 2005;17(6):697-716. [pmid: 16377768].
66 Bernabei R, Landi F, Gambassi G, Sgadari A, Zuccala G, Mor V, et al. Randomised trial of impact of model of integrated care and case management for older people living in the community. BMJ. 1998;316(7141):1348-51. [pmid: 9563983].
67 Melis RJ, van Eijken MI, Teerenstra S, van Achterberg T, Parker SG, Borm GF, et al. A randomized study of a multidisciplinary program to intervene on geriatric syndromes in vulnerable older people who live at home (Dutch EASY care Study). J Gerontol A Biol Sci Med Sci. 2008;63(3):283-90. [pmid: 18375877].
68 Schrijnemaekers VJ, Haveman MJ. Effects of preventive outpatient geriatric assessment: short-term results of a randomized controlled study. Home Health Care Serv Q. 1995;15(2):81-97. [pmid: 10143898].
69 Rockwood K, Stadnyk K, Carver D, MacPherson KM, Beanlands HE, Powell C, et al. A clinimetric evaluation of specialized geriatric care for rural dwelling, frail older people. J Am Geriatr Soc. 2000;48(9):1080-5. [pmid: 10983907].
70 Li CM, Chen CY, Li CY, Wang WD, Wu SC. The effectiveness of a comprehensive geriatric assessment intervention program for frailty in community-dwelling older people: a randomized, controlled trial. Arch Gerontol Geriatr. 2010;50(Suppl 1):S39-42. [pmid: 20171455].
71 van Hout HP, Jansen AP, van Marwijk HW, Pronk M, Frijters DF, Nijpels G. Prevention of adverse health trajectories in a vulnerable elderly population through nurse home visits: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2010;65(7):734-42. [pmid: 20457579].
72 Lam LC, Lee JS, Chung JC, Lau A, Woo J, Kwok TC. A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. 2010;25(4):395-402. [pmid: 19606455].
73 Silverman M, Musa D, Martin DC, Lave JR, Adams J, Ricci EM. Evaluation of outpatient geriatric assessment: a randomized multi-site trial. J Am Geriatr Soc. 1995;43(7):733-40. [pmid: 7602022].
74 Hogg W, Lemelin J, Dahrouge S, Liddy C, Armstrong CD, Legault F, et al. Randomized controlled trial of anticipatory and preventive multidisciplinary team care: for complex patients in a community-based primary care setting. Can Fam Physician. 2009;55(12):e76-85. [pmid: 20008582].
75 Elkan R, Kendrick D, Dewey M, Hewitt M, Robinson J, Blair M, et al. Effectiveness of home based support for older people: systematic review and meta-analysis. BMJ. 2001;323(7315):719-25. [pmid: 11576978].
76 Stuck AE, Egger M, Hammer A, Minder CE, Beck JC. Home visits to prevent nursing home admission and functional decline in elderly people: systematic review and meta-regression analysis. JAMA. 2002;287(8):1022-8. [pmid: 11866651].
77 Bouman A, van RE, Nelemans P, et al. Effects of intensive home visiting programs for older people with poor health status: A systematic review. BMC Health Services Research. 2008;8:74. [pmid: 18387184].
78 Markle-Reid M, Browne G, Weir R, Gafni A, Roberts J, Henderson SR. The effectiveness and efficiency of home-based nursing health promotion for older people: a review of the literature. Med Care Res Rev. 2006;63(5):531-69. [pmid: 16954307].
79 Ploeg J, Feightner J, Hutchison B, Patterson C, Sigouin C, Gauld M. Effectiveness of preventive primary care outreach interventions aimed at older people: meta-analysis of randomized controlled trials. Can Fam Physician. 2005;51:1244-5. [pmid: 16926937].
80 Byles JE. A thorough going over: evidence for health assessments for older persons. Aust N Z J Public Health. 2000;24(2):117-23. [pmid: 10790930].
81 Reuben DB, Valle LA, Hays RD, Siu AL. Measuring physical function in community-dwelling older persons: a comparison of self-administered, interviewer-administered, and performance-based measures. J Am Geriatr Soc. 1995;43(1):17-23. [pmid: 7806733].
82 Rothwell PM. Treating individuals, 2: subgroup analysis in randomised controlled trials: importance, indications, and interpretation. Lancet. 2005;365(9454):176-86. [pmid: 15639301].
83 Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd ed. Hillsdale, NJ. L. Erlbaum Associates. 1988.
84 Guyatt GH, Osoba D, Wu AW, Wyrwich KW, Norman GR. Clinical Significance Consensus Meeting Group. Methods to explain the clinical significance of health status measures. Mayo Clin Proc. 2002;77(4):371-83. [pmid: 11936935].
85 Johnston BC, Thorlund K, Schünemann HJ, Xie F, Murad MH, Montori VM, et al. Improving the interpretation of quality of life evidence in meta-analyses: the application of minimal important difference units. Health Qual Life Outcomes. 2010;8:116. [pmid: 20937092].
86 Hsieh YW, Wang CH, Wu SC, Chen PC, Sheu CF, Hsieh CL. Establishing the minimal clinically important difference of the Barthel Index in stroke patients. Neurorehabil Neural Repair. 2007;21(3):233-8. [pmid: 17351082].
87 Bowling A. Measuring Disease: A Review of Disease-Specific Quality of Life Measurement Scales. 2nd ed. Philadelphia. Open University Press. 2001.
88 Balu S. Differences in psychometric properties, cut-off scores, and outcomes between the Barthel Index and Modified Rankin Scale in pharmacotherapy-based stroke trials: systematic literature review. Curr Med Res Opin. 2009;25(6):1329-41. [pmid: 19419341].
89 Wellwood I, Dennis MS, Warlow CP. A comparison of the Barthel Index and the OPCS disability instrument used to measure outcome after acute stroke. Age Ageing. 1995;24(1):54-7. [pmid: 7762463].
90 Sikkes SA, de Lange-de Klerk ES, Pijnenburg YA, Scheltens P, Uitdehaag BM. A systematic review of instrumental activities of daily living scales in dementia: room for improvement. J Neurol Neurosurg Psychiatry. 2009;80(1):7-12. [pmid: 19091706].
91 Kravitz RL, Duan N, Braslow J. Evidence-based medicine, heterogeneity of treatment effects, and the trouble with averages. Milbank Q. 2004;82(4):661-87. [pmid: 15595946].
92 Reuben DB. Medical care for the final years of life: “When you’re 83, it’s not going to be 20 years”. JAMA. 2009;302(24):2686-94. [pmid: 20040557].
93 Liang J, Xu X, Bennett JM, Ye W, Quiñones AR. Ethnicity and changing functional health in middle and late life: a person-centered approach. J Gerontol B Psychol Sci Soc Sci. 2009;65(4):470-81. [pmid: 20008483].
94 Gill TM, Gahbauer EA, Han L, Allore HG. Trajectories of disability in the last year of life. N Engl J Med. 2010;362(13):1173-80. [pmid: 20357280].
95 Hardy SE, Gill TM. Recovery from disability among community-dwelling older persons. JAMA. 2004;291(13):1596-602. [pmid: 15069047].
96 Des Jarlais DC, Lyles C, Crepaz N. TREND Group. Improving the reporting quality of nonrandomized evaluations of behavioral and public health interventions: the TREND statement. Am J Public Health. 2004;94(3):361-6. [pmid: 14998794].
97 Schulz KF, Altman DG, Moher D. CONSORT Group. CONSORT 2010 statement: updated guidelines for reporting parallel group randomized trials. Ann Intern Med. 2010;152(11):726-32. [pmid: 20335313].
98 Buurman BM, van Munster BC, Korevaar JC, de Haan RJ, de Rooij SE. Variability in measuring (instrumental) activities of daily living functioning and functional decline in hospitalized older medical patients: a systematic review. J Clin Epidemiol. 2011;64(6):619-27. [pmid: 21074969].
99 Ferrucci L, Guralnik JM, Studenski S, Fried LP, Cutler GB Jr, Walston JD. Interventions on Frailty Working Group. Designing randomized, controlled trials aimed at preventing or delaying functional decline and disability in frail, older persons: a consensus report. J Am Geriatr Soc. 2004;52(4):625-34. [pmid: 15066083].
100 Studenski S, Perera S, Patel K, Rosano C, Faulkner K, Inzitari M, et al. Gait speed and survival in older adults. JAMA. 2011;305(1):50-8. [pmid: 21205966].