# Introduction

The U.S. Preventive Services Task Force (USPSTF) has been working to improve its methods and processes for the preventive needs of older adults.1 Traditional methods for systematic reviews and evidence-based recommendations for prevention of cancer or chronic disease may fall short in addressing many geriatric conditions. This deficit is because of these conditions’ multifactorial risk factors and/or broad interventions aimed at improving multiple related health outcomes. The multidimensional nature of geriatric care presents unique challenges to thoughtfully interpreting the evidence base for many geriatric topics.

Clinical care and research in older adults have, in part, reflected this multidimensional nature by developing comprehensive geriatric assessments—a multidisciplinary diagnostic process intended to determine an older adult’s medical, psychosocial, and functional abilities/limitations in order to develop an overall plan for management.2 Over the past two decades, there has been a large body of international research evaluating different interventions that incorporate both inpatient and outpatient geriatric assessment approaches aimed at improving various health, quality of life, and clinical care outcomes.

In 2010, the USPSTF posted for public comment a draft recommendation statement based on a commissioned systematic review that found that exercise and physical therapy interventions and vitamin D supplementation reduced falling in community-dwelling older adults.3 However, other interventions (notably, multifactorial assessment and management interventions) did not appear to reduce risk for falling. Because this previous review focused on interventions whose primary aim was to prevent falls, the USPSTF commissioned a second review to more broadly address the net benefit of these types of assessment and management interventions in older adults. This second review presented the opportunity to test methods around evidence synthesis and evidence-based recommendations for highly related bodies of evidence (i.e., multifactorial interventions to prevent falls and/or functional decline), as well as methods for reviewing complex interventions and multiple interrelated health outcomes. This review was designed to answer two key questions: 1) Can outpatient multifactorial assessment and management interventions improve health-related quality of life (HRQL) or reduce hospitalization, institutionalization, disability, or mortality in community-dwelling older adults? and 2) What are the adverse effects associated with these multifactorial assessment and management interventions? This report briefly summarizes our review findings and focuses on the methodological challenges we encountered and methods we used in study design, reporting, and analysis.

## Summary of Review Methods

Detailed methods are available in Appendix A, including a description of all data manipulation and meta-analyses.

We used existing systematic reviews3–8 and database searches through June 3, 2010, to identify included trials. Two investigators independently reviewed all abstracts and articles against a priori inclusion criteria (Appendix A). We included only fair- to good-quality randomized, controlled trials (RCTs) conducted in community-dwelling older adults (age 65 years or older) that evaluated outpatient multifactorial assessment and management interventions (a clinical assessment of two or more domains of function, generally supplemented by assessment of disability-related or geriatric risk factors, in which assessment results were used as a basis for management). Two independent investigators assessed studies against the USPSTF design-specific quality criteria to assign quality ratings (Appendix A).9 Discrepancies were resolved by consultation with a third investigator.

We reviewed a total of 5,553 abstracts and 208 articles, and ultimately included 70 fair- to good-quality RCTs (Figure 1). Included trial details are available in Appendix B Tables 1 and 2. Excluded trials are available in Appendix C. A priori primary outcomes included functional status, falls, hospitalizations, institutionalizations, HRQL, and mortality.

Figure 1 Search Results and Article Flow

Abbreviations: ADL=activities of daily living; IADL=instrumental activities of daily living; QOL=quality of life.

Figure 1 displays the literature search results and article flow for the review. A total of 8948 articles were identified through database searching and 245 articles were identified through other searching. 5554 articles were screened after duplicates were removed. 209 full-text articles were assessed for eligibility. 70 trials (published in 94 articles) were included in the qualitative synthesis of effectiveness and 59 trials (published in 79 articles) were included in the quantitative synthesis of effectiveness. This figure is described in the text as follows: “We reviewed a total of 5554 abstracts and 209 articles, and ultimately included 70 fair- to good-quality randomized controlled trials.”

We conducted both qualitative and quantitative syntheses of results. A detailed description of data syntheses is available in Appendix A. For continuous activities of daily living (ADL) and instrumental activities of daily living (IADL) outcomes, we pooled mean differences (using standardized mean difference [SMD] [Hedges’ g statistic]) between intervention and control groups in changes from baseline to followup scores.10 For binary outcomes (e.g., falls, hospitalizations, institutionalizations, and mortality), the number of events and total sample size for intervention and control groups were combined using risk ratios (RRs). All outcomes were combined using a random effects model,11 except for institutionalizations, for which we used a fixed effects model because between-study heterogeneity was estimated to be zero. We assessed the presence of statistical heterogeneity among the trials using standard chi-square tests and the magnitude of heterogeneity was estimated using the I^2^ statistic. Tests of publication bias were performed using funnel plots and Egger’s linear regression method.12,13 All analyses were performed using Stata 10.0 (StataCorp, College Station, TX).

The investigators worked closely with the USPSTF leads for this topic at key points throughout the review to resolve issues around scope and for detailed input during the data analysis phase. A draft of the systematic review was also externally reviewed by three experts before review findings were presented to the full USPSTF. The Agency for Healthcare Research and Quality (AHRQ) funded this research under a contract to support the work of the USPSTF. AHRQ staff provided oversight throughout the project.