# Appendix References

1 Michael YL, Whitlock EP, Lin JS, et al. Primary care-relevant interventions to prevent falling in older adults: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2010;153(12):815-25. [pmid: 21173416].
2 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148:776-82. [pmid: 18490690].
3 Beswick AD, Rees K, Dieppe P, et al. Complex interventions to improve physical function and maintain independent living in elderly people: a systematic review and meta-analysis. Lancet. 2008;371(9614):725-35. [pmid: 18313501].
4 Bouman A, van Rossum E, Ambergen T, et al. Effects of a home visiting program for older people with poor health status: a randomized, clinical trial in the Netherlands. J Am Geriatr Soc. 2008;56(3):397-404. [pmid: 18179482].
5 Gates S, Fisher JD, Cooke MW, et al. Multifactorial assessment and targeted intervention for preventing falls and injuries among older people in community and emergency care settings: systematic review and meta-analysis. BMJ. 2008;336(7636):130-3. [pmid: 18089892].
6 Huss A, Stuck AE, Rubenstein LZ, et al. Multidimensional preventive home visit programs for community-dwelling older adults: a systematic review and meta-analysis of randomized controlled trials. J Gerontol A Biol Sci Med Sci. 2008;63(3):298-307. [pmid: 18375879].
7 Stuck AE, Siu AL, Wieland GD, et al. Comprehensive geriatric assessment: a meta-analysis of controlled trials. Lancet. 1993;342(8878):1032-6. [pmid: 8105269].
8 Harris R, Helfand M, Woolf SH, et al. Methods Work Group, Third US Preventive Services Task Force. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(Suppl 3):21-35. [pmid: 11306229].
9 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD. Agency for Healthcare Research and Quality. 2008. Accessed at http://www.ahrq.gov/clinic/uspstf08/methods/procmanual.htm. 12 July 2012.
10 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006.
11 Boult C, Boult LB, Morishita L, et al. A randomized clinical trial of outpatient geriatric evaluation and management. J Am Geriatr Soc. 2001;49(4):351-9. [pmid: 11347776].
12 Guanghan LF, Kaifeng L, Mogg R, et al. Should baseline be a covariate or dependent variable in analyses of change from baseline in clinical trials?. Stat Med. 2009;28(20):2509-30. [pmid: 19610129].
13 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
14 Chi I, Chou KL, Kwan CW, et al. Use of the Minimum Data Set–Home Care: a cluster randomized controlled trial among the Chinese older adults. Aging Ment Health. 2006;10(1):33-9. [pmid: 16338812].
15 Coleman EA, Grothaus LC, Sandhu N, et al. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc. 1999;47(7):775-83. [pmid: 10404919].
16 Counsell SR, Callahan CM, Clark DO, et al. Geriatric care management for low-income seniors: a randomized controlled trial. JAMA. 2007;298(22):2623-33. [pmid: 18073358].
17 Dyer CA, Taylor GJ, Reed M, et al. Falls prevention in residential care homes: a randomised controlled trial. Age Ageing. 2004;33(6):596-602. [pmid: 15381507].
18 Peri K, Kerse N, Robinson E, et al. Does functionally based activity make a difference to health status and mobility? A randomised controlled trial in residential care facilities (the Promoting Independent Living Study; PILS). Age Ageing. 2008;37(1):57-63. [pmid: 17965045].
19 Phelan EA, Balderson B, Levine M, et al. Delivering effective primary care to older adults: a randomized, controlled trial of the senior resource team at group health cooperative. J Am Geriatr Soc. 2007;55(11):1748-56. [pmid: 17979898].
20 Sommers LS, Marton KI, Barbaccia JC, et al. Physician, nurse, and social worker collaboration in primary care for chronically ill seniors. Arch Intern Med. 2000;160(12):1825-33. [pmid: 10871977].
21 Tinetti ME, Baker DI, McAvay G, et al. A multifactorial intervention to reduce the risk of falling among elderly people living in the community. N Engl J Med. 1994;331(13):821-7. [pmid: 8078528].
22 Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
23 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. 2005;58(9):894-901. [pmid: 16085192].
24 Yeo G, Ingram L, Skurnick J, et al. Effects of a geriatric clinic on functional health and well-being of elders. J Gerontol. 1987;42(3):252-8. [pmid: 3571860].
25 Epstein AM, Hall JA, Fretwell M, et al. Consultative geriatric assessment for ambulatory patients: a randomized trial in a health maintenance organization. JAMA. 1990;263(4):538-44. [pmid: 2294326].
26 Wagner EH, LaCroix AZ, Grothaus L, et al. Preventing disability and falls in older adults: a population-based randomized trial. Am J Public Health. 1994;84(11):1800-6. [pmid: 7977921].
27 Silverman M, Musa D, Martin DC, et al. Evaluation of outpatient geriatric assessment: a randomized multi-site trial. J Am Geriatr Soc. 1995;43(7):733-40. [pmid: 7602022].
28 Stuck AE, Aronow HU, Steiner A, et al. A trial of annual in-home comprehensive geriatric assessments for elderly people living in the community. N Engl J Med. 1995;333(18):1184-9. [pmid: 7565974].
29 Toseland RW, O’Donnell JC, Engelhardt JB, et al. Outpatient geriatric evaluation and management: results of a randomized trial. Med Care. 1996;34(6):624-40. [pmid: 8656727].
30 Leveille SG, Wagner EH, Davis C, et al. Preventing disability and managing chronic illness in frail older adults: a randomized trial of a community-based partnership with primary care. J Am Geriatr Soc. 1998;46(10):1191-8. [pmid: 9777899].
31 Wallace JI, Buchner DM, Grothaus L, et al. Implementation and effectiveness of a community-based health promotion program for older adults. J Gerontol A Biol Sci Med Sci. 1998;53(4):M301-6. [pmid: 18314570].
32 Reuben DB, Frank JC, Hirsch SH, et al. A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations. J Am Geriatr Soc. 1999;47(3):269-76. [pmid: 10078887].
33 Burns R, Nichols LO, Martindale-Adams J, et al. Interdisciplinary geriatric primary care evaluation and management: two-year outcomes. J Am Geriatr Soc. 2000;48(1):8-13. [pmid: 10642014].
34 Gill TM, Baker DI, Gottschalk M, et al. A program to prevent functional decline in physically frail, elderly persons who live at home. N Engl J Med. 2002;347(14):1068-74. [pmid: 12362007].
35 Vetter NJ, Jones DA, Victor CR. Effect of health visitors working with elderly patients in general practice: a randomised controlled trial. Br Med J (Clin Res Ed). 1984;288(6414):369-72.
36 Carpenter GI, Demopoulos GR. Screening the elderly in the community: controlled trial of dependency surveillance using a questionnaire administered by volunteers. BMJ. 1990;300(6734):1253-6. [pmid: 2354297].
37 McEwan RT, Davison N, Forster DP, et al. Screening elderly people in primary care: a randomized controlled trial. Br J Gen Pract. 1990;40(332):94-7. [pmid: 2112022].
38 Pathy MS, Bayer A, Harding K, et al. Randomised trial of case finding and surveillance of elderly people at home. Lancet. 1992;340(8824):890-3. [pmid: 1357306].
39 van Rossum E, Frederiks CM, Philipsen H, et al. Effects of preventive home visits to elderly people. BMJ. 1993;307(6895):27-32. [pmid: 8343668].
40 Schrijnemaekers VJ, Haveman MJ. Effects of preventive outpatient geriatric assessment: short-term results of a randomized controlled study. Home Health Care Serv Q. 1995;15(2):81-97. [pmid: 10143898].
41 Gagnon AJ, Schein C, McVey L, et al. Randomized controlled trial of nurse case management of frail older people. J Am Geriatr Soc. 1999;47(9):1118-24. [pmid: 10484257].
42 Rockwood K, Stadnyk K, Carver D, et al. A clinimetric evaluation of specialized geriatric care for rural dwelling, frail older people. J Am Geriatr Soc. 2000;48(9):1080-5. [pmid: 10983907].
43 Stuck AE, Minder CE, Peter-Wuest I, et al. A randomized trial of in-home visits for disability prevention in community-dwelling older people at low and high risk for nursing home admission. Arch Intern Med. 2000;160(7):977-86. [pmid: 10761963].
44 van Haastregt JC, Diederiks JP, van Rossum E, et al. Effects of a programme of multifactorial home visits on falls and mobility impairments in elderly people at risk: randomised controlled trial. BMJ. 2000;321(7267):994-8. [pmid: 11039967].
45 Hebert R, Robichaud L, Roy PM, et al. Efficacy of a nurse-led multidimensional preventive programme for older people at risk of functional decline: a randomized controlled trial. Age Ageing. 2001;30(2):147-53. [pmid: 11395345].
46 Kono A, Kai I, Sakato C, et al. Effect of preventive home visits for ambulatory housebound elders in Japan: a pilot study. Aging Clin Exp Res. 2004;16(4):293-9. [pmid: 15575123].
47 Melis RJ, van Eijken MI, Teerenstra S, et al. A randomized study of a multidisciplinary program to intervene on geriatric syndromes in vulnerable older people who live at home (Dutch EASYcare Study). J Gerontol A Biol Sci Med Sci. 2008;63(3):283-90. [pmid: 18375877].
48 Richardson J, Chan D, Risdon K, et al. Does monitoring change in function in community-dwelling older adults alter outcome? A randomized controlled trial. Clin Rehabil. 2008;22(12):1061-70. [pmid: 19052245].
49 Li CM, Chen CY, Li CY, et al. The effectiveness of a comprehensive geriatric assessment intervention program for frailty in community-dwelling older people: a randomized, controlled trial. Arch Gerontol Geriatr. 2010;50(Suppl 1):S39-42. [pmid: 20171455].
50 Ploeg J, Brazil K, Hutchison B, et al. Effect of preventive primary care outreach on health related quality of life among older adults at risk of functional decline: randomised controlled trial. BMJ. 2010;340:c1480. [pmid: 20400483].
51 van Hout HP, Jansen AP, van Marwijk HW, et al. Prevention of adverse health trajectories in a vulnerable elderly population through nurse home visits: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2010;65(7):734-42. [pmid: 20457579].
52 Morrissey JP, Harris RP, Kincade-Norburn J, et al. Medicare reimbursement for preventive care: changes in performance of services, quality of life, and health care costs. Med Care. 1995;33(4):315-31. [pmid: 7731275].
53 Cohen HJ, Feussner JR, Weinberger M, et al. A controlled trial of inpatient and outpatient geriatric evaluation and management. N Engl J Med. 2002;346(12):905-12. [pmid: 11907291].
54 Martin DC, Berger ML, Anstatt DT, et al. A randomized controlled open trial of population-based disease and case management in a Medicare Plus Choice health maintenance organization. Prev Chronic Dis. 2004;1(4):A05. [pmid: 15670436].
55 Holland SK, Greenberg J, Tidwell L, et al. Community-based health coaching, exercise, and health service utilization. J Aging Health. 2005;17(6):697-716. [pmid: 16377768].
56 Alkema GE, Wilber KH, Shannon GR, et al. Reduced mortality: the unexpected impact of a telephone-based care management intervention for older adults in managed care. Health Serv Res. 2007;42(4):1632-50. [pmid: 17610441].
57 Mahoney JE, Shea TA, Przybelski R, et al. Kenosha County falls prevention study: a randomized, controlled trial of an intermediate-intensity, community-based multifactorial falls intervention. J Am Geriatr Soc. 2007;55(4):489-98. [pmid: 17397425].
58 Shumway-Cook A, Silver IF, LeMier M, et al. Effectiveness of a community-based multifactorial intervention on falls and fall risk factors in community-living older adults: a randomized, controlled trial. J Gerontol A Biol Sci Med Sci. 2007;62(12):1420-7. [pmid: 18166695].
59 Hendriksen C, Lund E, Stromgard E. Consequences of assessment and intervention among elderly people: a three year randomised controlled trial. Br Med J (Clin Res Ed). 1984;289(6457):1522-4.
60 Vetter NJ, Lewis PA, Ford D. Can health visitors prevent fractures in elderly people?. BMJ. 1992;304(6831):888-90. [pmid: 1392755].
61 Gallagher EM. Head over heels: impact of a health promotion program to reduce falls in the elderly. Can J Aging. 1996;15:84-96.
62 Bernabei R, Landi F, Gambassi G, et al. Randomised trial of impact of model of integrated care and case management for older people living in the community. BMJ. 1998;316(7141):1348-51. [pmid: 9563983].
63 Close J, Ellis M, Hooper R, et al. Prevention of falls in the elderly trial (PROFET): a randomised controlled trial. Lancet. 1999;353(9147):93-7. [pmid: 10023893].
64 Dalby DM, Sellors JW, Fraser FD, et al. Effect of preventive home visits by a nurse on the outcomes of frail elderly people in the community: a randomized controlled trial. CMAJ. 2000;162(4):497-500. [pmid: 10701382].
65 Hogan DB, MacDonald FA, Betts J, et al. A randomized controlled trial of a community-based consultation service to prevent falls. CMAJ. 2001;165(5):537-43. [pmid: 11563205].
66 Newbury JW, Marley JE, Beilby JJ. A randomised controlled trial of the outcome of health assessment of people aged 75 years and over. Med J Aust. 2001;175(2):104-7. [pmid: 11556409].
67 Lightbody E, Watkins C, Leathley M, et al. Evaluation of a nurse-led falls prevention programme versus usual care: a randomized controlled trial. Age Ageing. 2002;31(3):203-10. [pmid: 12006310].
68 Yamada Y, Ikegami N. Preventive home visits for community-dwelling frail elderly people based on Minimum Data Set-Home Care: randomized controlled trial. Geriatric Gerontol Int. 2003;3(4):236-42.
69 Byles JE, Tavener M, O’Connell RL, et al. Randomised controlled trial of health assessments for older Australian veterans and war widows. Med J Aust. 2004;181(4):186-90. [pmid: 15310251].
70 Caplan GA, Williams AJ, Daly B, et al. A randomized, controlled trial of comprehensive geriatric assessment and multidisciplinary intervention after discharge of elderly from the emergency department—the DEED II study. J Am Geriatr Soc. 2004;52(9):1417-23. [pmid: 15341540].
71 Davison J, Bond J, Dawson P, et al. Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention—a randomised controlled trial. Age Ageing. 2005;34(2):162-8. [pmid: 15716246].
72 Lord SR, Tiedemann A, Chapman K, et al. The effect of an individualized fall prevention program on fall risk and falls in older people: a randomized, controlled trial. J Am Geriatr Soc. 2005;53(8):1296-304. [pmid: 16078954].
73 Sahlen KG, Dahlgren L, Hellner BM, et al. Preventive home visits postpone mortality—a controlled trial with time-limited results. BMC Public Health. 2006;6:220. [pmid: 16945128].
74 Salminen MJ, Vahlberg TJ, Salonoja MT, et al. Effect of a risk-based multifactorial fall prevention program on the incidence of falls. J Am Geriatr Soc. 2009;57(4):612-9. [pmid: 19392952].
75 Thomas R, Worrall G, Elgar F, et al. Can they keep going on their own? A four-year randomized trial of functional assessments of community residents. Can J Aging. 2007;26(4):379-90. [pmid: 18669005].
76 Vaapio S, Salminen M, Vahlberg T, et al. Effects of risk-based multifactorial fall prevention on health-related quality of life among the community-dwelling aged: a randomized controlled trial. Health Qual Life Outcomes. 2007;5:20. [pmid: 17462083].
77 Elley CR, Robertson MC, Garrett S, et al. Effectiveness of a falls-and-fracture nurse coordinator to reduce falls: a randomized, controlled trial of at-risk older adults. J Am Geriatr Soc. 2008;56(8):1383-9. [pmid: 18808597].
78 Harari D, Iliffe S, Kharicha K, et al. Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing. 2008;37(5):565-71. [pmid: 18755784].
79 Hendriks MR, Bleijlevens MH, van Haastregt JC, et al. Lack of effectiveness of a multidisciplinary fall-prevention program in elderly people at risk: a randomized, controlled trial. J Am Geriatr Soc. 2008;56(8):1390-7. [pmid: 18662214].
80 Vind AB, Andersen HE, Pedersen KD, et al. Effect of a program of multifactorial fall prevention on health related quality of life, functional ability, fear of falling and psychological well-being: a randomized controlled trial. Aging Clin Exp Res. 2010;22(3):249-54. [pmid: 19934621].
81 Hogg W, Lemelin J, Dahrouge S, et al. Randomized controlled trial of anticipatory and preventive multidisciplinary team care: for complex patients in a community-based primary care setting. Can Fam Physician. 2009;55(12):e76-e85. [pmid: 20008582].
82 Lam LC, Lee JS, Chung JC, et al. A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. 2010;25(4):395-402. [pmid: 19606455].
83 Logan PA, Coupland CA, Gladman JR, et al. Community falls prevention for people who call an emergency ambulance after a fall: randomised controlled trial. BMJ. 2010;340:c2102. [pmid: 20460331].
84 Bouman A, van Rossum E, Nelemans P, et al. Effects of intensive home visiting programs for older people with poor health status: a systematic review. BMC Health Serv Res. 2008;8:74. [pmid: 18387184].
85 Stuck AE, Egger M, Hammer A, et al. Home visits to prevent nursing home admission and functional decline in elderly people: systematic review and meta-regression analysis. JAMA. 2002;287(8):1022-8. [pmid: 11866651].
86 Elkan R, Kendrick D, Dewey M, et al. Effectiveness of home based support for older people: systematic review and meta-analysis. BMJ. 2001;323(7315):719-25. [pmid: 11576978].
87 van Haastregt JC, Diederiks JP, van Rossum E, et al. Effects of preventive home visits to elderly people living in the community: systematic review. BMJ. 2000;320(7237):754-8. [pmid: 10720360].
88 Allen CM, Becker PM, McVey LJ, et al. A randomized, controlled clinical trial of a geriatric consultation team: compliance with recommendations. JAMA. 1986;255(19):2617-21. [pmid: 3517396].
89 Applegate WB, Miller ST, Graney MJ, et al. A randomized, controlled trial of a geriatric assessment unit in a community rehabilitation hospital. N Engl J Med. 1990;322(22):1572-8. [pmid: 2186276].
90 Archbold PG, Stewart BJ, Miller LL, et al. The PREP system of nursing interventions: a pilot test with families caring for older members. Res Nurs Health. 1995;18(1):3-16. [pmid: 7831493].
91 Balaban DJ, Goldfarb NI, Perkel RL, et al. Follow-up study of an urban family medicine home visit program. J Fam Pract. 1988;26(3):307-12. [pmid: 3346634].
92 Beck A, Scott J, Williams P, et al. A randomized trial of group outpatient visits for chronically ill older HMO members: the Cooperative Health Care Clinic. J Am Geriatr Soc. 1997;45(5):543-9. [pmid: 9158573].
93 Burns R, Nichols LO, Graney MJ, et al. Impact of continued geriatric outpatient management on health outcomes of older veterans. Arch Intern Med. 1995;155(12):1313-8. [pmid: 7778963].
94 Burton LC, Paglia MJ, German PS, et al. The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. Prev Med. 1995;24(5):492-7. [pmid: 8524724].
95 Clark F, Azen SP, Zemke R, et al. Occupational therapy for independent-living older adults: a randomized controlled trial. JAMA. 1997;278(16):1321-6. [pmid: 9343462].
96 Clarke M, Clarke SJ, Jagger C. Social intervention and the elderly: a randomized controlled trial. Am J Epidemiol. 1992;136(12):1517-23. [pmid: 1288281].
97 Clemson L, Cumming RG, Kendig H, et al. The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J Am Geriatr Soc. 2004;52(9):1487-94. [pmid: 15341550].
98 Phibbs CS, Holty JE, Goldstein MK, et al. The effect of geriatrics evaluation and management on nursing home use and health care costs: results from a randomized trial. Med Care. 2006;44(1):91-5. [pmid: 16365618].
99 Crotty M, Whitehead C, Miller M, et al. Patient and caregiver outcomes 12 months after home-based therapy for hip fracture: a randomized controlled trial. Arch Phys Med Rehabil. 2003;84(8):1237-9. [pmid: 12917867].
100 Cunliffe AL, Gladman JR, Husbands SL, et al. Sooner and healthier: a randomised controlled trial and interview study of an early discharge rehabilitation service for older people. Age Ageing. 2004;33(3):246-52. [pmid: 15082429].
101 Dunn RB, Lewis PA, Vetter NJ, et al. Health visitor intervention to reduce days of unplanned hospital re-admission in patients recently discharged from geriatric wards: the results of a randomised controlled study. Arch Gerontol Geriatr. 1994;18(1):15-23. [pmid: 15374310].
102 Eekhof J, De Bock G, Schaapveld K, et al. Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. 2000;17(4):329-33. [pmid: 10934182].
103 Engelhardt JB, Toseland RW, O’Donnell JC, et al. The effectiveness and efficiency of outpatient geriatric evaluation and management. J Am Geriatr Soc. 1996;44(7):847-56. [pmid: 8675938].
104 Fabacher D, Josephson K, Pietruszka F, et al. An in-home preventive assessment program for independent older adults: a randomized controlled trial. J Am Geriatr Soc. 1994;42(6):630-8. [pmid: 8201149].
105 Fletcher AE, Price GM, Ng ES, et al. Population-based multidimensional assessment of older people in UK general practice: a cluster-randomised factorial trial. Lancet. 2004;364(9446):1667-77. [pmid: 15530627].
106 Ford AB, Katz S, Downs TD, et al. Results of long-term home nursing: the influence of disability. J Chronic Dis. 1971;24(9):591-6. [pmid: 5158770].
107 Fox PJ, Breuer W, Wright JA. Effects of a health promotion program on sustaining health behaviors in older adults. Am J Prev Med. 1997;13(4):257-64. [pmid: 9236961].
108 Fretwell MD, Raymond PM, McGarvey ST, et al. The Senior Care Study: a controlled trial of a consultative/unit-based geriatric assessment program in acute care. J Am Geriatr Soc. 1990;38(10):1073-81. [pmid: 2229859].
109 Gayton D, Wood-Dauphinee S, de Lorimer M, et al. Trial of a geriatric consultation team in an acute care hospital. J Am Geriatr Soc. 1987;35(8):726-36. [pmid: 3301989].
110 Gilchrist WJ, Newman RJ, Hamblen DL, et al. Prospective randomised study of an orthopaedic geriatric inpatient service. BMJ. 1988;297(6656):1116-8. [pmid: 3143450].
111 Gill TM, McGloin JM, Gahbauer EA, et al. Two recruitment strategies for a clinical trial of physically frail community-living older persons. J Am Geriatr Soc. 2001;49(8):1039-45. [pmid: 11555064].
112 Gill TM, Baker DI, Gottschalk M, et al. A prehabilitation program for the prevention of functional decline: effect on higher-level physical function. Arch Phys Med Rehabil. 2004;85(7):1043-9. [pmid: 15241748].
113 Gunner-Svensson F, Ipsen J, Olsen J, et al. Prevention of relocation of the aged in nursing homes. Scand J Prim Health Care. 1984;2(2):49-56. [pmid: 6544449].
114 Hall N. Randomized trial of a health promotion program for frail elders. Can J Aging. 1992;11:72-91.
115 Hansen FR, Spedtsberg K, Schroll M. Geriatric follow-up by home visits after discharge from hospital: a randomized controlled trial. Age Ageing. 1992;21(6):445-50. [pmid: 1471584].
116 Hansen FR, Poulsen H, Sorensen KH. A model of regular geriatric follow-up by home visits to selected patients discharged from a geriatric ward: a randomized controlled trial. Aging (Milano). 1995;7(3):202-6. [pmid: 8547378].
117 Harris RD, Henschke PJ, Popplewell PY, et al. A randomised study of outcomes in a defined group of acutely ill elderly patients managed in a geriatric assessment unit or a general medical unit. Aust N Z J Med. 1991;21(2):230-4. [pmid: 1810282].
118 Hogan DB, Fox RA, Badley BW, et al. Effect of a geriatric consultation service on management of patients in an acute care hospital. CMAJ. 1987;136(7):713-7. [pmid: 3548934].
119 Hogan DB, Fox RA. A prospective controlled trial of a geriatric consultation team in an acute-care hospital. Age Ageing. 1990;19(2):107-13. [pmid: 2337005].
120 Hogg W, Lemelin J, Dahrouge S, et al. Randomized controlled trial of anticipatory and preventive multidisciplinary team care: for complex patients in a community-based primary care setting. Can Fam Physician. 2009;55(12):e76-e85. [pmid: 20008582].
121 Dahrouge S, Hogg W, Lemelin J, et al. Methods for a study of multidisciplinary team care in a family practice. Can Fam Physician. 2010;56(2):e73-e83. [pmid: 20154234].
122 Hornbrook MC, Stevens VJ, Wingfield DJ, et al. Preventing falls among community-dwelling older persons: results from a randomized trial. Gerontologist. 1994;34(1):16-23. [pmid: 8150304].
123 Hughes SL, Weaver FM, Giobbie-Hurder A, et al. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. 2000;284(22):2877-85. [pmid: 11147984].
124 Jitapunkul S. A randomised controlled trial of regular surveillance in Thai elderly using a simple questionnaire administered by non-professional personnel. J Med Assoc Thai. 1998;81(5):352-6. [pmid: 9623035].
125 Kennie DC, Reid J, Richardson IR, et al. Effectiveness of geriatric rehabilitative care after fractures of the proximal femur in elderly women: a randomised clinical trial. BMJ. 1988;297(6656):1083-6. [pmid: 3143436].
126 Kerse NM, Flicker L, Jolley D, et al. Improving the health behaviours of elderly people: randomised controlled trial of a general practice education programme. BMJ. 1999;319(7211):683-7. [pmid: 10480825].
127 Leung AC, Liu CP, Chow NW, et al. Cost-benefit analysis of a case management project for the community-dwelling frail elderly in Hong Kong. J Appl Gerontol. 2004;23:70-85.
128 Phelan EA, Williams B, Penninx BW, et al. Activities of daily living function and disability in older adults in a randomized trial of the health enhancement program. J Gerontol A Biol Sci Med Sci. 2004;59(8):838-43. [pmid: 15345735].
129 Li CM, Chen CY, Li CY, et al. The effectiveness of a comprehensive geriatric assessment intervention program for frailty in community-dwelling older people: a randomized, controlled trial. Arch Gerontol Geriatr. 2010;50(Suppl 1):S39-42. [pmid: 20171455].
130 Logan PA, Coupland CA, Gladman JR, et al. Community falls prevention for people who call an emergency ambulance after a fall: randomised controlled trial. BMJ. 2010;340:c2102. [pmid: 20460331].
131 Luker KA. Health visiting and the elderly. Nurs Times. 1981;77:137-40.
132 Luker K. Evaluating Health Visiting Practice: An Experimental Study to Evaluate the Effects of Focused Health Visitor Intervention on Elderly Women Living Alone at Home. London. Royal College of Nursing. 1982.
133 Martin F, Oyewole A, Moloney A. A randomized controlled trial of a high support hospital discharge team for elderly people. Age Ageing. 1994;23(3):228-34. [pmid: 8085509].
134 Melin AL, Bygren LO. Efficacy of the rehabilitation of elderly primary health care patients after short-stay hospital treatment. Med Care. 1992;30(11):1004-15. [pmid: 1331632].
135 Melis RJ, van Eijken MI, Borm GF, et al. The design of the Dutch EASYcare study: a randomised controlled trial on the effectiveness of a problem-based community intervention model for frail elderly people. BMC Health Serv Res. 2005;5:65. [pmid: 16207382].
136 Melis RJ, Adang E, Teerenstra S, et al. Cost-effectiveness of a multidisciplinary intervention model for community-dwelling frail older people. J Gerontol A Biol Sci Med Sci. 2008;63(3):275-82. [pmid: 18375876].
137 Naylor MD, Brooten D, Campbell R, et al. Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. JAMA. 1999;281(7):613-20. [pmid: 10029122].
138 Newcomer R, Maravilla V, Faculjak P, et al. Outcomes of preventive case management among high-risk elderly in three medical groups: a randomized clinical trial. Eval Health Prof. 2004;27(4):323-48. [pmid: 15492046].
139 Nicolaides-Bouman A, van Rossum E, Kempen GI, et al. Effects of home visits by home nurses to elderly people with health problems: design of a randomised clinical trial in the Netherlands. BMC Health Serv Res. 2004;4(1):35. [pmid: 15601473].
140 Bouman A, van Rossum E, Evers S, et al. Effects on health care use and associated cost of a home visiting program for older people with poor health status: a randomized clinical trial in the Netherlands. J Gerontol A Biol Sci Med Sci. 2008;63(3):291-7. [pmid: 18375878].
141 Nikolaus T, Specht-Leible N, Bach M, et al. A randomized trial of comprehensive geriatric assessment and home intervention in the care of hospitalized patients. Age Ageing. 1999;28(6):543-50. [pmid: 10604506].
142 Nikolaus T, Bach M. Preventing falls in community-dwelling frail older people using a home intervention team (HIT): results from the randomized Falls-HIT trial. J Am Geriatr Soc. 2003;51(3):300-5. [pmid: 12588572].
143 Oktay JS, Volland PJ. Post-hospital support program for the frail elderly and their caregivers: a quasi-experimental evaluation. Am J Public Health. 1990;80(1):39-46. [pmid: 2152843].
144 Ploeg J, Brazil K, Hutchison B, et al. Effect of preventive primary care outreach on health related quality of life among older adults at risk of functional decline: randomised controlled trial. BMJ. 2010;340:c1480. [pmid: 20400483].
145 Powell C, Montgomery P. The age study: the admission of geriatric patients through emergency. Age Ageing. 1990;19:21.
146 Rubenstein LZ, Josephson KR, Wieland GD, et al. Effectiveness of a geriatric evaluation unit: a randomized clinical trial. N Engl J Med. 1984;311(26):1664-70. [pmid: 6390207].
147 Rubenstein LV, Calkins DR, Young RT, et al. Improving patient function: a randomized trial of functional disability screening. Ann Intern Med. 1989;111(10):836-42. [pmid: 2683917].
148 Rubenstein LZ, Aronow HU, Schloe M, et al. A home-based geriatric assessment, follow-up and health promotion program: design, methods, and baseline findings from a 3-year randomized clinical trial. Aging (Milano). 1994;6(2):105-20. [pmid: 7918729].
149 Bula CJ, Berod AC, Stuck AE, et al. Effectiveness of preventive in-home geriatric assessment in well functioning, community-dwelling older people: secondary analysis of a randomized trial. J Am Geriatr Soc. 1999;47(4):389-95. [pmid: 10203111].
150 Rubin CD, Sizemore MT, Loftis PA, et al. The effect of geriatric evaluation and management on Medicare reimbursement in a large public hospital: a randomized clinical trial. J Am Geriatr Soc. 1992;40(10):989-95. [pmid: 1401688].
151 Rubin CD, Sizemore MT, Loftis PA, et al. A randomized, controlled trial of outpatient geriatric evaluation and management in a large public hospital. J Am Geriatr Soc. 1993;41(10):1023-8. [pmid: 8409145].
152 Sahlen KG, Lofgren C, Mari HB, et al. Preventive home visits to older people are cost-effective. Scand J Public Health. 2008;36(3):265-71. [pmid: 18519295].
153 Salminen M, Vahlberg T, Kivela SL. The long-term effect of a multifactorial fall prevention programme on the incidence of falls requiring medical treatment. Public Health. 2009;123(12):809-13. [pmid: 19958918].
154 Scott JC, Conner DA, Venohr I, et al. Effectiveness of a group outpatient visit model for chronically ill older health maintenance organization members: a 2-year randomized trial of the cooperative health care clinic. J Am Geriatr Soc. 2004;52(9):1463-70. [pmid: 15341547].
155 Shapiro A, Taylor M. Effects of a community-based early intervention program on the subjective well-being, institutionalization, and mortality of low-income elders. Gerontologist. 2002;42(3):334-41. [pmid: 12040135].
156 Sorensen KH, Sivertsen J. Follow-up three years after intervention to relieve unmet medical and social needs of old people. Compr Gerontol B. 1988;2(2):85-91. [pmid: 3228801].
157 Steinberg M, Cartwright C, Peel N, et al. A sustainable programme to prevent falls and near falls in community dwelling older people: results of a randomised trial. J Epidemiol Community Health. 2000;54(3):227-32. [pmid: 10746118].
158 Stewart S, Pearson S, Luke CG, et al. Effects of home-based intervention on unplanned readmissions and out-of-hospital deaths. J Am Geriatr Soc. 1998;46(2):174-80. [pmid: 9475445].
159 Stewart S, Harvey I, Poland F, et al. Are occupational therapists more effective than social workers when assessing frail older people? Results of CAMELOT, a randomised controlled trial. Age Ageing. 2005;34(1):41-6. [pmid: 15525654].
160 Stuck AE, Zwahlen HG, Neuenschwander BE, et al. Methodologic challenges of randomized controlled studies on in-home comprehensive geriatric assessment: the EIGER project. Aging (Milano). 1995;7(3):218-23. [pmid: 8547381].
161 Stuck AE, Kharicha K, Dapp U, et al. The PRO-AGE study: an international randomised controlled study of health risk appraisal for older persons based in general practice. BMC Med Res Methodol. 2007;7:2. [pmid: 17217546].
162 Teasdale TA, Shuman L, Snow E, et al. A comparison of placement outcomes of geriatric cohorts receiving care in a geriatric assessment unit and on general medicine floors. J Am Geriatr Soc. 1983;31(9):529-34. [pmid: 6886278].
163 Thomas DR, Brahan R, Haywood BP. Inpatient community-based geriatric assessment reduces subsequent mortality. J Am Geriatr Soc. 1993;41(2):101-4. [pmid: 8426028].
164 Tinetti ME, Baker DI, Gottschalk M, et al. Home-based multicomponent rehabilitation program for older persons after hip fracture: a randomized trial. Arch Phys Med Rehabil. 1999;80(8):916-22. [pmid: 10453768].
165 Townsend J, Piper M, Frank AO, et al. Reduction in hospital readmission stay of elderly patients by a community based hospital discharge scheme: a randomised controlled trial. BMJ. 1988;297(6647):544-7. [pmid: 2844356].
166 Trentini M, Semeraro S, Motta M. Effectiveness of geriatric evaluation and care: one-year results of a multicenter randomized clinical trial. Aging (Milano). 2001;13(5):395-405. [pmid: 11820714].
167 Tulloch AJ, Moore V. A randomized controlled trial of geriatric screening and surveillance in general practice. J R Coll Gen Pract. 1979;29(209):733-40. [pmid: 536982].
168 Sjosten NM, Salonoja M, Piirtola M, et al. A multifactorial fall prevention programme in the community-dwelling aged: predictors of adherence. Eur J Public Health. 2007;17(5):464-70. [pmid: 17208952].
169 Sjösten NM, Salonoja M, Piirtola M, et al. A multifactorial fall prevention programme in home-dwelling elderly people: a randomized-controlled trial. Public Health. 2007;121(4):308-18. [pmid: 17320125].
170 van Hout HP, Nijpels G, van Marwijk HW, et al. Design and pilot results of a single blind randomized controlled trial of systematic demand-led home visits by nurses to frail elderly persons in primary care. BMC Geriatr. 2005;5:11. [pmid: 16150147].
171 van Rossum E. Effects of preventive home visits to the elderly (Thesis). 1993:1-147.
172 Vass M, Avlund K, Kvist K, et al. Structured home visits to older people: are they only of benefit for women? A randomised controlled trial. Scand J Prim Health Care. 2004;22(2):106-11. [pmid: 15255491].
173 Vind AB, Andersen HE, Pedersen KD, et al. Effect of a program of multifactorial fall prevention on health related quality of life, functional ability, fear of falling and psychological well-being: a randomized controlled trial. Aging Clin Exp Res. 2010;22(3):249-54. [pmid: 19934621].
174 Williams ME, Williams TF, Zimmer JG, et al. How does the team approach to outpatient geriatric evaluation compare with traditional care: a report of a randomized controlled trial. J Am Geriatr Soc. 1987;35(12):1071-8. [pmid: 3119693].
175 Williams EI, Greenwell J, Groom LM. The care of people over 75 years old after discharge from hospital: an evaluation of timetabled visiting by Health Visitor Assistants. J Public Health Med. 1992;14(2):138-44. [pmid: 1325167].
176 Winograd CH. Targeting strategies: an overview of criteria and outcomes. J Am Geriatr Soc. 1991;39:25S-35S. [pmid: 1885875].
177 Zimmer JG, Groth-Juncker A, McCusker J. A randomized controlled study of a home health care team. Am J Public Health. 1985;75(2):134-41. [pmid: 3966617].