# Inclusion and Exclusion of Trials From Relevant Systematic Evidence Reviews

Trial Publications | Beswick 2008^*,3^ | Bouman 2008^*,84^ | Huss 2008^*,6^ | Stuck 2002^85^ | Elkan 2001^86^ | Van Haastregt 2000^87^ | Stuck 1993^*,7^ | Status of article: Included (X) or Reason for Exclusion
Alkema 2007^56^ | | | | | | | | X
Allen 1986^88^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Applegate 1990^89^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Archbold 1995^90^ | | | | | X | | | Design not RCT
Balaban 1988^91^ | X | | | | X | | | Problems with baseline comparability between groups
Beck 1997^92^ | X | | | | | | | Not a clinical assessment and management intervention
Bernabei 1998^62^ | X | | | | | | | X
Boult 2001^11^ | X | | | | | | | X
Burns 1995^93^ Burns 2000^33^ | X | | | | | | | X
Burton 1995^94^ | X | | | | | | | No relevant outcomes
Byles 2004^69^ | X | | X | | | | | X
Caplan 2004^70^ | X | | | | | | | X
Carpenter 1990^36^ | X | | X | X | | X | X | X
Chi 2006^14^ | | | | | | | | X
Clark 1997^95^ | X | | | | | | | Not a clinical assessment and management intervention
Clarke 1992^96^ | X | | | X | | | | Not a clinical assessment and management intervention
Clemson 2004^97^ | X | | | | | | | Not a clinical assessment and management intervention
Close 1999^63^ | X | | | | | | | X
Cohen 2002^53^ Phibbs 2006^98^ | | | | | | | | X
Coleman 1999^15^ | X | | | | | | | X
Counsell 2007^16^ | | | | | | | | X
Crotty 2003^99^ | X | | | | | | | Not a clinical assessment and management intervention
Cunliffe 2004^100^ | X | | | | | | | Intervention not conducted in primary care or other similar setting
Dalby 2000^64^ | X | X | | | | | | X
Davison 2005^71^ | X | | | | | | | X
Dunn 1994^101^ | X | | | | X | | | Intervention not conducted in primary care or other similar setting
Dyer 2004^17^ | | | | | | | | X
Eekhof 2000^102^ | X | | | | | | | No relevant outcomes
Elley 2008^77^ | | | | | | | | X
Engelhardt 1996^103^ Toseland 1996^29^ | X | | | | | | | X
Epstein 1990^25^ | X | | | | | | X | X
Fabacher 1994^104^ | X | | X | X | X | X | | Outcome assessment unblinded
Fletcher 2004^105^ | X | | | | | | | Design not RCT
Ford 1971^106^ | X | | | | | | | Requires integrated inpatient and outpatient approach
Fox 1997^107^ | X | | | | | | | Design not RCT
Fretwell 1990^108^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Gagnon 1999^41^ | X | | | | | | | X
Gallagher 1996^61^ | X | | | | | | | X
Gayton 1987^109^ | | | | | | | X | Design not RCT
Gilchrist 1988^110^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Gill 2001^111^ Gill 2002^34^ Gill 2004^112^ | X | | | | | | | X
Gunner-Svensson 1984^113^ | X | | X | X | | | | Not a clinical assessment and management intervention
Hall 1992^114^ | X | X | | | X | X | | Design not RCT
Hansen 1992^115^ | X | | | | X | | X | Not a clinical assessment and management intervention
Hansen 1995^116^ | X | | | | | | | Requires integrated inpatient and outpatient approach
Harris 1991^117^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Hebert 2001^45^ | X | | X | X | | | | X
Hendriks 2008^79^ | | | | | | | | X
Hendriksen 1984^59^ | X | | X | X | X | X | X | X
Hogan 1987^118^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Hogan 1990^119^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Hogan 2001^65^ | X | | | | | | | X
Hogg 2009^120^ Dahrouge 2010^121^ | | | | | | | | X
Holland 2005^55^ | | | | | | | | X
Hornbrook 1994^122^ | X | | | | | | | Not a clinical assessment and management intervention
Hughes 2000^123^ | X | | | | | | | Requires integrated inpatient and outpatient approach
Jitapunkul 1998^124^ | X | | | | | | | Intervention not conducted in primary care or other similar setting
Kennie 1988^125^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Kerse 1999^126^ | X | | | | | | | Not a clinical assessment and management intervention
Kono 2004^46^ | X | | X | | | | | X
Lam 2010^82^ | | | | | | | | X
Leung 2004^127^ | X | | | | | | | Poor reporting
Leveille 1998^30^ Phelan 2004^128^ | X | | | | | | | X
Li 2010^129^ | | | | | | | | X
Lightbody 2002^67^ | X | | | | | | | X
Logan 2010^130^ | | | | | | | | X
Lord 2005^72^ | X | | | | | | | X
Luker 1981^131^ | | | | | | X | | Design not RCT
Luker 1982^132^ | | | | | X | | | Intervention not conducted in primary care or other similar setting
Mahoney 2007^57^ | | | X | | | | | X
Martin 1994^133^ | X | | | | | | | Intervention not conducted in primary care or other similar setting
Martin 2004^54^ | | | | | | | | X
McEwan 1990^37^ | X | | | X | X | X | | X
Melin 1992^134^ | X | | | | | | X | Design not RCT
Melis 2005^135^ Melis 2008^47^ Melis 2008^136^ | | | X | | | | | X
Morrissey 1995^52^ | X | | | | | | | X
Naylor 1999^137^ | X | | | | | | | Intervention not conducted in primary care or other similar setting
Newbury 2001^66^ | X | | | X | | | | X
Newcomer 2004^138^ | X | | | | | | | Not a clinical assessment and management intervention
Nicolaides-Bouman 2004^139^ Bouman 2008^4^ Bouman 2008^140^ | | X | X | | | | | X
Nikolaus 1999^141^ | X | | | | | | | Intervention not conducted in primary care or other similar setting
Nikolaus 2003^142^ | X | | | | | | | Intervention not conducted in primary care or other similar setting
Oktay 1990^143^ | | | | | X | | | Design not RCT
Pathy 1992^38^ | X | | X | X | X | X | X | X
Peri 2008^18^ | | | | | | | | X
Phelan 2007^19^ | | | | | | | | X
Ploeg 2010^144^ | | | | | | | | X
Powell 1990^145^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Reuben 1999^32^ | X | | | | | | | X
Richardson 2008^48^ | | | | | | | | X
Rockwood 2000^42^ | X | | | | | | | X
Rubenstein 1984^146^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Rubenstein 1989^147^ | X | | | | | | | Conducted in a population that does not have an average age of 65 years and older
Rubenstein 1994^148^ Stuck 1995^28^ Bula 1999^149^ | X | | X | X | X | X | | X
Rubin 1992^150^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Rubin 1993^151^ | X | | | | | | | Requires integrated inpatient and outpatient approach
Sahlen 2006^73^ Sahlen 2008^152^ | X | | X | | | | | X
Salminen 2009^74^ Salminen 2009^153^ | | | | | | | | X
Schrijnemaekers 1995^40^ | X | | | | | | | X
Scott 2004^154^ | X | | | | | | | Not a clinical assessment and management intervention
Shapiro 2002^155^ | X | | | | | | | High or differential attrition
Shumway-Cook 2007^58^ | | | | | | | | X
Silverman 1995^27^ | X | | | | | | | X
Sommers 2000^20^ | X | | | | | | | X
Sorensen 1988^156^ | X | | | X | | X | X | Poor reporting
Steinberg 2000^157^ | X | | | | | | | No relevant outcomes
Stewart 1998^158^ | X | | | | | | | Requires integrated inpatient and outpatient approach
Stewart 2005^159^ | X | | | | | | | Design not RCT
Stuck 1995^160^ Stuck 2000^43^ | X | X | X | X | | | | X
Stuck 2007^161^ Harari 2008^78^ | | | | | | | | X
Teasdale 1983^162^ | | | | | | | X | Design not RCT
Thomas 1993^163^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Thomas 2007^75^ | | | | | | | | X
Tinetti 1994^21^ | X | | X | X | | X | | X
Tinetti 1999^164^ | X | | | | | | | Not a clinical assessment and management intervention
Townsend 1988^165^ | X | | | | | | | Requires integrated inpatient and outpatient approach
Trentini 2001^166^ | X | | | | | | | Requires integrated inpatient and outpatient approach
Tulloch 1979^167^ | X | | | | | | X | Poor reporting
Vaapio 2007^76^ Sjösten 2007^168^ Sjösten 2007^169^ | | | X | | | | | X
van Haastregt 2000^44^ | X | X | X | X | | | | X
van Hout 2005^170^ | | X | | | | | | No relevant outcomes
van Hout 2010^51^ | | | | | | | | X
van Rossum 1993^39^ van Rossum 1993^171^ | X | X | X | X | X | X | | X
Vass 2004^172^ | X | | | | | | | Design not RCT
Vetter 1984^35^ | X | | X | X | X | X | X | X
Vetter 1992^60^ | X | | X | X | | X | X | X
Vind 2009^173^ | | | | | | | | X
Wagner 1994^26^ | X | | | | | X | | X
Wallace 1998^31^ | X | | | | | | | X
Williams 1987^174^ | X | | | | | | X | No relevant outcomes
Williams 1992^175^ | X | | | | X | | | Requires integrated inpatient and outpatient approach
Winograd 1991^176^ | | | | | | | X | Intervention not conducted in primary care or other similar setting
Yamada 2003^68^ | | X | | | | | | X
Yeo 1987^24^ | X | | | | | | X | X
Zimmer 1985^177^ | X | | | | | | | Conducted in a population that is not comparable to primary care
Total Trials | 87 | 8 | 20 | 17 | 15 | 14 | 27 | 70
Total Unique Trials | 34 | 1 | 0 | 0 | 3 | 1 | 15 | 23

* Used as a source document

Abbreviations: RCT=randomized, controlled trial.