# List of Excluded Studies

1 Anttila SK, Huhtala HS, Pekurinen MJ, Pitkäjärvi TK. Cost-effectiveness of an innovative four-year post-discharge programme for elderly patients—prospective follow-up of hospital and nursing home use in project elderly and randomized controls. Scand J Public Health. 2000;28(1):41-6. Study relevance. [pmid: 10817313].
2 Avlund K, Vass M, Kvist K, Hendriksen C, Keiding N. Educational intervention toward preventive home visitors reduced functional decline in community-living older women. J Clin Epidemiol. 2007;60(9):954-62. Study relevance. [pmid: 17689812].
3 Balaban DJ, Goldfarb NI, Perkel RL, Carlson BL. Follow-up study of an urban family medicine home visit program. J Fam Pract. 1988;26(3):307-12. Study quality. [pmid: 3346634].
4 Bandinelli S, Lauretani F, Boscherini V, Gandi F, Pozzi M, Corsi AM, et al. A randomized, controlled trial of disability prevention in frail older patients screened in primary care: the FRASI study. Design and baseline evaluation. Aging Clin Exp Res. 2006;18(5):359-66. Study design. [pmid: 17167299].
5 Beck A, Scott J, Williams P, Robertson B, Jackson D, Gade G, et al. A randomized trial of group outpatient visits for chronically ill older HMO members: the Cooperative Health Care Clinic. J Am Geriatr Soc. 1997;45(5):543-9. Study relevance. [pmid: 9158573].
6 Béland F, Bergman H, Lebel P, Clarfield AM, Tousignant P, Contandriopoulos AP, et al. A system of integrated care for older persons with disabilities in Canada: results from a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2006;61(4):367-73. Study relevance. [pmid: 16611703].
7 Béland F, Bergman H, Lebel P, Dallaire L, Fletcher J, Contandriopoulos AP, et al. Integrated services for frail elders (SIPA): a trial of a model for Canada. Can J Aging. 2006;25(1):5-42. Study relevance. [pmid: 16770746].
8 Bergman H, Béland F, Lebel P, Contandriopoulos AP, Tousignant P, Brunelle Y, et al. Care for Canada’s frail elderly population: fragmentation or integration?. CMAJ. 1997;157(8):1116-21. Study relevance. [pmid: 9347783].
9 Beswick AD, Rees K, Dieppe P, Ayis S, Gooberman-Hill R, Horwood J, et al. Complex interventions to improve physical function and maintain independent living in elderly people: a systematic review and meta-analysis. Lancet. 2008;371(9614):725-35. Study relevance. [pmid: 18313501].
10 Bleijlevens MH, Hendriks MR, van Haastregt JC, van Rossum E, Kempen GI, Diederiks JP, et al. Process factors explaining the ineffectiveness of a multidisciplinary fall prevention programme: a process evaluation. BMC Public Health. 2008;8:332. No relevant outcomes. [pmid: 18816381].
11 Boult C, Reider L, Frey K, Leff B, Boyd CM, Wolff JL, et al. Early effects of “guided care” on the quality of health care for multimorbid older persons: a cluster-randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2008;63(3):321-7. Study relevance. [pmid: 18375882].
12 Bouman A, van Rossum E, Nelemans P, Kempen GI, Knipschild P. Effects of intensive home visiting programs for older people with poor health status: a systematic review. BMC Health Serv Res. 2008;8:74. Study relevance. [pmid: 18387184].
13 Boyd CM, Boult C, Shadmi E, Leff B, Brager R, Dunbar L, et al. Guided care for multimorbid older adults. Gerontologist. 2007;47(5):697-704. Study relevance. [pmid: 17989412].
14 Burton LC, Paglia MJ, German PS, Shapiro S, Damiano AM. The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. Prev Med. 1995;24(5):492-7. No relevant outcomes. [pmid: 8524724].
15 Calver J, Wiltshire A, Holman CD, Hunter E, Garfield C, Rosman DL. Does health assessment improve health outcomes in indigenous people? An RCT with 13 years of follow-up. Aust N Z J Public Health. 2005;29(2):107-11. Population. [pmid: 15915612].
16 Challis D, Clarkson P, Williamson J, Hughes J, Venables D, Burns A, et al. The value of specialist clinical assessment of older people prior to entry to care homes. Age Ageing. 2004;33(1):25-34. Study design. [pmid: 14695860].
17 Ciaschini PM, Straus SE, Dolovich LR, Goeree RA, Leung KM, Woods CR, et al. Community-based intervention to optimise falls risk management: a randomised controlled trial. Age Ageing. 2009;38(6):724-30. Study quality. [pmid: 19767629].
18 Clark F, Azen SP, Carlson M, Mandel D, LaBree L, Hay J, et al. Embedding health-promoting changes into the daily lives of independent-living older adults: long-term follow-up of occupational therapy intervention. J Gerontol B Psychol Sci Soc Sci. 2001;56(1):60-3. Study relevance.
19 Clarke M, Clarke SJ, Jagger C. Social intervention and the elderly: a randomized controlled trial. Am J Epidemiol. 1992;136(12):1517-23. Study relevance. [pmid: 1288281].
20 Clemson L, Cumming RG, Kendig H, Swann M, Heard R, Taylor K. The effectiveness of a community-based program for reducing the incidence of falls in the elderly: a randomized trial. J Am Geriatr Soc. 2004;52(9):1487-94. Study relevance. [pmid: 15341550].
21 Counsell SR, Callahan CM, Buttar AB, Clark DO, Frank KI. Geriatric Resources for Assessment and Care of Elders (GRACE): a new model of primary care for low-income seniors. J Am Geriatr Soc. 2006;54(7):1136-41. No relevant outcomes. [pmid: 16866688].
22 Courtney M, Edwards H, Chang A, Parker A, Finlayson K, Hamilton K. Fewer emergency readmissions and better quality of life for older adults at risk of hospital readmission: a randomized controlled trial to determine the effectiveness of a 24-week exercise and telephone follow-up program. J Am Geriatr Soc. 2009;57(3):395-402. No relevant outcomes. [pmid: 19245413].
23 Crotty M, Whitehead C, Miller M, Gray S. Patient and caregiver outcomes 12 months after home-based therapy for hip fracture: a randomized controlled trial. Arch Phys Med Rehabil. 2003;84(8):1237-9. Study relevance. [pmid: 12917867].
24 Cunliffe AL, Gladman JR, Husbands SL, Miller P, Dewey ME, Harwood RH. Sooner and healthier: a randomised controlled trial and interview study of an early discharge rehabilitation service for older people. Age Ageing. 2004;33(3):246-52. Setting. [pmid: 15082429].
25 Cutchin MP, Coppola S, Talley V, Svihula J, Catellier D, Shank KH. Feasibility and effects of preventive home visits for at-risk older people: design of a randomized controlled trial. BMC Geriatr. 2009;9:54. No relevant outcomes. [pmid: 19958547].
26 Daniels R, van Rossum E, de Witte L, Kempen GI, van den Heuvel W. Interventions to prevent disability in frail community-dwelling elderly: a systematic review. BMC Health Serv Res. 2008;8:278. Study relevance. [pmid: 19115992].
27 Dunn RB, Lewis PA, Vetter NJ, Guy PM, Hardman CS, Jones RW. Health visitor intervention to reduce days of unplanned hospital re-admission in patients recently discharged from geriatric wards: the results of a randomised controlled study. Arch Gerontol Geriatr. 1994;18(1):15-23. Setting. [pmid: 15374310].
28 Edwards M. Hospital and home rehabilitation did not differ for functional competence in activities of daily living. Evid Based Nurs. 2009;12(3):84. Study design. [pmid: 19553421].
29 Eekhof J, De Bock G, Schaapveld K, Springer M. Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. 2000;17(4):329-33. No relevant outcomes. [pmid: 10934182].
30 Eklund K, Sjöstrand J, Dahlin-Ivanoff S. A randomized controlled trial of a health-promotion programme and its effect on ADL dependence and self-reported health problems for the elderly visually impaired. Scand J Occup Ther. 2008;15(2):68-74. Study relevance. [pmid: 17852958].
31 Engelhardt JB, Rizzo VM, Della Penna RD, Feigenbaum PA, Kirkland KA, Nicholson JS, et al. Effectiveness of care coordination and health counseling in advancing illness. Am J Manag Care. 2009;15(11):817-25. Population. [pmid: 19895186].
32 Fabacher D, Josephson K, Pietruszka F, Linderborn K, Morley JE, Rubenstein LZ. An in-home preventive assessment program for independent older adults: a randomized controlled trial. J Am Geriatr Soc. 1994;42(6):630-8. Study quality. [pmid: 8201149].
33 Fairhall N, Aggar C, Kurrle SE, Sherrington C, Lord S, Lockwood K, et al. Frailty Intervention Trial (FIT). BMC Geriatr. 2008;8:27. No relevant outcomes. [pmid: 18851754].
34 Finkelstein SM, Speedie SM, Zhou X, Ratner E, Potthoff S. VALUE: Virtual Assisted Living Umbrella for the Elderly—user patterns. Conf Proc IEEE Eng Med Biol Soc. 2006;1:3294-6. Study relevance. [pmid: 17946174].
35 Fletcher AE, Price GM, Ng ES, Stirling SL, Bulpitt CJ, Breeze E, et al. Population-based multidimensional assessment of older people in UK general practice: a cluster-randomised factorial trial. Lancet. 2004;364(9446):1667-77. Study design. [pmid: 15530627].
36 Fletcher AE, Jones DA, Bulpitt CJ, Tulloch AJ. The MRC trial of assessment and management of older people in the community: objectives, design and interventions. BMC Health Serv Res. 2002;2(1):21. Study design.
37 Forbes DA. An educational programme for primary healthcare providers improved functional ability in older people living in the community. Evid Based Nurs. 2005;8(4):122. Study design. [pmid: 16247903].
38 Ford AB, Katz S, Downs TD, Adams M. Results of long-term home nursing: the influence of disability. J Chronic Dis. 1971;24(9):591-6. Study relevance. [pmid: 5158770].
39 Fox PJ, Breuer W, Wright JA. Effects of a health promotion program on sustaining health behaviors in older adults. Am J Prev Med. 1997;13(4):257-64. Study design. [pmid: 9236961].
40 Friedman B, Wamsley BR, Liebel DV, Saad ZB, Eggert GM. Patient satisfaction, empowerment, and health and disability status effects of a disease management-health promotion nurse intervention among Medicare beneficiaries with disabilities. Gerontologist. 2009;49(6):778-92. Study quality. [pmid: 19587109].
41 Gates S, Fisher JD, Cooke MW, Carter YH, Lamb SE. Multifactorial assessment and targeted intervention for preventing falls and injuries among older people in community and emergency care settings: systematic review and meta-analysis. BMJ. 2008;336(7636):130-3. Study relevance. [pmid: 18089892].
42 German PS, Burton LC, Shapiro S, Steinwachs DM, Tsuji I, Paglia MJ, et al. Extended coverage for preventive services for the elderly: response and results in a demonstration population. Am J Public Health. 1995;85(3):379-86. Study relevance. [pmid: 7892923].
43 Gitlin LN, Hauck WW, Dennis MP, Winter L, Hodgson N, Schinfeld S. Long-term effect on mortality of a home intervention that reduces functional difficulties in older adults: results from a randomized trial. J Am Geriatr Soc. 2009;57(3):476-81. Study relevance. [pmid: 19187417].
44 Gitlin LN, Winter L, Dennis MP, Hauck WW. Variation in response to a home intervention to support daily function by age, race, sex, and education. J Gerontol A Biol Sci Med Sci. 2008;63(7):745-50. Study relevance. [pmid: 18693230].
45 Graves N, Courtney M, Edwards H, Chang A, Parker A, Finlayson K. Cost-effectiveness of an intervention to reduce emergency re-admissions to hospital among older patients. PLoS One. 2009;4(10):e7455. Study relevance. [pmid: 19829702].
46 Gunner-Svensson F, Ipsen J, Olsen J, Waldstrøm B. Prevention of relocation of the aged in nursing homes. Scand J Prim Health Care. 1984;2(2):49-56. Study relevance. [pmid: 6544449].
47 Hall N. Randomized trial of a health promotion program for frail elders. Can J Aging. 1992;11:72-91. Study design.
48 Hansen FR, Poulsen H, Sørensen KH. A model of regular geriatric follow-up by home visits to selected patients discharged from a geriatric ward: a randomized controlled trial. Aging (Milano). 1995;7(3):202-6. Study relevance. [pmid: 8547378].
49 Hansen FR, Spedtsberg K, Schroll M. Geriatric follow-up by home visits after discharge from hospital: a randomized controlled trial. Age Ageing. 1992;21(6):445-50. Study relevance. [pmid: 1471584].
50 Hendriks MR, Evers SM, Bleijlevens MH, van Haastregt JC, Crebolder HF, van Eijk JT. Cost-effectiveness of a multidisciplinary fall prevention program in community-dwelling elderly people: a randomized controlled trial. Int J Technol Assess Health Care. 2008;24(2):193-202. No relevant outcomes. [pmid: 18400123].
51 Hopp F, Woodbridge P, Subramanian U, Copeland L, Smith D, Lowery J. Outcomes associated with a home care telehealth intervention. Telemed J E Health. 2006;12(3):297-307. Study relevance. [pmid: 16796497].
52 Hørdam B, Sabroe S, Pedersen PU, Mejdahl S, Søballe K. Nursing intervention by telephone interviews of patients aged over 65 years after total hip replacement improves health status: a randomised clinical trial. Scand J Caring Sci. 2010;24(1):94-100. Study relevance. [pmid: 19422632].
53 Hornbrook MC, Stevens VJ, Wingfield DJ, Hollis JF, Greenlick MR, Ory MG. Preventing falls among community-dwelling older persons: results from a randomized trial. Gerontologist. 1994;34(1):16-23. Study relevance. [pmid: 8150304].
54 Hughes SL, Weaver FM, Giobbie-Hurder A, Manheim L, Henderson W, Kubal JD, et al. Department of Veterans Affairs Cooperative Study Group on Home-Based Primary Care. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. 2000;284(22):2877-85. Study relevance. [pmid: 11147984].
55 Huss A, Stuck AE, Rubenstein LZ, Egger M, Clough-Gorr KM. Multidimensional preventive home visit programs for community-dwelling older adults: a systematic review and meta-analysis of randomized controlled trials. J Gerontol A Biol Sci Med Sci. 2008;63(3):298-307. Study relevance. [pmid: 18375879].
56 Jitapunkul S. A randomised controlled trial of regular surveillance in Thai elderly using a simple questionnaire administered by non-professional personnel. J Med Assoc Thai. 1998;81(5):352-6. Setting. [pmid: 9623035].
57 Kerse NM, Flicker L, Jolley D, Arroll B, Young D. Improving the health behaviours of elderly people: randomised controlled trial of a general practice education programme. BMJ. 1999;319(7211):683-7. Study relevance. [pmid: 10480825].
58 Kingston P, Jones M, Lally F, Crome P. Older people and falls: a randomized controlled trial of a health visitor (HV) intervention. Rev Clin Gerontol. 2001;11(3):209-14. Study relevance.
59 Kirchberger I, Meisinger C, Seidl H, Wende R, Kuch B, Holle R. Nurse-based case management for aged patients with myocardial infarction: study protocol of a randomized controlled trial. BMC Geriatr. 2010;10(1):29. Population. [pmid: 20507567].
60 Kircher TT, Wormstall H, Müller PH, Schwärzler F, Buchkremer G, Wild K, et al. A randomised trial of a geriatric evaluation and management consultation services in frail hospitalised patients. Age Ageing. 2007;36(1):36-42. Setting. [pmid: 17264136].
61 Kono A, Fujita T, Tsumura C, Kondo T, Kushiyama K, Rubenstein LZ. Preventive home visit model targeted to specific care needs of ambulatory frail elders: preliminary report of a randomized trial design. Aging Clin Exp Res. 2009;21(2):167-73. No relevant outcomes. [pmid: 19448389].
62 Kronborg C, Vass M, Lauridsen J, Avlund K. Cost effectiveness of preventive home visits to the elderly: economic evaluation alongside randomized controlled study. Eur J Health Econ. 2006;7(4):238-46. Study design. [pmid: 16763802].
63 Lamb SE. Multidisciplinary assessment of elderly people with a history of multiple falls reduces the risk of further falls. Aust J Physiother. 2009;55(2):139. Study design. [pmid: 19534015].
64 Latour CH, Bosmans JE, van Tulder MW, de Vos R, Huyse FJ, de Jonge P, et al. Cost-effectiveness of a nurse-led case management intervention in general medical outpatients compared with usual care: an economic evaluation alongside a randomized controlled trial. J Psychosom Res. 2007;62(3):363-70. No relevant outcomes. [pmid: 17324688].
65 Latour CH, de Vos R, Huyse FJ, de Jonge P, van Gemert LA, Stalman WA. Effectiveness of post-discharge case management in general-medical outpatients: a randomized, controlled trial. Psychosomatics. 2006;47(5):421-9. No relevant outcomes. [pmid: 16959931].
66 Leff B, Reider L, Frick KD, Scharfstein DO, Boyd CM, Frey K, et al. Guided care and the cost of complex healthcare: a preliminary report. Am J Manag Care. 2009;15(8):555-9. Study relevance. [pmid: 19670959].
67 Leung AC, Liu C, Chow NW, Chi I. Cost-benefit analysis of a case management project for the community-dwelling frail elderly in Hong Kong. J Appl Gerontol. 2004;23:70-85. Study quality.
68 Lewin G, Vandermeulen S. A non-randomised controlled trial of the Home Independence Program (HIP): an Australian restorative programme for older home-care clients. Health Soc Care Community. 2010;18(1):91-9. Study design. [pmid: 19674125].
69 Littbrand H, Lundin-Olsson L, Gustafson Y, Rosendahl E. The effect of a high-intensity functional exercise program on activities of daily living: a randomized controlled trial in residential care facilities. J Am Geriatr Soc. 2009;57(10):1741-9. Setting. [pmid: 19702617].
70 Martin F, Oyewole A, Moloney A. A randomized controlled trial of a high support hospital discharge team for elderly people. Age Ageing. 1994;23(3):228-34. Setting. [pmid: 8085509].
71 Melin AL, Bygren LO. Efficacy of the rehabilitation of elderly primary health care patients after short-stay hospital treatment. Med Care. 1992;30(11):1004-15. Study design. [pmid: 1331632].
72 Melin AL, Håkansson S, Bygren LO. The cost-effectiveness of rehabilitation in the home: a study of Swedish elderly. Am J Public Health. 1993;83(3):356-62. Study design. [pmid: 8438972].
73 Melis RJ, van Eijken MI, van Achterberg T, Teerenstra S, Vernooij-Dassen MJ, van de Lisdonk EH, et al. The effect on caregiver burden of a problem-based home visiting programme for frail older people. Age Ageing. 2009;38(5):542-7. No relevant outcomes. [pmid: 19574322].
74 Meng H, Friedman B, Wamsley BR, Mukamel D, Eggert GM. Effect of a consumer-directed voucher and a disease-management-health-promotion nurse intervention on home care use. Gerontologist. 2005;45(2):167-76. No relevant outcomes. [pmid: 15799981].
75 Meng H, Wamsley B, Liebel D, Dixon D, Eggert G, Van Nostrand J. Urban-rural differences in the effect of a Medicare health promotion and disease self-management program on physical function and health care expenditures. Gerontologist. 2009;49(3):407-17. Study relevance. [pmid: 19401357].
76 Naylor MD, Brooten D, Campbell R, Jacobsen BS, Mezey MD, Pauly MV, et al. Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. JAMA. 1999;281(7):613-20. Setting. [pmid: 10029122].
77 Newcomer R, Maravilla V, Faculjak P, Graves MT. Outcomes of preventive case management among high-risk elderly in three medical groups: a randomized clinical trial. Eval Health Prof. 2004;27(4):323-48. Study relevance. [pmid: 15492046].
78 Nikolaus T, Specht-Leible N, Bach M, Oster P, Schlierf G. A randomized trial of comprehensive geriatric assessment and home intervention in the care of hospitalized patients. Age Ageing. 1999;28(6):543-50. Setting. [pmid: 10604506].
79 Nikolaus T, Bach M. Preventing falls in community-dwelling frail older people using a home intervention team (HIT): results from the randomized Falls-HIT trial. J Am Geriatr Soc. 2003;51(3):300-5. Setting. [pmid: 12588572].
80 Peeters GM, de Vries OJ, Elders PJ, Pluijm SM, Bouter LM, Lips P. Prevention of fall incidents in patients with a high risk of falling: design of a randomised controlled trial with an economic evaluation of the effect of multidisciplinary transmural care. BMC Geriatr. 2007;7:15. No relevant outcomes. [pmid: 17605771].
81 Rubenstein LV, Calkins DR, Young RT, Cleary PD, Fink A, Kosecoff J, et al. Improving patient function: a randomized trial of functional disability screening. Ann Intern Med. 1989;111(10):836-42. Population. [pmid: 2683917].
82 Rubenstein LZ, Alessi CA, Josephson KR, Trinidad Hoyl M, Harker JO, Pietruszka FM. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. 2007;55(2):166-74. Study design. [pmid: 17302651].
83 Rubin CD, Sizemore MT, Loftis PA, de Mola NL. A randomized, controlled trial of outpatient geriatric evaluation and management in a large public hospital. J Am Geriatr Soc. 1993;41(10):1023-8. Study relevance. [pmid: 8409145].
84 Scholes D, LaCroix AZ, Wagner EH, Grothaus LC, Hecht JA. Tracking progress toward national health objectives in the elderly: what do restricted activity days signify?. Am J Public Health. 1991;81(4):485-8. No relevant outcomes. [pmid: 2003629].
85 Scott JC, Conner DA, Venohr I, Gade G, McKenzie M, Kramer AM, et al. Effectiveness of a group outpatient visit model for chronically ill older health maintenance organization members: a 2-year randomized trial of the cooperative health care clinic. J Am Geriatr Soc. 2004;52(9):1463-70. Study relevance. [pmid: 15341547].
86 Shapiro A, Taylor M. Effects of a community-based early intervention program on the subjective well-being, institutionalization, and mortality of low-income elders. Gerontologist. 2002;42(3):334-41. Study quality. [pmid: 12040135].
87 Shaw FE, Bond J, Richardson DA, Dawson P, Steen IN, McKeith IG, et al. Multifactorial intervention after a fall in older people with cognitive impairment and dementia presenting to the accident and emergency department: randomised controlled trial. BMJ. 2003;326(7380):73. Population. [pmid: 12521968].
88 Shyu YI, Liang J, Wu CC, Su JY, Cheng HS, Chou SW, et al. A pilot investigation of the short-term effects of an interdisciplinary intervention program on elderly patients with hip fracture in Taiwan. J Am Geriatr Soc. 2005;53(5):811-8. Setting. [pmid: 15877556].
89 Sørensen KH, Sivertsen J. Follow-up three years after intervention to relieve unmet medical and social needs of old people. Compr Gerontol B. 1988;2(2):85-91. Study quality. [pmid: 3228801].
90 Spice CL, Morotti W, George S, Dent TH, Rose J, Harris S, et al. The Winchester falls project: a randomised controlled trial of secondary prevention of falls in older people. Age Ageing. 2009;38(1):33-40. Study design. [pmid: 18829689].
91 Steinberg M, Cartwright C, Peel N, Williams G. A sustainable programme to prevent falls and near falls in community dwelling older people: results of a randomised trial. J Epidemiol Community Health. 2000;54(3):227-32. No relevant outcomes. [pmid: 10746118].
92 Stewart S, Harvey I, Poland F, Lloyd-Smith W, Mugford M, Flood C. Are occupational therapists more effective than social workers when assessing frail older people? Results of CAMELOT, a randomised controlled trial. Age Ageing. 2005;34(1):41-6. Study design. [pmid: 15525654].
93 Stewart S, Pearson S, Luke CG, Horowitz JD. Effects of home-based intervention on unplanned readmissions and out-of-hospital deaths. J Am Geriatr Soc. 1998;46(2):174-80. Study relevance. [pmid: 9475445].
94 Stock R, Mahoney ER, Reece D, Cesario L. Developing a senior healthcare practice using the chronic care model: effect on physical function and health-related quality of life. J Am Geriatr Soc. 2008;56(7):1342-8. Study design. [pmid: 18503521].
95 Stuck AE, Siu AL, Wieland GD, Adams J, Rubenstein LZ. Comprehensive geriatric assessment: a meta-analysis of controlled trials. Lancet. 1993;342(8878):1032-6. Study relevance. [pmid: 8105269].
96 Stuck AE, Kharicha K, Dapp U, Anders J, von Renteln-Kruse W, Meier-Baumgartner HP, et al. Development, feasibility and performance of a health risk appraisal questionnaire for older persons. BMC Med Res Methodol. 2007;7:1. Study relevance. [pmid: 17217545].
97 Tinetti ME, Baker DI, Gottschalk M, Williams CS, Pollack D, Garrett P, et al. Home-based multicomponent rehabilitation program for older persons after hip fracture: a randomized trial. Arch Phys Med Rehabil. 1999;80(8):916-22. Study relevance. [pmid: 10453768].
98 Townsend J, Piper M, Frank AO, Dyer S, North WR, Meade TW. Reduction in hospital readmission stay of elderly patients by a community based hospital discharge scheme: a randomised controlled trial. BMJ. 1988;297(6647):544-7. Study relevance. [pmid: 2844356].
99 Trentini M, Semeraro S, Motta M. Effectiveness of geriatric evaluation and care: one-year results of a multicenter randomized clinical trial. Aging (Milano). 2001;13(5):395-405. Study relevance. [pmid: 11820714].
100 Tulloch AJ, Moore V. A randomized controlled trial of geriatric screening and surveillance in general practice. J R Coll Gen Pract. 1979;29(209):733-40. Study quality. [pmid: 536982].
101 van Haastregt JC. Preventing falls and mobility imparements in elderly people living in the community. Maastricht University. 2002. Study design.
102 van Haastregt JC, van Rossum E, Diederiks JP, de Witte LP, Voorhoeve PM, Crebolder HF. Process-evaluation of a home visit programme to prevent falls and mobility impairments among elderly people at risk. Patient Educ Couns. 2002;47(4):301-9. Study design. [pmid: 12135821].
103 van Hout HP, Nijpels G, van Marwijk HW, Jansen AP, Van’t Veer PJ, Tybout W, et al. Design and pilot results of a single blind randomized controlled trial of systematic demand-led home visits by nurses to frail elderly persons in primary care. BMC Geriatr. 2005;5:11. No relevant outcomes. [pmid: 16150147].
104 Vass M, Avlund K, Lauridsen J, Hendriksen C. Feasible model for prevention of functional decline in older people: municipality-randomized, controlled trial. J Am Geriatr Soc. 2005;53(4):563-8. Study relevance. [pmid: 15816999].
105 Vass M, Avlund K, Hendriksen C, Andersen CK, Keiding N. Preventive home visits to older people in Denmark: methodology of a randomized controlled study. Aging Clin Exp Res. 2002;14(6):509-15. Study design. [pmid: 12674492].
106 Vass M, Avlund K, Hendriksen C. Randomized intervention trial on preventive home visits to older people: baseline and follow-up characteristics of participants and non-participants. Scand J Public Health. 2007;35(4):410-7. Study relevance. [pmid: 17786805].
107 Vass M, Avlund K, Kvist K, Hendriksen C, Andersen CK, Keiding N. Structured home visits to older people: are they only of benefit for women? A randomised controlled trial. Scand J Prim Health Care. 2004;22(2):106-11. Study design. [pmid: 15255491].
108 Whitehead C, Wundke R, Crotty M, Finucane P. Evidence-based clinical practice in falls prevention: a randomised controlled trial of a falls prevention service. Aust Health Rev. 2003;26(3):88-97. No relevant outcomes. [pmid: 15368824].
109 Williams EI, Greenwell J, Groom LM. The care of people over 75 years old after discharge from hospital: an evaluation of timetabled visiting by Health Visitor Assistants. J Public Health Med. 1992;14(2):138-44. Study relevance. [pmid: 1325167].
110 Williams ME, Williams TF, Zimmer JG, Hall WJ, Podgorski CA. How does the team approach to outpatient geriatric evaluation compare with traditional care: a report of a randomized controlled trial. J Am Geriatr Soc. 1987;35(12):1071-8. No relevant outcomes. [pmid: 3119693].
111 Wong FK, Chow S, Chung L, Chang K, Chan T, Lee WM, et al. Can home visits help reduce hospital readmissions? Randomized controlled trial. J Adv Nurs. 2008;62(5):585-95. No relevant outcomes. [pmid: 18489451].
112 Wright K, Hazelett S, Jarjoura D, Allen K. The AD-LIFE trial: working to integrate medical and psychosocial care management models. Home Healthc Nurse. 2007;25(5):308-14. Setting. [pmid: 17495560].
113 Ziden L, Frandin K, Kreuter M. Home rehabilitation after hip fracture: a randomized controlled study on balance confidence, physical function and everyday activities. Clin Rehabil. 2008;22(12):1019-33. Study relevance. [pmid: 19052241].
114 Zijlstra G, van-Haastregt JC, van-Eijk JT, Kempen GI. Evaluating an intervention to reduce fear of falling and associated activity restriction in elderly persons: design of a randomised controlled trial. BMC Public Health. 2005;5:26. Study relevance. [pmid: 15780139].
115 Zimmer JG, Groth-Juncker A, McCusker J. A randomized controlled study of a home health care team. Am J Public Health. 1985;75(2):134-41. Population. [pmid: 3966617].