# Evidence Tables

Appendix B Table 1 Evidence Table: Population and Intervention Details for Trials With a Primary Purpose of Preventing Functional Decline

Appendix B Table 2 Evidence Table: Population and Intervention Details for Trials With a Primary Purpose Other Than Preventing Functional Decline