# Detailed Methods

## Analytic Framework and Key Questions

Building on the methods and approach of the 2009 USPSTF evidence review of interventions to prevent falls in older adults,1 we developed an analytic framework and formulated two key questions to guide our systematic review. The key questions were designed to evaluate the effectiveness and harms of primary care–relevant multifactorial assessment and management interventions in reducing disability and maintaining independence among community-dwelling older adults. Multifactorial assessment and management interventions are defined as a preventive strategy aimed at the identification and treatment of multidimensional geriatric risk factors. This strategy generally includes evaluation of physical functioning, with or without assessment of cognitive functioning or social problems. Multifactorial assessment and management interventions for this review must include a clinical assessment of two or more domains of functioning, generally supplemented by assessment of disability-related or general geriatric risk factors and/or conditions. The assessment results also must be used as the basis for ongoing management.

Key question 1: Do primary care–relevant multifactorial assessment and management interventions improve quality of life; reduce hospitalization, disability, or mortality; or maintain independent living in community-dwelling older adults?

Key question 2: What are the adverse effects associated with these multifactorial assessment and management interventions (e.g., paradoxical increase in falls, hospitalization, or institutionalization)?

## Search Strategy

Incorporating a published strategy,2 we used two recent systematic reviews as a foundation for our literature search.1,3 The first review was conducted for the USPSTF and addressed multifactorial assessment and management interventions to prevent falls in older adults.1 The second review was a comprehensive systematic review that included 87 trials of “complex interventions” to improve physical functioning and maintain independent living in older adults published before 2005.^3^ We reviewed all the full-text articles of both the included and excluded trials from these two reviews, as well as checked the reference listing for included trials from several other relevant reviews.3–7 We then conducted a search for both key questions in MEDLINE, the Cochrane Central Registry of Controlled Trials, and the Cumulative Index to Nursing and Allied Health Literature from 2004 through June 3, 2010 (see Appendix A Table 1 for the search string).

Appendix A Table 1 Search String

1. geriatric assessment.sh.; 2. health services for the aged.sh.; 3. preventive health services.sh.; 4. community health services.sh.; 5. community health nursing.sh.; 6. home care services.sh.; 7. preventive medicine.sh.; 8. nursing assessment.sh.; 9. disability evaluation.sh.; 10. house calls.sh.; 11. (house adj5 calls).tw.; 12. home-based.tw.; 13. (geriatric$ adj5 assess$).tw.; 14. (home adj5 intervention$).tw.; 15. (home adj5 visit$).tw.; 16. (home adj5 assessment$).tw.; 17. (preventive adj5 program$).tw.; 18. health visitor$.tw.; 19. (preventive adj5 care).tw.; 20. (health adj5 assessment$).tw.; 21. (preventive adj5 medicine).tw.; 22. health promotion.sh. (24649); 23. (health adj5 promotion).tw.; 24. occupational therapy.sh.; 25. (occupation$ adj5 therap$).tw.; 26. counseling.sh.; 27. psychotherapy.sh.; 28. social work.sh.; 29. (behavior$ adj5 modif$).tw.; 30. Relaxation Therapy/; 31. (behaviour$ adj5 modif$).tw.; 32. (behavior$ adj5 therap$).tw.; 33. (behaviour$ adj5 therap$).tw.; 34. (cognitive adj5 therap$).tw.; 35. (relax$ adj5 program$).tw.; 36. (social adj5 program$).tw.; 37. (social adj5 work$).tw.; 38. counseling.tw.; 39. counselling.tw.; 40. psychotherap$.tw.; 41. (physical$ adj5 exercise).tw.; 42. (physical$ adj5 fitness).tw.; 43. (exercise adj5 program$).tw.; 44. (exercise adj5 behavi$).tw.; 45. (physical$ adj5 activit$).tw.; 46. exercise therapy.sh.; 47. physical fitness.sh.; 48. walking.sh.; 49. tai chi.tw.; 50. tai ji.sh.; 51. or/1–50; 52. activities of daily living.sh.; 53. hospitalization.sh.; 54. institutionalization.sh.; 55. (independent$ adj5 living).tw.; 56. (independent$ adj5 life).tw.; 57. function$.tw.; 58. disabilit$.tw.; 59. balance.tw.; 60. proprioception.tw.; 61. hospitalisation.tw.; 62. hospitalization.tw.; 63. institutionali$.tw.; 64. (activit$ adj5 daily).tw.; 65. ADL.tw.; 66. (nursing adj5 home).tw.; 67. health status.sh.; 68. aging.sh.; 69. quality of life.sh.; 70. aging.tw.; 71. locomot$.tw.; 72. mobility.tw.; 73. (quality adj5 life).tw.; 74. or/52–73; 75. 51 and 74; 76. (“Aged, 80 and over” or Aged).sh.; 77. Frail Elderly.sh.; 78. elderly.tw.; 79. elders.tw.; 80. geriatric$.tw.; 81. (old adj5 people).tw.; 82. or/76–81; 83. 75 and 82; 84. (clinical trial or controlled clinical trial or randomized controlled trial or meta-analysis).sh.; 85. meta-analysis as topic.sh.; 86. (clinical trials as topic or controlled clinical trials as topic or randomized controlled trials as topic).sh.; 87. (control$ adj3 trial$).tw.; 88. random$.tw.; 89. clinical trial$.tw.; 90. or/84–89; 91. 83 and 90; 92. exp animal/not human/; 93. 91 not 92; 94. limit 93 to english language; 95. limit 94 to yr=“2004 – 2010”; 96. remove duplicates from 95; 97. from 96 keep 1–500

### Inclusion and Quality Criteria

Two investigators independently reviewed all abstracts and articles against inclusion and exclusion criteria (see Appendix A Table 2 for the inclusion and exclusion criteria) and critically appraised all included articles using design-specific criteria and USPSTF methods.8 The USPSTF has defined a three-category quality rating of “good,” “fair,” and “poor” based on specific criteria (see Appendix A Table 3 for quality criteria). Discrepancies in quality ratings were resolved by consultation with a third investigator. All trials rated as poor quality were excluded from the review.

Appendix A Table 2 Inclusion Criteria

Populations | Include | Ambulatory community-dwelling adults age 65 years or older, including those post-hospital or emergency department discharge Studies with samples age 65 years or older on average or studies that present results for adults age 65 years or older separately
Populations | Exclude | Studies limited to persons in nursing homes or care homes, rehabilitation centers, or other long-term care facilities
Settings | Include | Ambulatory care, home-based interventions, primary care, generalizable to U.S. practice, and primary care–referable settings in countries listed as “high” (>0.90) on the United Nations Development Index (Australia, Austria, Belgium, Canada, China, Denmark, Finland, France, Germany, Greece, Hong Kong, Iceland, Ireland, Israel, Italy, Japan, Korea, Luxembourg, Netherlands, New Zealand, Norway, Portugal, Singapore, Slovenia, Spain, Sweden, Switzerland, Taiwan, United Kingdom, and United States)
Settings | Exclude | Hospitals, nursing homes, rehabilitation centers, and other long-term care facilities
Interventions | Include | Multifactorial assessments and management; includes a clinical assessment of two or more domains of functioning, generally supplemented by assessment of disability-related or general geriatric risk factors and/or conditions, with assessment results used as a basis for remedial management Either conducted in a primary care setting or judged to be feasible in primary care or be primary care–referable:; - Involve individual-level identification and management of health (and social) problems; - Usually involve primary care physicians, other physicians, nurses, nurse practitioners, physician assistants, or related clinical staff (e.g., health educators, other counselors), or the intervention is seen as connected to the health care system by the participant; - Individual or small group format (15 people or less, generally does not primarily involve group-level interventions outside the primary care settings or more than 8 group sessions); - Located anywhere, as long as linked to primary care; Or, must be primary care–referable, such that the intervention needs to be conducted as part of a health care setting or be widely available for referral in most communities
Interventions | Exclude | Community, nonreferral:; - Community programs (e.g., senior residence programs); - Social marketing (e.g., media campaigns); - Policy (e.g., local and State public or health policy); Hospital-based and other institutional methods; model of care
Outcomes | Include | Hospitalization, institutionalization, disability (activities of daily living or instrumental activities of daily living), health related quality of life, and death Any harm (adverse effects)
Outcomes | Exclude | Less than 6 months of followup for outcomes
Study Designs | Include | Randomized, controlled trials Trials must have a control arm with no intervention, minimal intervention, or attention control English language only
Study Designs | Exclude | Nonrandomized trials, comparative effectiveness trials (i.e., without a control arm), case-control studies, nonsystematic reviews, cohort studies, and observational literature, including editorials, letters, or opinion pieces

Appendix A Table 3 Quality Criteria

Design | USPSTF Quality Rating Criteria9 | National Institute for Health and Clinical Excellence Methodology Checklists10
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - Study addresses an appropriate and clearly focused question; - Description of the methodology used is included; - Literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - Enough similarities between the studies selected to make combining them reasonable
Randomized, controlled trials | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - Study addresses an appropriate and clearly focused question; - Assignment of subjects to treatment groups is randomized; - Adequate concealment method is used; - Subjects and investigators are kept blind about treatment allocation; - Treatment and control groups are similar at the start of the trial; - Only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid, and reliable way; - Percentage of the individuals or clusters recruited into each treatment arm of the study who dropped out before the study was completed is reported; - All the subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - When the study is carried out at more than one site, results are comparable for all sites

### Data Abstraction and Outcomes

One investigator abstracted data from included trials into evidence tables and a second investigator reviewed abstracted data for accuracy. We abstracted prespecified study details into evidence tables that included the following items: study purpose, setting (location, target population, recruitment strategy), population characteristics (study inclusion and exclusion criteria, participant age, sex, race/ethnicity, and socioeconomic status, as defined by income or education), baseline health status (self-rated health, disability, previous hospitalizations, living situation, and cognitive impairment) and high-risk categorization (as defined by the trial), intervention characteristics (assessment components and delivery approach, management components and personnel), and outcomes. Relevant outcomes for abstraction included any measure of ADL or IADL (e.g., Katz or Lawton scale, SF-36 physical functioning domain) and any measure of HRQL (e.g., SF-12, SF-36, or EuroQol), in addition to falls, hospitalization, institutionalization, mortality, and adverse events (e.g., harms requiring unexpected medical attention).

Patient-reported outcomes: ADL, IADL, and HRQL. A variety of instruments were used for ADL, IADL, and HRQL. Some studies used more than one instrument to measure the same outcome, and author designations of the purpose of the instrument were not always clear or consistent across studies. We included any instrument that was consistent with measuring typical ADL or IADL, and consulted with a geriatrician when needed. We included any HRQL instrument. Often the instrument was not reported, but the authors detailed the questions in the methods of the article so we could determine if it measured traditional ADL, IADL, or HRQL domains. Briefly, we applied the following hierarchical decision rules to selecting functional ability and HRQL outcomes to be abstracted from each study, after conducting an audit of all instruments used to report these outcomes across all included studies. For ADL, IADL, and HRQL, a minimum of 6 months followup was required.

Typical ADLs included bathing, dressing, grooming, toileting, transferring, continence, feeding, mobility, and stairs. One ADL instrument was not carried over to the meta-analysis because we could not find any information indicating it was similar to the other ADL instruments used, specifically, the Chinese version of the Minimum Data Set–Home Care. When given a choice between a lesser known ADL instrument and the SF-36 physical functioning domain, the SF-36 was carried over to the meta-analysis instead of the other instrument. Likewise, when given a choice between the Barthel Index and the SF-36, the Barthel Index was carried over to the meta-analysis as determined by consensus. If a trial used a different instrument (not listed above) to measure functional status, we reviewed that instrument for comparability with other included instruments. As an example, one study11 used a component of the Sickness Impact Profile (SIP) as a measure of functional ability. Using a priori decision rules, we determined this instrument should represent HRQL. On examination, we determined the physical functioning dimension of the SIP to be much more extensive than the other included measures of ADL and more in line with the physical component score of the SF-36. Therefore, these results were not included in the ADL meta-analyses; however, they are captured in the master evidence table under HRQL.

Typical IADLs include telephoning, shopping, food preparation, housekeeping, laundry, transportation, medications, and finances. When given a choice between a lesser known IADL instrument and the SF-36, the SF-36 was carried over to the meta-analysis instead of the other instrument. Two IADL instruments were not carried over to the meta-analysis because we could not find any information indicating they were similar to the other IADL instruments used: social ADL and the Chinese version of the Minimum Data Set–Home Care (involvement and capacity).

When data on ADL or IADL outcomes seemed to have been measured but not reported, or reported in a format we could not use, we emailed the authors to request the data if the study was published after 2000. Many authors replied with additional data, and we included both published and unpublished data in the meta-analysis. Some trials used instruments that measured combined ADL and IADL. These data were not utilized in the meta-analysis, as deficits in ADL and IADL could not be teased apart from one another, although these combined outcomes were abstracted using the same methodology as for ADL and IADL.

For HRQL, we abstracted only overall or component scores (specifically, mental and physical component scores). If only selected domains (or subscales) were reported, we did not abstract these at the risk of selective reporting bias. Except when we determined that a HRQL tool (as designated by study authors) fit within our schema as a measure of function, we did not limit data abstraction according to the type of HRQL instrument used.

Dichotomous outcomes were also abstracted for ADL, IADL, and HRQL. The method the authors used to report data was collected in the evidence table. No further manipulations of these data were made.

Other outcomes: falls, hospitalizations, institutionalizations, and mortality. The number of fallers, number hospitalized, and number institutionalized at a minimum of 6 months followup and at each time point thereafter for the intervention and control groups were abstracted from each study. If raw numbers were not available, we abstracted any odds ratios or risk ratios. For fallers, we looked for the number of participants who fell over the course of the study and the number analyzed for the intervention and control groups. For institutionalizations, we looked for the number of participants who were institutionalized and the number randomized to the intervention and control groups. The number of participants who died within a minimum of 12 months followup and at each time point thereafter in the intervention and control groups was abstracted from each study. For mortality, we looked for the number of participants who died over the course of the study and the number randomized to the intervention and control groups.

### Data Analyses

Clinical heterogeneity. Given the clinical heterogeneity associated with the populations selected and study characteristics, we identified a series of explanatory variables from previous research and from our own observations of variability between studies to explore in synthesizing the results. In addition to the categorizing variables, study purpose, and trial country, we considered other potential explanatory variables, including: mean age of trial population, baseline frailty/risk status of the population, baseline functional status of the control group, control group mortality rate, applicability of trial to current U.S. setting, comprehensiveness of the management delivered following multifactorial assessment, whether geriatric expertise was used in the assessment and management, intensity of the interventions, year of trial publication, and quality of trial.

To understand the clinical heterogeneity of the populations included in the trials, we grouped trials by health status, frailty, or risk for functional decline of the trial population, using four separate approaches: 1) mean age, 2) a three-level composite measure to approximate frailty (which included age, self-rated health, and loss/dependency of one or more ADLs or IADLs), 3) baseline functional status of the control group (based on ADL and IADL, if reported, and categorized into low, medium, and high tertiles for each instrument used), and 4) control group mortality rate at 12 months. None of these approaches were informative.

To understand the clinical heterogeneity of the interventions evaluated, we grouped trials by applicability to current care in the United States, intervention comprehensiveness, geriatric expertise involvement, and intervention intensity:

1. Applicability of the intervention was based on whether the current health care system had comparable health professionals, mechanism to pay for service, and adequate access to the type of service. Highly applicable interventions used interventions and services currently available in the U.S. health care system and a mechanism to pay for these services. Lowly applicable interventions used health professionals not currently available in the U.S. health care system, services not generally available, and no reimbursement mechanism for the services being delivered.
2. Intervention comprehensiveness was categorized as low, moderate, or high. Low comprehensiveness management included feedback of assessment results to the patient and primary care physician, moderate comprehensiveness included some additional management as part of the intervention (e.g., referrals to specialists), and high comprehensiveness included full management of identified risks during multifactorial assessment as part of the intervention.
3. Geriatric expertise involvement was based on whether a clinician with geriatric expertise (e.g., geriatrician, geriatric nurse practitioner) conducted the assessment and/or was involved in the management.
4. Intensity of the intervention was measured by the number, frequency, and duration of the assessments and management contacts with each participant, as well as the overall duration of the entire intervention.

We also ordered trials by year of publication and grouped trials by quality to determine if these variables had any effect on any of the outcomes. None of these explanatory variables helped explain differences in results when plotted or reduced statistical heterogeneity when examined in meta-regression or through stratified analysis. We therefore undertook a novel approach to categorize studies according to primary intent (intervention focused on preventing functional decline) as opposed to secondary intent (primarily focused on related issues, such as reducing utilization or improving comprehensive health care delivery) and according to setting (United States vs. non-United States). Given the large differences in health care delivery systems and financing between countries, including variation in how much social services are integrated with medical care, we judged that results for the United States would be most applicable for this review.

To categorize each study’s purpose related to functional decline prevention, one investigator considered the stated purpose of the study (i.e., if the stated primary aim was to prevent functional decline or if the population was selected based on their functional status), the outcomes assessed (i.e., were measures of functional ability assessed), and whether the stated primary study outcomes were functional ability measures. At least two of three of these factors categorized a study’s primary purpose to be prevention of functional decline. Study purpose categorizations were examined by another investigator and an outside geriatric expert for consistency and accuracy.

Within the strata of study purpose and setting, we also looked at interventions based on authors’ descriptions (i.e., comprehensive geriatric assessment, home visit care, primary care redesign, and falls prevention). Studies that did not clearly fit into one of these research streams were described briefly and not grouped (e.g., senior center disability prevention/exercise program, geriatric resource team assisting a health maintenance organization physician to change practice/outcomes, screening/case findings with physician for functional issues prior to physician visit, physical function performance assessments with feedback to the patient/physician). These intervention groupings were not utilized further in the analysis or synthesis of the results.

Quantitative pooling of outcomes. We conducted meta-analyses to summarize data and obtain more precise estimates on outcomes that were reported by trials homogeneous enough to provide a meaningful combined estimate. For all outcomes in the meta-analysis, we pooled data reported for followup time points of 6 to 18 months for the meta-analysis (except mortality, for which we only pooled 12 to 18 months). If two time points were available to pool in the 6 to 18 month range, we preferentially used 12-month data. If a lesser and greater time point from 12 months was available, we preferred the longest followup time. Longer-term followup data, between 24 and 39 months, was pooled for meta-analysis when available. To ensure uniformity among reported outcomes, we undertook multiple data manipulations to compute similar data across trials for each outcome, including maintaining a consistent directionality in functional measures, with higher numbers indicating better function. Continuous (rather than dichotomous) outcomes were most consistently reported for functional outcomes, while other outcomes (e.g., fallers, hospitalizations, institutionalization, and mortality) were primarily dichotomous.

For continuous ADL and IADL outcomes, we only included trials with a primary purpose of preventing functional decline. We abstracted either the mean or the standard deviation at baseline and followup times, the mean change or the standard deviation between baseline and followup times for both the intervention and control groups, or a mean difference in change and standard error between baseline and followup times between the intervention and control group. When the preferred measure of dispersion was not available, it was calculated from the provided information, such as the confidence interval or p value. If only followup mean values from a model adjusted for baseline values of the outcome of interest were reported, they were used as a mean change from baseline. Adjusting for baseline values at followup or subtracting baseline values at followup are both acceptable methods to use to adjust for baseline differences.12 We performed our meta-analyses using measures adjusted for baseline differences. Additionally, to ensure uniformity, we determined that a higher score would always indicate a more desirable level of functioning or quality of life for the ADL, IADL, and HRQL outcomes. Therefore, a score needed to be reversed if a higher score indicated poorer functioning. If mean values at baseline and followup were presented for groups with the undesired directionality, then the data were coded in the meta-analysis table to reverse the directionality. If mean change in scores were presented for both groups at followup and the directionality was the undesired direction, then the sign of the mean change was reversed (i.e., a negative sign was added to the change). If a mean difference in change in score was presented and the directionality of the instrument was not in the desired direction, no change was necessary.

ADL and IADL outcomes were combined using the SMD (Hedges’ g statistic), as they were measured using different instruments. We conducted three separate analyses for these functional ability outcome measures: 1) ADL only, 2) IADL only, and 3) ADL and/or IADL. For the ADL and/or IADL analysis, if a trial reported more than one functional outcome, we chose the combined (ADL/IADL) measure (first choice) over the IADL measure (second choice), and the IADL measure over the ADL measure (third choice). In approximately 50 percent of cases, we had to perform some calculation to incorporate reported data into our meta-analyses. All calculations were double-checked for accuracy. All data were combined using a random effects model.13 While dichotomous ADL and IADL outcomes were also abstracted, we did not combine them due to the relatively sparse reporting and variation in thresholds for dichotomization. We did not conduct meta-analyses for HRQL outcomes, given the relatively few trials reporting similar HRQL measures.

For binary outcomes (i.e., falls, hospitalizations, institutionalizations, and mortality), the number of events and total sample size for intervention and control groups were abstracted and combined using risk ratio. We used only the most intensive intervention arm in the meta-analyses for trials with multiple intervention arms. All outcomes were combined using a random effects model,13 except for institutionalizations, for which we used a fixed effects model. For institutionalizations, between-study heterogeneity was estimated to be zero.

Several trials used clustered randomization for both continuous and binary outcomes.14–21 For these trials, if a study reported an estimate adjusted for clustering effect, we used the reported estimate. If not, we adjusted the clustering effect by multiplying the standard error of the reported estimate by the square root of the design effect. Here, design effect = 1+(m-1)ρ, where m is the average cluster size and ρ is the intracluster correlation coefficient. No study reported an estimate of ρ, so we assumed a conservative estimate of 0.10 for ρ in the main analysis. We also performed sensitivity analyses assuming a range of plausible values for ρ, which indicated no differences in results.

We assessed the presence of statistical heterogeneity among the trials using standard chi-square tests and the magnitude of heterogeneity was estimated using the I^2^ statistic. We used meta-regression to explore heterogeneity and investigate whether the size of effect estimates or heterogeneity were associated with important study-level characteristics (e.g., study purpose, country, or quality). We also explored heterogeneity using forest plots ordered by year of trial publication and control group mortality rate, and stratified analyses by study purpose, country, and quality and intervention applicability and comprehensiveness. Tests of publication bias (whether the distribution of the effect sizes was symmetric with respect to the precision measure) were performed using funnel plots and Egger’s linear regression method22 when the number of trials was about 10 or more.23

All analyses were performed using Stata 10.0 (StataCorp, College Station, TX).