# REFERENCES

1 US Food and Drug Administration. Estrogen and Estrogen With Progestin Therapies for Postmenopausal Women. Silver Spring, MD. U.S. Food and Drug Administration. 2010. Accessed at http://www.fda.gov/Drugs/DrugSafety/InformationbyDrugClass/ucm135318.htm. 4 May 2012.
2 U.S. Preventive Services Task Force. Postmenopausal hormone replacement therapy for primary prevention of chronic conditions: recommendations and rationale. Ann Intern Med. 2002;137(10):834-9. [pmid: 12435221].
3 LeBlanc ES, Janowsky J, Chan BK, Nelson HD. Hormone replacement therapy and cognition: systematic review and meta-analysis. JAMA. 2001;285(11):1489-99. [pmid: 11255426].
4 Miller J, Chan BK, Nelson HD. Postmenopausal estrogen replacement and risk for venous thromboembolism: a systematic review and meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136(9):680-90. [pmid: 11992304].
5 Humphrey LL. Hormone Replacement Therapy and Breast Cancer, Systematic Evidence Review No. 14. Rockville, MD. Agency for Healthcare Research and Quality. 2002. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK42718/. 4 May 2012.
6 Nelson HD, Humphrey LL, Nygren P, et al. Postmenopausal hormone replacement therapy: scientific review. JAMA. 2002;288(7):872-81. [pmid: 12186605].
7 Nelson HD. Assessing benefits and harms of hormone replacement therapy: clinical applications. JAMA. 2002;288(7):882-4. [pmid: 12186606].
8 LeBlanc ES, Chan BK, Nelson HD. Hormone Replacement Therapy and Cognition, Systematic Evidence Review No. 13. Rockville, MD. Agency for Healthcare Research and Quality. 2002. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK42704/. 4 May 2012.
9 Humphrey LL, Takano LM, Chan BK. Postmenopausal Hormone Replacement Therapy and Cardiovascular Disease, Systematic Evidence Review No. 10. Rockville, MD. Agency for Healthcare Research and Quality. 2002. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK42645/. 4 May 2012.
10 Miller J, Chan BK, Nelson HD. Hormone Replacement Therapy and Risk of Venous Thromboembolism, Systematic Evidence Review No. 11. Rockville, MD. Agency for Healthcare Research and Quality. 2002. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK42678/. 4 May 2012.
11 Nelson HD. Hormone Replacement Therapy and Osteoporosis, Systematic Evidence Review No. 12. Rockville, MD. Agency for Healthcare Research and Quality. 2002. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK42693/. 4 May 2012.
12 Rossouw JE, Anderson GL, Prentice RL, et al. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results from the Women’s Health Initiative randomized controlled trial. JAMA. 2002;288(3):321-33. [pmid: 12117397].
13 U.S. Preventive Services Task Force. Hormone therapy for the prevention of chronic conditions in postmenopausal women: recommendations from the U.S. Preventive Services Task Force. Ann Intern Med. 2005;142(10):855-60. [pmid: 15897536].
14 Management of osteoporosis in postmenopausal women: 2010 position statement of the North American Menopause Society. Menopause. 2010;17(1):25-54. [pmid: 20061894].
15 American College of Obstetricians and Gynecologists Women’s Health Care Physicians. Executive Summary: hormone therapy. Obstet Gynecol. 2004;104(4 Suppl):1S-4. [pmid: 15458927].
16 American Academy of Family Physicians. Hormone Replacement Therapy. Leawood, KS. American Academy of Family Physicians. 2005. Accessed at http://www.aafp.org/online/en/home/clinical/exam/hormonereplacement.html. 4 May 2012.
17 American College of Obstetricians and Gynecologists. ACOG Committee Opinion No. 420, November 2008: hormone therapy and heart disease. Obstet Gynecol. 2008;112(5):1189-92. [pmid: 18978127].
18 Mosca L, Benjamin E, Berra K, et al. Effectiveness-based guidelines for the prevention of cardiovascular disease in women—2011 update: a guideline from the American Heart Association. Circulation. 2011;123(11):1243-62. [pmid: 21325087].
19 Canadian Task Force on Preventive Health Care. Hormone Replacement Therapy for the Primary Prevention of Chronic Diseases. Ottowa, Canada. Canadian Task Force on Preventive Health Care. 2004. Accessed at http://www.canadiantaskforce.ca/recommendations/2003_01_eng.html. 4 May 2012.
20 North American Menopause Society. Gass ML, Manson JE, et al. The 2012 hormone therapy position statement of the North American Menopause Society. Menopause. 2012;19(3):257-271. [pmid: 22367731].
21 American College of Physicians. ACP Clinical Practice Guidelines. Philadelphia. American College of Physicians. 2012. Accessed at http://www.acponline.org/clinical_information/guidelines/guidelines/. 4 May 2012.
22 Harris RP, Helfand M, Woolf SH, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
23 Anderson GL, Judd HL, Kaunitz AM, et al. Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women’s Health Initiative randomized trial. JAMA. 2003;290(13):1739-48. [pmid: 14519708].
24 Cauley JA, Robbins J, Chen Z, et al. Effects of estrogen plus progestin on risk of fracture and bone mineral density: the Women’s Health Initiative randomized trial. JAMA. 2003;290(13):1729-38. [pmid: 14519707].
25 Chlebowski RT, Anderson GL, Gass M, et al. Estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women. JAMA. 2010;304(15):1684-92. [pmid: 20959578].
26 Chlebowski RT, Hendrix SL, Langer RD, et al. Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative randomized trial. JAMA. 2003;289(24):3243-53. [pmid: 12824205].
27 Chlebowski RT, Schwartz AG, Wakelee H, et al. Oestrogen plus progestin and lung cancer in postmenopausal women (Women’s Health Initiative trial): a post-hoc analysis of a randomised controlled trial. Lancet. 2009;374(9697):1243-51. [pmid: 19767090].
28 Chlebowski RT, Wactawski-Wende J, Ritenbaugh C, et al. Estrogen plus progestin and colorectal cancer in postmenopausal women. N Engl J Med. 2004;350(10):991-1004. [pmid: 14999111].
29 Cirillo DJ, Wallace RB, Rodabough RJ, et al. Effect of estrogen therapy on gallbladder disease. JAMA. 2005;293:330-9. [pmid: 15657326].
30 Cushman M, Kuller LH, Prentice R, et al. Estrogen plus progestin and risk of venous thrombosis. JAMA. 2004;292(13):1573-80. [pmid: 15467059].
31 Gramling R, Eaton CB, Rothman KJ, et al. Hormone replacement therapy, family history, and breast cancer risk among postmenopausal women. Epidemiology. 2009;20(5):752-6. [pmid: 19451819].
32 Hays J, Ockene JK, Brunner RL, et al. Effects of estrogen plus progestin on health-related quality of life. N Engl J Med. 2003;348(19):1839-54. [pmid: 12642637].
33 Heiss G, Wallace R, Anderson GL, et al. Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin. JAMA. 2008;299(9):1036-45. [pmid: 18319414].
34 Hendrix SL. The Women’s Health Initiative estrogen plus progestin trial: the study and how it changes our practice. J Am Osteopath Assoc. 2003;103(2 Suppl 2):S3-5. [pmid: 12625631].
35 Hendrix SL, Cochrane BB, Nygaard IE, et al. Effects of estrogen with and without progestin on urinary incontinence. JAMA. 2005;293(8):935-48. [pmid: 15728164].
36 Hsia J, Criqui MH, Rodabough RJ, et al. Estrogen plus progestin and the risk of peripheral aerterial disease. Circulation. 2004;109(5):620-6. [pmid: 14769684].
37 Manson JE, Hsia J, Johnson KC, et al. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003;349(6):523-34. [pmid: 12904517].
38 Margolis KL, Bonds DE, Rodabough RJ, et al. Effect of oestrogen plus progestin on the incidence of diabetes in postmenopausal women: results from the Women’s Health Initiative hormone trial. Diabetologia. 2004;47(7):1175-87. [pmid: 15252707].
39 Rossouw JE, Prentice RL, Manson JE, et al. Postmenopausal hormone therapy and risk of cardiovascular disease by age and years since menopause. JAMA. 2007;297(13):1465-77. [pmid: 17405972].
40 Toh S, Hernandez-Diaz S, Logan R, et al. Coronary heart disease in postmenopausal recipients of estrogen plus progestin therapy: does the increased risk ever disappear? A randomized trial. Ann Intern Med. 2010;152(4):211-7. [pmid: 20157135].
41 Wassertheil-Smoller S, Hendrix SL, Limacher M, et al. Effect of estrogen plus progestin on stroke in postmenopausal women: the Women’s Health Initiative: a randomized trial. JAMA. 2003;289(20):2673-84. [pmid: 12771114].
42 Anderson GL, Limacher M, Assaf AR, et al. Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women’s Health Initiative randomized controlled trial. JAMA. 2004;291(14):1701-12. [pmid: 15082697].
43 Bonds DE, Lasser N, Qi L, et al. The effect of conjugated equine oestrogen on diabetes incidence: the Women’s Health Initiative randomised trial. Diabetologia. 2006;49(3):459-68. [pmid: 16440209].
44 Brunner RL, Gass M, Aragaki A, et al. Effects of conjugated equine estrogen on health-related quality of life in postmenopausal women with hysterectomy: results from the Women’s Health Initiative randomized clinical trial. Arch Intern Med. 2005;165(17):1976-86. [pmid: 16186467].
45 Chlebowski RT, Anderson GL, Manson JE, et al. Lung cancer among postmenopausal women treated with estrogen alone in the Women’s Health Initiative randomized trial. J Natl Cancer Inst. 2010;102(18):1413-21. [pmid: 20709992].
46 Curb JD, Prentice RL, Bray PF, et al. Venous thrombosis and conjugated equine estrogen in women without a uterus. Arch Intern Med. 2006;166(7):772-80. [pmid: 16606815].
47 Hendrix SL, Wassertheil-Smoller S, Johnson KC, et al. Effects of conjugated equine estrogen on stroke in the Women’s Health Initiative. Circulation. 2006;113(20):2425-34. [pmid: 16702472].
48 Hsia J, Langer RD, Manson JE, et al. Conjugated equine estrogens and coronary heart disease: the Women’s Health Initiative. Arch Intern Med. 2006;166(3):357-65. [pmid: 16476878].
49 LaCroix AZ, Chlebowski RT, Manson JE, et al. Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy: a randomized controlled trial. JAMA. 2011;305(13):1305-14. [pmid: 21467283].
50 Ritenbaugh C, Stanford JL, Wu L, et al. Conjugated equine estrogens and colorectal cancer incidence and survival: the Women’s Health Initiative randomized clinical trial. Cancer Epidemiol Biomarkers Prev. 2008;17(10):2609-18. [pmid: 18829444].
51 Culhane NS. Estrogen plus progestin may increase incidence of dementia. J Fam Pract. 2003;52(10):754-5. [pmid: 14529594].
52 Espeland MA, Rapp SR, Shumaker SA, et al. Conjugated equine estrogens and global cognitive function in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004;291(24):2959-68. [pmid: 15213207].
53 Rapp SR, Espeland MA, Shumaker SA, et al. Effect of estrogen plus progestin on global cognitive function in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003;289(20):2663-72. [pmid: 12771113].
54 Shumaker SA, Legault C, Kuller L, et al. Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004;291(24):2947-58. [pmid: 15213206].
55 Shumaker SA, Legault C, Rapp SR, et al. Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003;289(20):2651-62. [pmid: 12771112].
56 Espeland MA, Brunner RL, Hogan PE, et al. Long-term effects of conjugated equine estrogen therapies on domain-specific cognitive function: results from the Women’s Health Initiative Study of Cognitive Aging extension. J Am Geriatr Soc. 2010;58(7):1263-71. [pmid: 20649689].
57 Resnick SM, Espeland MA, An Y, et al. Effects of conjugated equine estrogens on cognition and affect in postmenopausal women with prior hysterectomy. J Clin Endocrinol Metab. 2009;94(11):4152-61. [pmid: 19850684].
58 Resnick SM, Maki PM, Rapp SR, et al. Effects of combination estrogen plus progestin hormone treatment on cognition and affect. J Clin Endocrinol Metab. 2006;91(5):1802-10. [pmid: 16522699].
59 Grady D, Applegate W, Bush T, et al. Heart and Estrogen/progestin Replacement Study (HERS): design, methods, and baseline characteristics. Control Clin Trials. 1998;19(4):314-35. [pmid: 9683309].
60 Grady D, Herrington D, Bittner V, et al. Cardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA. 2002;288(1):49-57. [pmid: 12090862].
61 Hulley S, Furberg C, Barrett-Connor E, et al. Noncardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA. 2002;288(1):58-66. [pmid: 12090863].
62 Hulley S, Grady D, Bush T, et al. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. JAMA. 1998;280(7):605-13. [pmid: 9718051].
63 Kanaya AM, Herrington D, Vittinghoff E, et al. Glycemic effects of postmenopausal hormone therapy: the Heart and Estrogen/progestin Replacement Study. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2003;138(1):1-9. [pmid: 12513038].
64 Steinauer JE, Waetjen LE, Vittinghoff E, et al. Postmenopausal hormone therapy: does it cause incontinence?. Obstet Gynecol. 2005;106(5 Pt 1):940-5. [pmid: 16260510].
65 Grady D, Yaffe K, Kristof M, et al. Effect of postmenopausal hormone therapy on cognitive function: the Heart and Estrogen/progestin Replacement Study. Am J Med. 2002;113(7):543-8. [pmid: 12459399].
66 Vickers MR, Martin J, Meade TW. WISDOM Study Team. The Women’s International Study of Long-Duration Oestrogen After Menopause (WISDOM): a randomised controlled trial. BMC Womens Health. 2007;7:2. [pmid: 17324282].
67 Cherry N, Gilmour K, Hannaford P, et al. Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. Lancet. 2002;360(9350):2001-8. [pmid: 12504395].
68 Tierney MC, Oh P, Moineddin R, et al. A randomized double-blind trial of the effects of hormone therapy on delayed verbal recall in older women. Psychoneuroendocrinology. 2009;34(7):1065-74. [pmid: 19297102].
69 Ettinger B, Ensrud KE, Wallace R, et al. Effects of ultralow-dose transdermal estradiol on bone mineral density: a randomized clinical trial. Obstet Gynecol. 2004;104(3):443-51. [pmid: 15339752].
70 Johnson SR, Ettinger B, Macer JL, et al. Uterine and vaginal effects of unopposed ultralow-dose transdermal estradiol. Obstet Gynecol. 2005;105(4):779-87. [pmid: 15802405].
71 Waetjen LE, Brown JS, Vittinghoff E, et al. The effect of ultralow-dose transdermal estradiol on urinary incontinence in postmenopausal women. Obstet Gynecol. 2005;106(5 Pt 1):946-52. [pmid: 16260511].
72 Yaffe K, Vittinghoff E, Ensrud KE, et al. Effects of ultra-low-dose transdermal estradiol on cognition and health-related quality of life. Arch Neurol. 2006;63(7):945-50. [pmid: 16831962].
73 Anderson GL, Chlebowski RT, Aragaki AK, et al. Conjugated equine oestrogen and breast cancer incidence and mortality in postmenopausal women with hysterectomy: extended follow-up of the Women’s Health Initiative randomised placebo-controlled trial. Lancet Oncol. 2012;13:476-486. [pmid: 22401913].
74 Rossouw JE. Design of the Women’s Health Initiative clinical trial and observational study. Control Clin Trials. 1998;19(1):61-109. [pmid: 9492970].
75 Cauley JA, McTiernan A, Rodabough RJ, et al. Statin use and breast cancer: prospective results from the Women’s Health Initiative. J Natl Cancer Inst. 2006;98(10):700-7. [pmid: 16705124].