# METHODS

## Key Questions and Analytic Framework

A standard protocol was developed and followed for this review. Based on evidence from the previous review6 and using the methods of the USPSTF,22 USPSTF members and Agency for Healthcare Research and Quality (AHRQ) scientific staff determined the key questions for this update. Investigators created an analytic framework incorporating the key questions and outlining the patient populations, interventions, outcomes, and harms of menopausal hormone therapy (Figure 1). Key questions include:

1. What are the benefits of menopausal hormone therapy when used to prevent chronic conditions?
2. What are the harms of menopausal hormone therapy when used to prevent chronic conditions?
3. Do benefits and harms differ by subgroups? Subgroups include women with premature menopause; surgical menopause; age of use; types, doses, and modes of delivery of hormones; and presence of comorbidities.

Figure 1 Analytic Framework and Key Questions

Key Questions

1. What are the benefits of menopausal hormone therapy when used to prevent chronic conditions? Potential benefits include reduced fractures and colorectal cancer.

2. What are the harms of menopausal hormone therapy when used to prevent chronic conditions? Potential harms include coronary heart disease events, stroke, cognitive decline, venous thromboembolism, breast cancer, endometrial cancer, ovarian cancer, and cholecystitis.

3. Do benefits and harms differ by subgroups? Subgroups include women with premature menopause; women with surgical menopause; age of use; types, doses, and modes of delivery of hormones; and presence of comorbidities.

Figure 1 is an analytic framework that depicts the events that postmenopausal women experience when they are treated with hormone therapy to prevent chronic conditions. The hormone therapy is either estrogen only or estrogen plus progestin. The figure shows that women could experience improved health outcomes or adverse effects. The patient population of interest is postmenopausal women. The outcomes of interest are improved health ouctomes, improved mortality, or adverse effects.

The target population includes adult postmenopausal women eligible for use of estrogen with or without progestin. Women with known contraindications, such as thrombotic disorders, hormone sensitive cancer, and others,1 would be ineligible and are outside the scope of this review. Outcomes include cardiovascular disease such as coronary heart disease (CHD), stroke, and thromboembolic disease; cancer of the breast, colon, lung, endometrium, and ovaries; fractures at various sites; cognition and dementia; disease-specific and all-cause mortality, and new findings reported by the trials. This update includes health outcomes, such as fractures, rather than intermediate outcomes, such as bone mineral density, and emphasizes medications, health care settings, and populations of postmenopausal women applicable to U.S. primary care practice.

## Search Strategies

In conjunction with a research librarian, investigators searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through the third quarter of 2011), MEDLINE (2002 to November 30, 2011), reference lists of papers, and Scopus for relevant English-language studies and systematic reviews. Search strategies are described in Appendix B1.

## Study Selection

Investigators selected studies on the basis of inclusion and exclusion criteria developed for each key question (Appendix B2). For all key questions, RCTs of postmenopausal hormone therapy versus placebo were included to determine its effectiveness in reducing risks for chronic conditions (key question 1), its harms (key question 2), and differences among the defined population subgroups (key question 3). Trials were included that enrolled participants matching the target population, were designed to prevent new conditions rather than treat existing conditions, and provided results estimating risk reduction or elevation compared with placebo. Estimates based on individual hormone therapy regimens rather than those that pooled results from different regimens were included. For trials that enrolled participants with a preexisting condition, such as CHD in the Heart and Estrogen/Progestin Replacement Study (HERS), data were used for all outcomes except the preexisting condition and conditions related to it.

Some studies reported outcomes at multiple time points in the trial, including after the postintervention phase. In these cases, results were selected based on specific outcome measures. For conditions known to be related to ongoing exposure to hormone therapy, such as thromboembolic disease and osteoporotic fractures, results reported at the end of the trial intervention phase were used. For conditions initiated during exposure but continuing to accrue after the intervention phase, such as cancer, results reported at the end of the trial postintervention phase were used, if available. Investigators reviewed their selection of results from the WHI trials with WHI investigators. Nominal, rather than adjusted, estimates were used because they were considered the main results by the WHI investigators.

Observational studies were not included because of the existence of published RCTs designed to address the key questions directly, and the known biases inherent in observational studies of menopausal hormone use.

## Data Abstraction and Quality Rating

From the included studies, an investigator abstracted details about the patient population, study design, analysis, followup, and results. Essential data elements were confirmed by a second investigator. Investigators used criteria developed by the USPSTF22 to rate the quality of each study as good, fair, or poor (Appendix B3). Two investigators independently rated the quality of studies and resolved discrepancies by consensus.

## Data Synthesis

Results from WHI were used as the main estimates for each outcome rather than a meta-analysis of all trials because the trials were heterogeneous, WHI was the most applicable to the key questions, and results from WHI would dominate a meta-analysis because of its large enrollment. As a group, the research team assessed the overall quality of the body of evidence for each key question (good, fair, poor) using methods developed by the USPSTF based on the number, quality, and size of studies; consistency of results between studies; and directness of effect.22

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Program Officers, and collaborative partners (Appendix B4).