# INTRODUCTION

## Purpose of Review and Prior USPSTF Recommendation

This systematic evidence review is an update for the U.S. Preventive Services Task Force (USPSTF) recommendations on use of menopausal hormone therapy for postmenopausal women to prevent chronic health conditions such as cardiovascular disease, types of cancer, and osteoporotic fractures. Use of menopausal hormone therapy for treatment of menopausal symptoms, such as vasomotor hot flashes or urogenital atrophy, or for other indications is outside the scope of this review. Menopausal hormone therapy includes use of various forms, doses, and regimens of estrogen with or without progestin.1 Estrogen combined with progestin is used by women who have not had previous hysterectomies to prevent endometrial proliferation and endometrial cancer, whereas women with previous hysterectomies use estrogen only. (Abbreviations are listed in Appendix A.)

In 2002, the USPSTF recommended against the routine use of combined estrogen and progestin hormone therapy for the prevention of chronic conditions in postmenopausal women who have not had hysterectomies because the harmful effects were likely to exceed the chronic disease prevention benefits in most women (D recommendation).2 Based on the results of systematic reviews3–11 and early findings of the Women’s Health Initiative (WHI) trial of estrogen plus progestin,12 the USPSTF found good evidence that combined hormone therapy results in both benefits and harms. Benefits included reduced risk for fracture (good evidence) and colorectal cancer (fair evidence). Combined estrogen and progestin had no beneficial effect on coronary heart disease and suggested an increased risk (good evidence). Other harms included increased risk for breast cancer (good evidence), venous thromboembolism (good evidence), stroke (fair evidence), cholecystitis (fair evidence), dementia (fair evidence), and lower global cognitive function (fair evidence). Because of insufficient evidence, the USPSTF could not assess effects on the incidence of ovarian cancer, mortality from breast cancer or coronary heart disease, or all-cause mortality.

In 2005, the USPSTF recommended against the routine use of unopposed estrogen for the prevention of chronic conditions in postmenopausal women who have had previous hysterectomies based on results of the WHI trial of estrogen only in women with hysterectomies (D recommendation).13 The USPSTF found good evidence that the use of unopposed estrogen resulted in both benefits and harms. The benefits included reduced risk for fracture (good evidence), and harms included increased risk for venous thromboembolism (fair evidence), stroke (fair evidence), dementia (fair evidence), and lower global cognitive function (fair evidence). There was fair evidence that unopposed estrogen had no beneficial effect on coronary heart disease. The USPSTF could not assess the effects of unopposed estrogen on the incidence of breast cancer, ovarian cancer, or colorectal cancer, as well as breast cancer mortality or all-cause mortality.

## Prevalence and Burden of Condition

Women transitioning through menopause and postmenopausal women are the target populations for hormone therapy use. For many years, hormone therapy was used by large numbers of women to treat menopausal symptoms, such as hot flashes, as well as to prevent chronic conditions such as cardiovascular disease, cognitive decline, and osteoporosis. Results from WHI, a large U.S.-based randomized, controlled trial (RCT) of hormone therapy compared with placebo, indicated that hormone therapy was associated with important adverse health effects.12, 14,15 As a result, the U.S. Food and Drug Administration (FDA) changed the indications for use to now include only short-term treatment of menopausal symptoms and prevention of osteoporosis.1

## Recommendations of Other Groups and Current Clinical Practice

The American Academy of Family Physicians, American Congress of Obstetricians and Gynecologists, American Heart Association, North American Menopause Society, and Canadian Task Force on Preventive Health Care recommend against use of menopausal hormone therapy for the prevention of chronic conditions in postmenopausal women (Table 1).16–20 The American College of Physicians directs individuals to the USPSTF recommendations.21 No professional organizations recommend use of hormone therapy outside the FDA indications.

Table 1 Recommendations of Other Groups

Organization, year | Recommendations
American College of Physicians21 | Recommends the U.S. Preventive Services Task Force Web site and the Canadian Task Force on Preventive Health Care.
American Academy of Family Physicians, 2005^16^ | Recommends against the routine use of combined estrogen and progestin for the prevention of chronic conditions in postmenopausal women (Grade: D recommendation). AAFP recommends against the routine use of unopposed estrogen for the prevention of chronic conditions in postmenopausal women who have had a hysterectomy (Grade: D recommendation).
American Congress of Obstetricians and Gynecologists, 2004^17^ | The risks of hormone therapy exceed the benefits for prevention of chronic diseases in postmenopausal women and the benefits and risks should be discussed with patients before initiating therapy.
American Heart Association, 2011^18^ | Recommends against the use of hormone therapy for primary and secondary prevention of cardiovascular disease in women (Class III, Level of Evidence A).
North American Menopause Society, 2010^20^ | Supports the initiation of hormone therapy around the time of menopause to treat menopause-related symptoms, to treat or reduce the risk for osteoporosis in select postmenopausal women, or both. The benefit-risk ratio for menopausal hormone therapy is positive for women who begin therapy close to the start of menopause and decreases in older women. This position statement has been endorsed by the American Medical Women’s Association, the Asosiacion Mexicana para el Estudio del Climaterio, the Endocrine Society, HealthyWomen, the National Association of Nurse Practitioners in Women’s Health, and the Society of Obstetricians and Gynecologists of Canada.
Canadian Task Force on Preventive Health Care, 2004^19^ | Given the balance of harms and benefits, the Task Force recommends against the use of combined estrogen–progestin therapy and estrogen-only therapy for the primary prevention of chronic diseases in menopausal women (grade D recommendation).