# Evidence and Quality Tables

Appendix C1 Quality Assessment of Randomized, Controlled Trials

Author, Year Trial | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Maintain comparable groups? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Reporting of attrition, crossovers, adherence, and contamination? | Loss to followup differential/high? | Intention-to-treat analysis? | Post-randomization exclusions? | Outcomes prespecified? | Funding source | External validity | Quality rating
Anderson, 2004^42^ WHI | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes | National Heart, Lung, and Blood Institute, U.S. Department of Health and Human Services | Good | Fair
Anderson, 2003^23^ WHI | Yes | Yes | Yes | Compliance rates similar | Yes | Yes | Yes | Yes | Yes | No | Yes | NR | Yes | National Heart, Lung, and Blood Institute, U.S. Department of Health and Human Services | Good | Fair
Cherry, 2002^67^ ESPRIT | Yes | Yes | Yes | Greater noncompliance in treatment group | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | NR | Yes | Schering AG | Fair | Fair
Ettinger, 2004^69^ ULTRA | Yes | Yes | Mostly: 2% lower lumbar spine BMD in treatment group compared with placebo group | Unclear | Yes | Yes | Yes | Yes | Yes: attrition and adherence No: crossovers and contamination | No | Yes | No | Yes | Berlex Laboratories, Inc | Fair | Fair
Heiss, 2008^33^ WHI extension | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes | National Heart, Lung, and Blood Institute, U.S. Department of Health and Human Services | Good | Fair
Hulley, 2002^61^ HERS II | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Wyeth-Ayerst Research | Good/Fair | Fair
LaCroix, 2011^49^ WHI extension | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes | National Heart, Lung, and Blood Institute, U.S. Department of Health and Human Services | Good | Fair
Resnick, 2006^58^ WHISCA | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Completion rates at year 3: 42.2% E+P vs. 44.1% placebo | Yes | No | Yes | National Heart, Lung, and Blood Institute, U.S. Department of Health and Human Services | Good | Fair
Resnick, 2009^57^ WHISCA | Yes | Yes | Mostly, except for smoking status | Yes | Yes | Yes | Yes | Yes | Yes | Completion rates at year 4: 75.1% estrogen vs. 71.9% placebo | Yes | No | Yes | National Heart, Lung, and Blood Institute, U.S. Department of Health and Human Services | Good | Fair
Rossouw, 2002^12^ WHI | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes | National Heart, Lung, and Blood Institute, U.S. Department of Health and Human Services | Good | Fair
Shumaker, 2003^55^ WHIMS | Yes | Yes | Mostly, except for history of stroke and prior statins use | NR | Yes | Yes | Yes | Yes | Yes: attrition and adherence No: crossovers and contamination | Year 6 3MSE scores obtained for 31 (1.45%) E+P and 44 (1.98%) placebo participants | Yes | No | Yes | National Heart, Lung, and Blood Institute, U.S. Department of Health and Human Services | Good | Fair
Shumaker, 2004^54^ WHIMS | Yes | Yes | Mostly, except for hypertension | NR | Yes | Yes | Yes | Yes | Yes: attrition and adherence No: crossovers and contamination | Drop out rate for year 7: 59.4% for estrogen vs. 54.2% for placebo | Yes | No | Yes | National Heart, Lung, and Blood Institute, U.S. Department of Health and Human Services | Good | Fair
Tierney, 2009^68^ EMS | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes: attrition and adherence No: crossovers and contamination | No | Yes | No | Yes | Not reported | Fair | Fair
Vickers, 2007^66^ WISDOM | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear; prematurely closed trial | Yes | Unclear | Unclear: primary outcome changed | Not reported | Fair | Fair

Abbreviations: BMD=bone mineral density; E+P=estrogen and progestin; EMS=Estrogen Memory Study; ESPRIT=Oestrogen in the Prevention of Reinfarction Trial; HERS/HERS II=Heart and Estrogen/Progestin Replacement Study; ULTRA= Ultra-Low-Dose Transdermal Estrogen Assessment; WHI=Women’s Health Initiative; WHIMS=Women's Health Initiative Memory Study; WHISCA=Women's Health Initiative Study of Cognitive Aging; WISDOM=Women's International Study of Long Duration Oestrogen After Menopause.

Appendix C2 Evidence Table of Trials Reporting Incidence of Breast Cancer

Author, year; title | Population | Results (Treatment vs. Placebo) Breast cancer incidence
Chlebowski, 2010;^25^ Estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: Estrogen plus progestin 8,506 Intervention phase 8,056 Post-intervention phase 8,506 Extension phase Placebo 8,102 Intervention phase 7,682 Post-intervention phase 8,102 Extension phase | Incidence of breast cancer 385 (0.42% per year) vs. 293 (0.34% per year); HR, 1.25 (95% CI, 1.07 to 1.46); p=0.004 Overall mortality per year 25 vs. 12; HR, 1.96 (95% CI, 1.00 to 4.04); p=0.049 Rates when analyses limited to 80% adherence 14 vs. 5; HR, 2.96 (95% CI, 1.00 to 8.77); p=0.053
Chlebowski, 2003;^26^ Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative randomized trial. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 16,608 Enrolled 8,506 Estrogen plus progestin 8,102 Placebo | Invasive breast cancer 199 (0.41%) vs. 150 (0.33%); HR, 1.24 (95% CI, 1.01 to 1.54); p=0.003 Sensitivity analyses examining impact of nonadherence suggested a stronger effect on invasive breast cancer incidence when events in nonadeherent women are excluded (HR, 1.49; p<0.001) Without prior menopausal hormone use Treatment (n=6,277) vs. Placebo (n=6,020) Year 1 after entry: 7 (0.11%) vs. 14 (0.23%); HR, 0.48 (95% CI, 0.19 to 1.20) Year 2 after entry: 15 (0.24%) vs. 22 (0.37%); HR, 0.65 (95% CI, 0.34 to 1.25) Year 3 after entry: 19 (0.31%) vs. 19 (0.33%); HR, 0.96 (95% CI, 0.51 to 1.82) Year 4 after entry: 35 (0.58%) vs. 23 (0.40%); HR, 1.45 (95% CI, 0.85 to 2.45) Year 5 after entry: 28 (0.54%) vs. 17 (0.34%); HR, 1.61 (95% CI, 0.88 to 2.94) Year 6 or more after entry: 37 (0.69%) vs. 26 (0.56%); HR, 1.24 (95% CI, 0.75 to 2.05) Overall Year 1 after entry: 12 (0.14%) vs. 19 (0.24%); HR, 0.60 (95% CI, 0.29 to 1.23) Year 2 after entry: 26 (0.31%) vs. 32 (0.40%); HR, 0.77 (95% CI, 0.46 to 1.30) Year 3 after entry: 29 (0.35%) vs. 22 (0.28%); HR, 1.26 (95% CI, 0.73 to 2.20) Year 4 after entry: 44 (0.54%) vs. 27 (0.35%); HR, 1.54 (95% CI, 0.95 to 2.49) Year 5 after entry: 43 (0.61%) vs. 21 (0.32%); HR, 1.99 (95% CI, 1.18 to 3.35) Year 6 or more after entry: 45 (0.61%) vs. 29 (0.45%); HR, 1.35 (95% CI, 0.85 to 2.16)
Rossouw, 2002;^12^ Risks and benefits of estrogen plus progestin in healthy postmenopausal women. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 8,506 Estrogen plus progestin 8,102 Placebo | Invasive breast cancer 166 (0.38 annualized %) vs. 124 (0.30 annualized %); HR, 1.26 (95% CI, 1.00 to 1.59) Breast cancer mortality 3 (0.01 annualized %) vs. 2 (<0.01 annualized %)
Gramling, 2009;^31^ Hormone replacement therapy, family history, and breast cancer risk among postmenopausal women (longitudinal follow-up). WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 16,608 Enrolled 8,506 Estrogen plus progestin 8,102 Placebo | Those with a first-degree family history of breast cancer Total: 1,009 vs. 895 Invasive breast cancer: 35 vs. 25 Women-years: 5,596 vs. 4,900 Those without a first-degree family history of breast cancer Total: 7,497 vs. 7,202 Invasive breast cancer: 164 vs. 125 Woman-years: 41,998 vs. 37,798
Heiss, 2008;^33^ Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin. WHI Estrogen plus progestin trial | All women included in WHI: 8,052 Estrogen plus progestin (analyzed 95% of original 8,506) 7,678 Placebo (analyzed 95% of original 8,102) | Intervention phase 206 (0.43 annualized %) vs. 153 (0.34 annualized %); HR, 1.26 (95% CI, 1.02 to 1.55) Postintervention phase 79 (0.42 annualized %) vs. 60 (0.33 annualized %); HR, 1.27 (95% CI, 0.91 to 1.78) p-value for difference between phases=0.97 Overall combined phase data 285 (0.43 annualized %) vs. 213 (0.34 annualized %); HR, 1.27 (95% CI, 1.06 to 1.51)
LaCroix, 2011;^49^ Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy post-intervention. WHI Estrogen only trial | Women enrolled in WHI trial: 10,739 Enrolled 5,310 Estrogen 5,429 Placebo | Intervention stage 104 vs. 135; HR, 0.79 (95% CI, 0.61 to 1.02); p=0.76 Postintervention 47 vs. 64; HR, 0.75 (95% CI, 0.51 to 1.09); p=0.76 Overall 151 vs. 199; HR, 0.77 (95% CI, 0.62 to 0.95); p=0.76
Anderson, 2004;^42^ Effects of conjugated equine estrogen in postmenopausal women with hysterectomy. WHI Estrogen only trial | Women enrolled in WHI trial: 10,739 Enrolled 5,310 Estrogen 5,429 Placebo | Number of patients (annualized %) 94 (0.26) vs. 124 (0.33); HR, 0.77 (95% CI, 0.59 to 1.01)
Hulley, 2002;^61^ Noncardiovascular disease outcomes during 6.8 years of hormone therapy (Heart and Estrogen/Progestin Replacement Study follow-up, HERS II). HERS II Estrogen plus progestin trial | Women from original HERS trial who consented to followup: 2,321 (93% of surviving participants from HERS) | Total 49 (5.9 per 1,000 person-years) vs. 39 (4.7 per 1,000 person-years); HR, 1.27 (95% CI, 0.84 to 0.94); p=0.26 HERS 34 (6.2 per 1,000 person-years) vs. 25 (4.5 per 1,000 person-years); HR, 1.38 (95% CI, 0.82 to 2.31); p=0.22 HERS II 15 (5.3 per 1,000 person-years) vs. 14 (4.9 per 1,000 person-years); HR, 1.08 (95% CI, 0.52 to 2.24); p=0.83 Unadjusted ITT vs. adjusted ITT vs. adjusted as-treated 1.27 (95% CI, 0.84 to 1.94) vs. 1.27 (95% CI, 0.84 to 1.94) vs. 1.11 (95% CI, 0.61 to 2.03)
Cherry (ESPRIT Team), 2002;^67^ Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomized placebo controlled trial. ESPRIT Estrogen only trial | Postmenopausal women aged 50–69 years who had survived a first myocardial infarction: 1,017 Enrolled 513 Estrogen 504 Placebo | Cases by 24 months 4 (1%) vs. 4 (1%); HR, 0.98 (95% CI, 0.25 to 3.91); p=1.00
Vickers, 2007;^66^ Main morbidities recorded in the Women’s International Study of Long Duration Oestrogen After Menopause (WISDOM): a randomized controlled trial of hormone replacement therapy in postmenopausal women. WISDOM Estrogen plus progestin trial | 4,385 Enrolled (estrogen plus progestin vs. placebo trial only) 2,196 Estrogen plus progestin 2,189 Placebo | Breast cancer incidence 5 vs. 7; HR, not reported Mortality from breast cancer 0 vs. 0; HR, not reported

Abbreviations: CI=confidence interval; ESPRIT = Oestrogen in the Prevention of Reinfarction Trial; HERS=Heart and Estrogen/Progestin Replacement Study; HERS II=Heart and Estrogen/Progestin Replacement Study Phase II; HR=hazard ratio; ITT=intention-to-treat; WHI=Women's Health Initiative; WISDOM=Women’s International Study of Long-Duration Oestrogen After Menopause.

Appendix C3 Evidence Table of Trials Reporting Incidence of Colorectal Cancer

Author, year; title | Population | Results (Treatment vs. Placebo) Incidence of colorectal cancer
Heiss 2008;^33^ Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin. WHI Estrogen plus progestin trial | Women in the post-intervention phase of WHI: 16,608 Enrolled 8,506 Estrogen plus progestin 8,102 Placebo | Clinical Trial Phase 50 vs. 75; HR, 0.62 (95% CI, 0.43 to 0.89) Post-intervention phase 34 vs. 30; HR, 1.08 (95% CI, 0.66 to 1.77); p=0.007 Overall combined phase data 84 vs. 105; HR, 0.75 (95% CI, 0.57 to 1.00)
Chlebowski, 2004;^28^ Estrogen plus progestin and colorectal cancer in postmenopausal women. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 16,608 Enrolled 8,506 Estrogen + progestin 8,102 Placebo | Annualized rate of colorectal cancer Colorectal cancer: 48 vs. 74; HR, 0.61 (95% CI, 0.42 to 0.87); p=0.007 Invasive colorectal cancer: 43 vs. 72; HR, 0.56 (95% CI, 0.38 to 0.81); p= 0.003 Within invasive colorectal cancer Colon cancer: 35 vs. 61; HR, 0.54 (95% CI, 0.36 to 0.82); p= 0.004 Rectal cancer: 8 vs. 11; HR, 0.66 (95% CI, 0.26 to 0.65); p=0.37
Rossouw, 2002;^12^ Risks and benefits of estrogen plus progestin in healthy postmenopausal women. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 16,608 Enrolled 8,506 Estrogen plus progestin 8,102 Placebo | Colorectal cancer 45 vs. 67; HR, 0.63 (nominal 95% CI, 0.43 to 0.92) (adjusted 95% CI, 0.32 to −1.24) Colorectal cancer by followup year Year 1: 10 vs. 15; HR, 0.64 Year 2: 11 vs. 9; HR, 1.17 Year 3: 6 vs. 8; HR, 0.72 Year 4: 9 vs. 20; HR, 0.43 Year 5: 4 vs. 8; HR, 0.47 Year 6 and later: 5 vs. 7; HR, 0.59
LaCroix, 2011;^49^ Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy post-intervention. WHI Estrogen only trial | Women enrolled in WHI trial: 10,739 Enrolled 5,310 Estrogen 5,429 Placebo | Colorectal cancer Intervention stage: 65 vs. 58; HR, 1.15 (95% CI, 0.81 to 1.64); p= 0.71 Postintervention: 24 vs. 24; HR, 1.01 (95% CI, 0.58 to 1.79); p=0.71 Overall: 89 vs. 82; HR, 1.11 (95% CI, 0.82 to 1.50); p=0.71
Ritenbaugh, 2008;^50^ Conjugated equine estrogens and colorectal cancer incidence and survival: the Women’s Health Initiative randomized clinical trial. WHI Estrogen only trial | Women enrolled in WHI trial: 10,739 Enrolled 5,310 Estrogen 5,429 Placebo | Incidence of invasive colorectal cancer 58 vs. 53; HR, 1.12 (95% CI, 0.77 to 1.63); p=0.55 Within invasive colorectal cancer Colon cancer: 53 vs. 43; HR, 1.26 (95% CI, 0.84 to 1.88); p=0.26 Rectal cancer: 5 vs. 10; HR, 0.53 (95% CI, 0.18 to 1.56); p=0.25
Anderson, 2004;^42^ Effects of conjugated equine estrogen in postmenopausal women with hysterectomy. WHI Estrogen only trial | Women enrolled in WHI trial: 10,739 Enrolled 5,310 Estrogen 5,429 Placebo | Colorectal cancer 61 vs. 58; HR, 1.08 (nominal 95% CI, 0.75 to 1.55); (adjusted 95% CI, 0.63 to 1.86)
Hulley 2002;^61^ Noncardiovascular disease outcomes during 6.8 years of hormone therapy (Heart and Estrogen/Progestin Replacement Study Follow-Up, HERS II). HERS II Estrogen plus progestin trial | Women from original HERS trial who consented to followup: 2,321 (93% of surviving patients from HERS) | Colon cancer (events per 1,000 person-years) HERS: 2.0 vs. 2.9; HR, 0.69 (95% CI, 0.32 to 1.49); p=0.35 HERS II: 10/3.4 vs. 10/3.4; HR, 1.01 (95% CI, 0.42 to 2.43); p=0.98 Total: 21/2.5 vs. 26/3.1; HR, 0.81 (95% CI, 0.46 to 1.45); p=0.48 p-value for treatment-time interaction = 0.52 Unadjusted ITT vs. adjusted ITT vs. adjusted as-treated HR, 0.81 (95% CI, 0.46 to 1.45) vs. HR, 0.82 (95% CI, 0.46 to 1.47) vs. HR, 0.58 (95% CI, 0.25 to 1.35)
Tierney, 2009;^68^ A randomized double-blind trial of the effects of hormone therpay on delayed verbal recall in older women. EMS Estrogen plus progestin trial | Within the greater Toronto area; enrolled between April 2000 and January 2004; aged >60 years; last menstrual cycle >12 months before screening; fluent in English and could read normal print and hear normal speech. 142 Enrolled 70 Estrogen + progestin 72 Placebo | Colorectal cancer 0 vs. 0
Vickers 2007;^66^ Main morbidities recorded in the Women’s International Study of Long Duration Oestrogen After Menopause (WISDOM): a randomised controlled trial of hormone replacement therapy in postmenopausal women. WISDOM Estrogen plus progestin trial | 4,385 Enrolled 2,196 Estrogen plus progestin 2,189 Placebo | Colorectal Cancer 2 vs. 2; HR, not reported Mortality 1 vs. 0; HR, not reported

Abbreviations: CI=confidence interval; EMS=Estrogen Memory Study; HERS=Heart and Estrogen/Progestin Replacement Study; HERS II=Heart and Estrogen/Progestin Replacement Study Phase II; HR=hazard ratio; ITT=intention-to-treat; WHI=Women's Health Initiative; WISDOM=Women’s International Study of Long-Duration Oestrogen After Menopause.

Appendix C4 Evidence Table of Trials Reporting Incidence of Diabetes

Author, year; title | Population | Results (Treatment vs. Placebo) Diabetes incidence
Margolis, 2004;^38^ Effect of oestrogen plus progestin on the incidence of diabetes in postmenopausal women: results from the Women’s Health Initiative Hormone Trial. WHI Estrogen plus progestin trial | Excluded women with self-reported diabetes at baseline: 15,641 Enrolled 8,014 Estrogen plus progestin 7,627 Placebo | Incident diabetes 277 (3.5%) vs. 324 (4.2%); HR, 0.79 (95% CI, 0.67 to 0.93); p=0.006 Absolute reduction of 1.5 cases/1,000 women/year with estrogen plus progestin 21% relative reduction in the risk for incident treated diabetes 143 women would need to be treated with estrogen plus progestin to prevent 1 case of diabetes over 5.6 years
Bonds, 2006;^43^ The effect of conjugated equine oestrogen on diabetes incidence: the Women’s Health Initiative randomised trial. WHI Estrogen only trial | Excluded women with self-reported diabetes at baseline: 9,712 Enrolled 4,806 Estrogen 4,906 Placebo | Incident diabetes overall 397 (8.3%) vs. 455 (9.3%); HR, 0.88 (95% CI, 0.77 to 1.01); p=not significant Of those who adhered to ≥80% of medication 27% reduction in risk for new, treated diabetes in estrogen group compared with placebo group; HR, 0.73 (95% CI, 0.60 to 0.88)
Kanaya, 2003;^63^ Glycemic effects of postmenopausal hormone therapy: the Heart and Estrogen/Progestin Replacement Study. HERS Estrogen plus progestin trial | Excluded women with self-reported diabetes at baseline: 2,763 Enrolled 1,380 Estrogen plus progestin 1,383 Placebo | Cumulative incidence of new diabetes diagnosis Overall: 62/999 (6.2%) vs. 98/1030 (9.5%); NNT, 30 (95% CI, 18 to 103); p=0.006 Baseline normal glucose: 38/904 (4%) vs. 52/907 (6%); p=0.13 Baseline impaired fasting glucose: 24/95 (25%) vs. 46/123 (37%); p=0.06 Risk for incident diabetes Unadjusted: HR, 0.65 (95% CI, 0.48 to 0.89) Adjusted for BMI, weight, change in weight, and waist circumference: HR, 0.66 (95% CI, 0.48 to 0.93) Adjusted for triglyceride and HDL levels: HR, 0.69 (95% CI, 0.50 to 0.95) Adjusted for hypertension: HR, 0.65 (95% CI, 0.47 to 0.89) Adjusted for smoking: HR, 0.65 (95% CI, 0.47 to 0.89) Adjusted for medications (diuretics, β-blockers, ACE inhibitors, statins): HR, 0.63 (95% CI, 0.46 to 0.87) Adjusted for all above: HR, 0.67 (95% CI, 0.49 to 0.93)

Abbreviations: ACE=angiotensin-converting enzyme; BMI=body mass index; CI=confidence interval; HDL=high-density lipoprotein; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; NNT=number needed to treat; WHI=Women’s Health Initiative.

Appendix C5 Evidence Table of Trials Reporting Incidence of Cardiovascular Disease

Author, year; title | Population | Results (Treatment vs. Placebo) Cardiovascular disease incidence during intervention
Heiss, 2008;^33^ Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin (WHI, post-treatment). WHI Estrogen plus progestin trial | Women enrolled in WHI E+P trial: 8,052 Estrogen plus progestin 7,678 Placebo | Overall CHD 196 vs. 154; HR, 1.22 (95% CI, 0.99 to 1.51) CHD death 40 vs. 36; HR, 1.04 (95% CI, 0.67 to 1.64) Total MI 168 vs. 127; HR, 1.26 (95% CI, 1.00 to 1.59) Stroke 159 vs. 110; HR, 1.34 (95% CI, 1.05 to 1.71) DVT 122 vs. 61; HR, 1.88 (95% CI, 1.38 to 2.55) PE 87 vs. 41; HR, 1.98 (95% CI, 1.36 to 2.87) All CVD events 785 vs. 660; HR, 1.13 (95% CI, 1.02 to 1.25)
Manson, 2003;^37^ Estrogen plus progestin and the risk of coronary heart disease. WHI Estrogen plus progestin trial | Women enrolled in WHI E+P trial: 8,052 Estrogen plus progestin 7,678 Placebo | Overall CHD 188 vs. 147; HR, 1.24 (95% CI, 1.00 to 1.54) Nonfatal MI 151 vs. 114; HR, 1.28 (95% CI, 1.00 to 1.63) CHD death 39 vs. 34; HR, 1.10 (95% CI, 0.70 to 1.75) CHF 113 vs. 109; HR, 0.99 (95% CI, 0.76 to 1.29) Subgroups not associated with HT and outcomes Age, years since menopause, vasomotor symptoms, BMI, aspirin use, statin use, serum lipid levels except for LDL cholesterol, fibrinogen, Factor VIII:C, C-reactive protein, race or ethnic group, education level, current smoking, hypertension, diabetes, number of CHD risk factors, CVD at baseline, CHD at baseline. Subgroups associated with HT and outcomes LDL cholesterol level; also risk highest and most significant during the first year of the trial.
Wassertheil-Smoller, 2003;^41^ Effect of estrogen plus progestin on stroke in postmenopausal women: the Women’s Health Initiative: a randomized trial. WHI Estrogen plus progestin trial | Women enrolled in WHI E+P trial: 8,052 Estrogen plus progestin 7,678 Placebo | All stroke 151 vs. 107; HR, 1.31 (95% CI, 1.02 to 1.68) Ischemic stroke 125 vs. 81; HR, 1.44 (95% CI, 1.09 to 1.90) Hemorrhagic stroke 18 vs. 20; HR, 0.82 (95% CI, 0.43 to 1.56) Subgroups not associated with HT and outcomes Prior oral contraceptive use. Subgroups associated with HT and outcomes Current smoking, hypertension, diabetes, high Framingham stroke score, high white cell count or hematocrit, biomarkers of inflammation—but these did not modify the effect of HT on stroke. Reduced risk with vitamin C use and increased physical activity.
Cushman, 2004;^30^ Estrogen plus progestin and risk of venous thrombosis. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 8,052 Estrogen plus progestin 7,678 Placebo | VT 167 vs. 76; HR, 2.06 (95% CI, 1.57 to 2.70) DVT 123 vs. 59; HR, 1.95 (95% CI, 1.43 to 2.67) PE 86 vs. 38; HR, 2.13 (95% CI, 1.45 to 3.11) Subgroups not associated with HT and outcomes Genetic variants except Factor V Leiden. Subgroups associated with HT and outcomes Age, BMI, Factor V Leiden.
Rossouw, 2007;^39^ Postmenopausal hormone therapy and risk of cardiovascular disease by age and years since menopause. WHI Estrogen plus progestin and estrogen only trials | Women enrolled in WHI trial: 8,052 Estrogen plus progestin 7,678 Placebo 5,310 Estrogen 5,429 Placebo | Overall CHD Combined trials: 396 vs. 379; HR, 1.07 (95% CI, 0.92 to 1.23) E+P: 195 vs. 153; HR, 1.23 (95% CI, 0.99 to 1.53) Estrogen only: 201 vs. 217; HR, 0.95 (95% CI, 0.78 to 1.16) Stroke Combined trials: 327 vs. 239; HR, 1.32 (95% CI, 1.12 to 1.56) E+P: 159 vs. 112; HR, 1.31 (95% CI, 1.03 to 1.68) Estrogen only: 169 vs. 127; HR, 1.33 (95% CI, 1.05 to 1.68) Subgroups not associated with HT and outcomes Age, years since menopause for stroke. Subgroups associated with HT and outcomes Years since menopause for CHD. Interaction with CHD and vasomotor symptoms at baseline.
LaCroix, 2011;^49^ Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy post-intervention. WHI Estrogen only trial | Women enrolled in WHI trial: 5,310 Estrogen 5,429 Placebo | Overall CHD 203 vs. 221; HR, 0.95 (95% CI, 0.78 to 1.15) CHD death 63 vs. 66; HR, 0.98 (95% CI, 0.70 to 1.39) Total MI 164 vs. 173; HR, 0.98 (95% CI, 0.79 to 1.21) Stroke 169 vs. 129; HR, 1.36 (95% CI, 1.08 to 1.71) DVT 85 vs. 59; HR, 1.47 (95% CI, 1.06 to 2.05) PE 52 vs. 39; HR, 1.37 (95% CI, 0.90 to 2.07) All CVD events 874 vs. 811; HR, 1.11 (95% CI, 1.01 to 1.23)
Hsia, 2006;^48^ Conjugated equine estrogens and coronary heart disease: the Women’s Health Initiative. WHI Estrogen only trial | Women enrolled in WHI trial: 5,310 Estrogen 5,429 Placebo | CHD outcomes not significantly different between estrogen vs. placebo MI or CHD death, nonfatal MI, coronary death, CABG or PCI, angina, CHF, acute coronary syndrome, combinations of outcomes. Subgroups not associated with CEE and CHD outcomes Race or ethnic group, level of education, smoking, hypertension, diabetes, high cholesterol requiring medication, coronary risk factors, CVD at baseline, CHD at baseline, age, vasomotor symptoms, years since bilateral oophorectomy, years since hysterectomy, BMI, waist circumference, statin use at baseline, aspirin use at baseline, serum lipid levels, fibrinogen levels, Factor VIII:C. Significant association High C-reactive protein levels.
Hendrix, 2006;^47^ Effects of conjugated equine estrogen on stroke in the Women’s Health Initiative. WHI Estrogen only trial | Women enrolled in WHI trial: 5,310 Estrogen 5,429 Placebo | All stroke 168 vs. 127; HR, 1.37 (95% CI, 1.09 to 1.73) Ischemic stroke 142 vs. 95; HR, 1.55 (95% CI, 1.19 to 2.01) Hemorrhagic stroke 17 vs. 27; HR, 0.64 (95% CI, 0.35 to 1.18) Subgroups not associated with HT and outcomes Age, race or ethnicity, years since menopause, prior CVD, hypertension, diabetes, BMI, smoking, prior HT use and duration, statin use, aspirin use, vasomotor symptoms, Framingham risk score. Subgroups not associated with HT and outcomes None.
Curb, 2006;^46^ Venous thrombosis and conjugated equine estrogen in women without a uterus. WHI Estrogen only trial | Women enrolled in WHI trial: 5,310 Estrogen 5,429 Placebo | VT 111 vs. 86; HR, 1.32 (95% CI, 0.99 to 1.75) DVT 85 vs. 59; HR, 1.47 (95% CI, 1.06 to 2.06) PE 52 vs. 39; HR, 1.37 (95% CI, 0.90 to 2.07) Subgroups not associated with HT and outcomes Age, BMI, race or ethnicity, smoking, prior HT use, prior oral contraceptives, physical activity level (borderline significance), dietary fatty acid intake, dietary fish intake, treatment for hypertension, aspirin use, statin use, history of CVD, time in the study, multiple genetic variants, serum cholesterol levels except HDL. Subgroups associated with HT and outcomes HDL cholesterol level, but no estimates were statistically significant.

Abbreviations: BMI=body mass index; CABG=coronary artery bypass graft; CEE=conjugated equine estrogen; CHD=coronary heart disease; CHF=coronary heart failure; CI=confidence interval; CVD=cardiovascular disease; DVT=deep vein thrombosis; E+P=estrogen with progestin; HDL=high-density lipoprotein; HR=hazard ratio; HT=hormone therapy; LDL=low-density lipoprotein; MI=myocardial infarction; PCI=percutaneous coronary intervention; PE=pulmonary embolism; VT=venous thrombosis; WHI=Women’s Health Initiative.

Appendix C6 Evidence Table of Trials Reporting Incidence of Fractures

Author, year; title | Population | Results (Treatment vs. Placebo) Fracture incidence
Cauley, 2003;^24^ Effects of estrogen plus progestin on risk of fracture and bone mineral density. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 8,506 Estrogen plus progestin 8,102 Placebo | Hip 52 vs. 73; HR, 0.67 (95% CI, 0.47 to 0.96) No significant interactions with age, years since menopause, BMI, smoking, number of recent falls, parental history of fracture, previous HT, history of fracture, or fracture risk score; improved effect with calcium intake >1200 mg/d. Total 733 vs. 896; HR, 0.76 (95% CI, 0.69 to 0.83) No significant interactions with age, years since menopause, BMI, smoking, number of recent falls, total calcium intake, parental history of fracture, previous HT, race or ethnicity, history of fracture, fracture risk score, or low baseline BMD.
Rossouw, 2002;^12^ Risks and benefits of estrogen plus progestin in healthy postmenopausal women. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 8,506 Estrogen plus progestin 8,102 Placebo | Hip 44 vs. 62; HR, 0.66 (95% CI, 0.45 to 0.98) Vertebral 41 vs. 60; HR, 0.66 (95% CI, 0.44 to 0.98) Other osteoporotic 579 vs. 701; HR, 0.77 (95% CI, 0.69 to 0.86) Total 650 vs. 788; HR, 0.76 (95% CI, 0.69 to 0.85)
LaCroix, 2011;^49^ Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy post-intervention. WHI Estrogen only trial | Women enrolled in WHI trial: 5,310 Estrogen 5,429 Placebo | Hip intervention 48 vs. 74; HR, 0.67 (95% CI, 0.46 to 0.96) Hip postintervention 66 vs. 53; HR, 1.27 (95% CI, 0.88 to 1.82) Hip overall 114 vs. 127; HR, 0.92 (95% CI, 0.71 to 1.18)
Anderson, 2004;^42^ Effects of conjugated equine estrogen in postmenopausal women with hysterectomy. WHI Estrogen only trial | Women enrolled in WHI trial: 5,310 Estrogen 5,429 Placebo | Hip 38 vs. 64; HR, 0.61 (95% CI, 0.41 to 0.91) Vertebral 39 vs. 64; HR, 0.62 (95% CI, 0.42 to 0.93) Total 503 vs. 724; HR, 0.70 (95% CI, 0.63 to 0.79) No significant interactions with age.
Hulley, 2002;^61^ Noncardiovascular disease outcomes during 6.8 years of hormone therapy (Heart and Estrogen/Progestin Replacement Study follow-up, HERS II). HERS II Estrogen plus progestin trial | Women from original HERS trial who consented to followup: 2,321 | Hip 40 vs. 25; HR, 1.61 (95% CI, 0.98 to 2.66) Wrist 42 vs. 43; HR, 0.98 (95% CI, 0.64 to 1.50) Vertebral 26 vs. 30; HR, 0.87 (95% CI, 0.52 to 1.48) Other 144 vs. 154; HR, 0.94 (95% CI, 0.75 to 1.18) Any 230 vs. 222; HR, 1.04 (95% CI, 0.87 to 1.25)

Abbreviations: BMD=bone mineral density; BMI=body mass index; CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; HT=hormone therapy; WHI=Women’s Health Initiative.

Appendix C7 Evidence Table of Trials Reporting Incidence of Lung Cancer

Author, year; title | Population | Results (Treatment vs. Placebo) Lung cancer incidence
Chlebowski, 2009;^27^ Ostrogen plus progestin and lung cancer in postmenopausal women (Women’s Health Initiative trial): a post-hoc analysis of a randomised controlled trial. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 16,608 Enrolled 8,506 Estrogen plus progestin 8,102 Placebo | Lung cancer incidence 109 vs. 85; HR, 0.23 (95% CI, 0.92 to 1.63); p=0.16 Lung cancer mortality Mortality from lung cancer: 73 vs. 40; HR, 1.71 (95% CI, 1.6 to 2.52); p=0.01 Non-small cell: 62 vs. 31; HR, 1.87 (95% CI, 1.22 to 2.88); p=0.004 Small cell: 11 vs. 9; HR, 1.16 (95% CI, 0.48 to 2.79); p=0.75 Mortality after diagnosis: 78 vs. 49; HR, 1.50 (95% CI, 1.05 to 2.14); p=0.03 Non-small cell: 67 vs. 39; HR, 1.61; (95% CI, 1.09 to 2.39); p=0.02 Small cell: 11 vs. 10; HR, 1.04 (95% CI, 0.44 to 2.46); p=0.92
Chlebowski, 2010;^45^ Lung cancer among postmeopausal women treated with estrogen alone in the Women’s Health Initiative randomized trial. WHI Estrogen only trial | Women enrolled in WHI trial: 10,739 Enrolled 5,310 Estrogen 5,429 Placebo | Lung cancer incidence 61 vs. 54; HR, 1.17 (95% CI, 0.81 to 1.69); p =0.39
Hulley 2002;^61^ Noncardiovascular disease outcomes during 6.8 years of hormone therapy (Heart and Estrogen/Progestin Replacement Study follow-up, HERS II). HERS II Estrogen plus progestin trial | Women who agreed to be followed after HERS termination: 2,321 (93% of surviving patients from HERS) | Lung cancer HERS: 24 vs. 19; HR, 1.28 (95% CI, 0.70 to 2.33); p=0.43 HERS II: 13 vs. 8; HR, 1.64 (95% CI, 0.68 to 3.96); p=0.27 Total: 37 vs. 27; HR, 1.39 (95% CI, 0.84 to 2.28); p=0.20 Treatment-time interaction: p=0.64 Unadjusted ITT vs. adjusted ITT vs. adjusted as-treated 1.39 vs. 1.43 vs. 1.73
Tierney, 2009;^68^ A randomized double-blind trial of the effects of hormone therapy on delayed verbal recall in older women. EMS Estrogen plus progestin trial | Women enrolled in EMS trial: 142 Enrolled 70 Estrogen plus progestin 72 Placebo | Lung cancer 1 (1.4%) vs. 0 Lung cancer mortality 1 vs. 0

Abbreviations: CI=confidence interval; EMS=Estrogen Memory Study; HERS=Heart and Estrogen/Progestin Replacement Study; HERS II=Heart and Estrogen/Progestin Replacement Study Phase II; HR=hazard ratio; ITT=intention to treat; WHI=Women’s Health Initiative.

Appendix C8 Evidence Table of Trials Reporting Incidence of Gynecological Cancers

Author, year; title | Population | Results (Treatment vs. Placebo)
Author, year; title | Population | Gynecological cancer incidence | Other outcomes
Heiss, 2008;^33^ Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 15,730 Analyzed 8,052 Estrogen plus progestin 7,678 Placebo | Endometrial cancer (postintervention phase only) 17 (0.09 annualized %) vs. 21 (0.11 annualized %); HR, 0.75 (95% CI, 0.40 to 1.43); p=0.83 Endometrial cancer (intervention and postintervention phases combined) 44 (0.07 annualized %) vs. 52 (0.08 annualized %); HR, 0.78 (95% CI, 0.52 to 1.16) | Not reported
Anderson, 2004;^42^ Effects of estrogen plus progestin on gynecological cancers and associated diagnostic procedures: the Women’s Health Initiative randomized trial. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 16,608 Enrolled 8,506 Estrogen plus progestin 8,102 Placebo | Ovarian cancer 20 (0.04 annualized %) vs. 12 (0.03 annualized %); HR, 1.58 (95% CI, 0.77 to 3.24) Mortality: 9 vs. 3; HR, 2.70 (95% CI, 0.73 to 10.0) Observed annual incidence rate: 34 per 100,000 person-years Rate of diagnosis: 42 per 100,000 person-years vs. 27 per 100,000 person-years Endometrial cancer 27 (0.06 annualized %) vs. 31 (0.07 annualized %); HR, 0.81 (95% CI, 0.48 to 1.36) Observed incidence rate: 62 per 100,000 person-years Rate of diagnosis: 56 per 100,000 person-years vs. 69 per 100,000 person-years Cervical cancer 8 (0.02 annualized %) vs. 5 (0.01 annualized %); HR, 1.44 (95% CI, 0.47 to 4.42) Other gynecological cancer (including fallopian, primary peritoneum cancers) 6 (<0.01%) vs. 1 (<0.01%); HR, not reported | Followup endometrial biopsy Routine biopsy subgroup and endometrial cancer: 0 vs. 0 Usual care subgroup and endometrial cancer: 7 (0.3%) vs. 7 (1.6%)
Hulley, 2002;^61^ Noncardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/Progestin Replacement Study Follow-up HERS II Estrogen plus progestin trial | Women reconsenting to followup period of HERS study: 2,485 Eligible from HERS 1,156 Estrogen plus progestin 1,165 Placebo | Endometrial cancer HERS: 2 (0.4 events per 1,000 person-years) vs. 5 (0.9 events per 1,000 person-years); HR, 0.39 (95% CI, 0.08 to 2.02); p=0.26 HERS II: 0 vs. 3 (1.0 events per 1,000 person-years) Interaction between HR in HERS and HERS II: p=0.99 HERS and HERS II combined: 2 (0.2 events per 1,000 person-years) vs. 8 (0.9 events per 1,000 person-years); HR, 0.25 (95% CI, 0.05 to 1.18); p=0.08 | Not reported
Cherry, 2002;^67^ Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. ESPRIT Estrogen alone | Women enrolled in ESPRIT trial: 1,017 Enrolled 513 Estrogen 504 Placebo | Endometrial cancer 0 vs. 0 | 208/373 women without hysterectomy had vaginal bleeding with treatment; 189 had biopsy; 8/189 had atypical hyperplasia, 12 complex hyperplasia, 57 simple hyperplasia, and 112 negative biopsy. Endometrium of all women with abnormal biopsy reverted to normal after treatment with medroxyprogesterone or cessation of estrogen. No women required hysterectomies because of bleeding or abnormal histology.
Johnson, 2005;^70^ Uterine and vaginal effects of unopposed ultralow-dose transdermal estradiol. ULTRA Estrogen alone | Women enrolled in ULTRA trial: 417 Enrolled 208 Estrogen 209 Placebo Analysis focused on women with endometrial biopsy results: 188 Estrogen 177 Placebo | Endometrial cancer 0.0% (95% CI, 0 to 1.9) vs. 0.0% (95% CI, 0.0 to 2.1); difference=0.0 (95% CI, −4.2 to 3.1); p=1.000 | Benign or atrophic endometrium: 83.5% vs. 86.4%; p=0.5 Proliferative endometrium: 8.5% vs. 1.1%; p=0.06 Of 11 women in estradiol group who had biopsy showing proliferation, none had progressively higher histological diagnoses and 9 (82%) reverted to benign, nonproliferative histology. All 11 women had continued on estradiol therapy. Women with vaginal bleeding 90 days prior to biopsy were more likely to have proliferation than those without bleeding (OR, 9.5 [95% CI, 1.1 to 84]; p=0.04).

Abbreviations: CI=confidence interval; EMS=Estrogen Memory Study; ESPRIT=Oestrogen in the Prevention of Reinfarction Trial; HERS=Heart and Estrogen/Progestin Replacement Study; HERS II=Heart and Estrogen/Progestin Replacement Study Phase II; HR=hazard ratio; OR=odds ratio; ULTRA=Ultra-Low-Dose Transdermal Estrogen Replacement Assessment; WHI=Women’s Health Initiative.

Appendix C9 Evidence Table of Trials Reporting Incidence of Mortality

Author, year; title | Population | Results (Treatment vs. Placebo) Mortality incidence
Heiss, 2008;^33^ Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin. WHI Estrogen plus progestin trial | All women enrolled in WHI trial followed through postintervention phase | All-cause mortality No differences between groups During treatment 250 (2.9%) vs. 239 (3%); HR, 0.97 (95% CI, 0.81 to 1.16) Annualized rate: 0.52 vs. 0.53 Posttreatment 233 (2.9%) vs. 196 (2.5%); HR, 1.15 (95% CI, 0.95 to 1.39) Annualized rate: 1.20 vs. 1.06 Overall 483 (5.7%) vs. 435 (5.4%); HR, 1.04 (95% CI, 0.91 to 1.18) Annualized rate: 0.71 vs. 0.68
LaCroix, 2011;^49^ Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy. WHI Estrogen only trial | All women enrolled in WHI trial followed through postintervention extension phase | All-cause mortality No differences between groups During treatment 300 (5.6%) vs. 297 (5.5%); HR, 1.04 (95% CI, 0.89 to 1.22) Annualized rate: 0.80 vs. 0.77 Posttreatment 277 (5.8%) vs. 284 (5.8%); HR, 1.00 (95% CI, 0.84 to 1.18) Annualized rate: 1.47 vs. 1.48 Overall 577 (10.9%) vs. 581 (10.7%); HR, 1.02 (95% CI, 0.91 to 1.15) Annualized rate: 1.02 vs. 1.00
Hulley, 2002;^61^ Noncardiovascular disease outcomes during 6.8 years of hormone therapy. HERS II Estrogen plus progestin trial | All women enrolled in HERS trial followed through HERS II | All-cause mortality No differences between groups During treatment 130 (9.4%) vs. 123 (8.9%); HR, 1.06 (95% CI, 0.83 to 1.36); p=0.62 23.5 per 1,000 person-years vs. 22.1 per 1,000 person-years Posttreatment 131 (11.3%) vs. 116 (9.9%); HR, 1.14 (95% CI, 0.89 to 1.46); p=0.31 43.4 per 1,000 person-years vs. 38.1 per 1,000 person-years Overall 261 (18.9%) vs. 239 (17.3%); HR, 1.10 (95% CI, 0.92 to 1.31); p=0.29 30.6 per 1,000 person-years vs. 27.8 per 1,000 person-years
Cherry, 2002;^67^ Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. ESPRIT Estrogen only trial | All women enrolled in ESPRIT trial followed through trial completetion | All-cause mortality 32 (6.2%) vs. 39 (7.7%); Rate ratio, 0.79 (95% CI, 0.50 to 1.27); p=0.34

Abbreviations: CI=confidence interval; ESPRIT=Oestrogen in the Prevention of Reinfarction Trial; HERS=Heart and Estrogen/Progestin Replacement Study; HERS II=Heart and Estrogen/Progestin Replacement Study Phase II; HR=hazard ratio; WHI=Women’s Health Initiative.

Appendix C10 Evidence Table of Trials Reporting Incidence of Gallbladder Disease

Author, year; title | Population | Results (Treatment vs. Placebo)
Author, year; title | Population | Gallbladder event incidence | Other outcomes
Cirillo, 2005;^29^ Effect of estrogen therapy on gallbladder disease. WHI Estrogen plus progestin and estrogen only trials | Excluded women with cholecystectomy at baseline. 14,203 (85.5%) Eligible from WHI estrogen plus progestin trial: 7,308 Estrogen plus progestin 6,895 Placebo 8,376 (77.99%) Eligible from WHI estrogen only trial: 4,141 Estrogen 4,235 Placebo | Annual incidence rate for any gallbladder event E+P: 5.5/1,000 person-years vs. 3.5/1,000 person-years E: 7.8/1,000 person-years vs. 4.7/1,000 person-years | Cholecystectomy E+P: 190 (2.6%) vs. 107 (1.5%); HR, 1.67 (95% CI, 1.32 to 2.11); p<0.001 E: 192 (4.6%) vs. 104 (2.4%); HR, 1.93 (95% CI, 1.52 to 2.44); p<0.001 Global gallbladder disease E+P: 223 (3.0%) vs. 130 (1.9%); HR, 1.61 (95% CI, 1.30 to 2.00); p<0.001 E: 223 (5.4%) vs. 130 (3.1%); HR, 1.79 (95% CI, 1.44 to 2.22); p<0.001 Cholecystitis E+P: 192 (2.6%) vs. 117 (1.7%); HR, 1.54 (95% CI, 1.22 to 1.94); p<0.001 E: 186 (4.5%) vs. 107 (2.5%); HR, 1.80 (95% CI, 1.42 to 2.28); p<0.001

Abbreviations: CI=confidence interval; E=estrogen; E+P=estrogen with progestin; HR=hazard ratio; WHI=Women’s Health Initiative.

Appendix C11 Evidence Table of Trials Reporting Incidence of Cognitive Functioning

Author, year; title | Population | Results (Treatment vs. Placebo)
Author, year; title | Population | PD incidence | MCI incidence | Other dementia diagnosis outcomes | 3MSE Scores | Other measures
Shumaker, 2003;^55^ Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. WHIMS Estrogen plus progestin trial | Women enrolled in WHI trial aged ≥65 years without probable dementia: 4,532 Enrolled 2,229 Estrogen plus progestin 2,303 Placebo | 40 (1.8%) vs. 21 (0.9%) 4.5 vs. 2.2 per 1,000 person-years HR, 2.05 (95% CI, 1.21 to 3.48); p=0.01 | 56 (2.5%) vs. 55 (2.4%) 6.3 vs. 5.9 per 1,000 person-years HR, 1.07 (95% CI, 0.74 to 1.55); p=0.72 | PD or MCI: 85 (3.8%) vs. 66 (2.9%) PD or MCI per 1,000 person-years: 9.5 vs. 7.1 HR, 1.37 (95% CI, 0.99 to 1.89); p=NR No differences between groups in type of dementia diagnosed, with majority being diagnosed AD: 20 (50%) vs. 12 (57.1%) | NR | NR
Rapp, 2003;^53^ Effect of estrogen plus progestin on global cognitive function in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. WHIMS Estrogen plus progestin trial | Women enrolled in WHI trial aged ≥65 years without probable dementia and with >1 postrandomization 3MSE score: 4,381 Enrolled 2,145 Estrogen plus progestin 2,236 Placebo | NR | NR | NR | Mean change from baseline in 3MSE Overall: 0.149 (SE, 0.021) vs. 0.213 (SE, 0.020); difference: −0.063 (95% CI, −1.20 to −0.006); p=0.03 | NR
Espeland, 2004;^52^ Conjugated equine estrogens and global cognitive function in postmenopausal women: Women’s Health Initiative Memory Study. WHIMS Estrogen plus progestin and estrogen only trial | Women enrolled in WHI trial aged ≥65 years without probable dementia, enrolled in WHIMS >6 months after initiation of assigned WHI therapy and with >1 post-randomization 3MSE score: 4,344 Enrolled 2,131 Estrogen plus progestin 2,213 Placebo 1,387 Estrogen 1,421 Placebo | NR | NR | NR | Mean difference in change from baseline in 3MSE E+P: No differences E: Overall: −0.26 (95% CI, −0.52 to 0.00); p=0.04 No difference between groups on means | NR
Resnick, 2006;^58^ Effects of combination estrogen plus progestin hormone treatment on cognition and affect. WHISCA Estrogen plus progestin trial | Women enrolled in WHIMS trial, limited to 14 of 39 WHIMS locations: 1,416 Enrolled 690 Estrogen plus progestin 726 Placebo | 5 (0.7%) vs. 6 (0.8%) | 6 (0.9%) vs. 13 (1.8%) | NR | NR | Differences BVRT errors: −0.27 (SE, 0.11); p=0.012 CVLT total list A: −0.52 (SE, 0.20); p=0.0009 CVLT short-delay free: −0.24 (SE, 0.10); p=0.016 CVLT long-delay free: −0.23 (SE, 0.10); p=0.015
Espeland, 2010;^56^ Long-term effects of conjugated equine estrogen therapies on domain-specific cognitive function: results from the Women’s Health Initiative Study of Cognitive Aging Extension. WHISCA Estrogen plus progestin trial | Women enrolled in WHISCA and participated in extension after termination of trial | NR | NR | NR | NR | On trial Global cognitive function: −0.080 (SE, 0.034); p=0.02 Posttrial No differences between groups
Shumaker, 2004;^54^ Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women’s Health Initiative Memory Study. WHIMS Estrogen only trial | Women enrolled in WHI trial aged ≥65 years without probable dementia: 2947 Enrolled 1464 Estrogen 1483 Placebo | 28 (1.9%) vs. 19 (1.3%) 3.7 vs. 2.5 per 1,000 person-years HR, 1.49 (95% CI, 0.83 to 2.66); p=0.18 | 7.6 vs. 5.8 per 1,000 person-years HR, 1.34 (95% CI, 0.95 to 1.89); p=NS | PD or MCI: 93 (6.4%) vs. 69 (4.7%) PD or MCI per 1,000 person-years: 12.6 vs. 9.1 HR, 1.38 (95% CI, 1.01 to 1.89); p=0.04 No differences between groups in type of dementia diagnosed with majority being diagnosed AD: 13 (46.4%) vs. 9 (47.4%) | NR | NR
Resnick, 2009;^57^ Effects of conjugated equine estrogens on cognition and affect in postmenopausal women with prior hysterectomy. WHISCA Estrogen only trial | Women enrolled in WHIMS trial, limited to 14 of 39 WHIMS locations: 866 Enrolled 434 Estrogen 452 Placebo | 4 (0.9%) vs. 2 (0.4%) | 18 (4.1%) vs. 15 (3.3%) | NR | NR | Differences in change Card rotations: 1.26 (SE, 0.48); p=0.008 No other differences on any measures
Espeland, 2010;^56^ Long-term effects of conjugated equine estrogen therapies on domain-specific cognitive function: results from the Women’s Health Initiative Study of Cognitive Aging Extension. WHISCA Estrogen only trial | Women enrolled in WHISCA and participated in extension after termination of trial | NR | NR | NR | NR | Intervention Global cognitive function: −0.092 (SE, 0.039); p=0.02 Verbal knowledge: −0.100 (SE, 0.051); p=0.05 Verbal fluency: −0.118 (SE, 0.054); p=0.03 Figural memory: −0.132 (SE, 0.048); p=0.006 Spatial ability: −0.137 (SE, 0.057); p=0.02 Fine motor speed: −0.171 (SE, 0.053); p=0.001 Postintervention Spatial ability: −0.179 (SE, 0.063); p=0.004
Grady, 2002;^65^ Effect of postmenopausal hormone therapy on cognitive function: the Heart and Estrogen/Progestin Replacement Study. HERS Estrogen plus progestin trial | Completed HERS trial at any 1 of 10 out of 20 centers: 1,063 Enrolled 662 Estrogen plus progestin 666 Placebo | NR | NR | NR | No differences between groups | Verbal fluency 15.9 (SD, 4.8) vs. 16.6 (SD, 4.8); difference= −0.7 (95% CI, −1.3 to −0.1); p=0.02 No other differences betweeen groups
Tierney, 2009;^68^ A randomized duoble-blind trial of the effects of hormone therapy on delayed verbal recall in older women. EMS Estrogen plus progestin trial | Women aged ≥60 years with last menstrual period ≥12 months before, with normal to just below normal scores on cogntive battery tests, but free of dementia: 142 Enrolled 70 Estrogen plus progestin 72 Placebo | NR | NR | NR | No differences between groups | Of those at or above average scores at baseline (N=37 vs. 36) Mean adjusted CVLT short-delay recall year 1: 10.37 vs. 8.67; p=0.007 Mean adjusted CVLT short-delay recall year 2: 10.61 vs. 9.02; p=0.01
Yaffe, 2006;^72^ Effects of ultra-low-dose transdermal estradiol on cognition and health-related quality of life. ULTRA Estrogen only trial | Women aged 60–80 years with an intact uterus and ≥5 years beyond menopause with normal BMD: 417 Enrolled 208 Estrogen 209 Placebo | NR | NR | NR | Mean difference between groups (estradiol tertile 1 vs. 2 vs. 3) 3MSE: −2.01 (p<0.001) vs. 0.01 (p=0.99) vs. −0.22 (p=0.73); overall p=0.05 No other differences | No differences between groups on any tests

Abbreviations: 3MSE=Modified Mini-Mental State Examination; AD=Alzheimer’s Disease; BMD=bone mineral density; BVRT=Benton Visual Retention Test; CI=confidence interval; CVLT=California Verbal Learning Test; EMS=Estrogen Memory Study; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; MCI=mild cognitive impairment; NR=not reported; NS=not significant; PD=probable dementia; SD=standard deviation; SE=standard error; WHI=Women’s Health Initiative; WHIMS=Women’s Health Initiative Memory Study; WHISCA=Women’s Health Initiative Study of Cognitive Aging; ULTRA=Ultra Low-Dose Transdermal Estrogen Replacement Assessment.

Appendix C12 Evidence Table of Trials Reporting Incidence of Urinary Incontinence

Author, year; title | Population | Results (Treatment vs. Placebo) Urinary incontinence incidence
Hendrix, 2005;^35^ Effects of estrogen with and without progestin on urinary incontinence. WHI Estrogen plus progestin and estrogen only trials | Analysis focused on women with urinary incontinence data at baseline and 1 year: 7,247 Estrogen plus progestin (2,675 continent at baseline) 7,056 Placebo (2,507 continent at baseline) 4,476 Estrogen (1,526 continent at baseline) 4,517 Placebo (1,547 continent at baseline) | Results at 1 year [underlined: Estrogen and progestin] Incident UI: 834 vs. 563; RR, 1.39 (95% CI, 1.27 to 1.52) Stress UI: 429 (16.0%) vs. 218 (8.7%); RR, 1.87 (95% CI, 1.61 to 2.18); p<0.001 Urge UI: 304 (11.4%) vs. 272 (10.8%); RR, 1.15 (95% CI, 0.99 to 1.34); p=0.06 Mixed UI: 99 (3.7%) vs. 69 (2.8%); RR, 1.49 (95% CI, 1.10 to 2.01); p=0.01 [underlined: Estrogen only] Incident UI: 557 vs. 368; RR, 1.53 (95% CI, 1.37 to 1.71) Stress UI: 266 (17.4%) vs. 131 (8.5%); RR, 2.15 (95% CI, 1.77 to 2.62); p<0.001 Urge UI: 210 (13.8%) vs. 184 (11.9%); RR, 1.32 (95% CI, 1.10 to 1.58); p=0.003 Mixed UI: 76 (5.0%) vs. 50 (3.2%); RR, 1.79 (95% CI, 1.26 to 2.53); p=0.001 Results at 3 years [underlined: Estrogen and progestin] 39/153 (25.5%) vs. 26/185 (14.1%) of continent women at baseline and 1 year reported incident UI at 3 years (RR, 1.81 [95% CI, 1.16 to 2.84]) 51/172 (70.8%) vs. 40/57 (70.2%) of women with incident UI at 1 year still had UI at 3 years (p=0.94) [underlined: Estrogen only] 27/96 (28.1%) vs. 26/136 (19.1%) of continent women at baseline and 1 year reported incident UI at 3 years (RR, 1.47 [95% CI, 0.92 to 2.36]) 43/60 (71.7%) vs. 26/38 (68.4%) of women with incident UI at 1 year still had UI at 3 years (p=0.73)
Steinauer, 2005;^64^ Postmenopausal hormone therapy: does it cause incontinence? HERS Estrogen plus progestin trial | Analysis focused on women reporting no episodes of incontinence in the past week at baseline: 1,208 Enrolled 597 Estrogen plus progestin 611 Placebo | Odds ratio Weekly UI: OR, 1.6 (95% CI, 1.3 to 1.9); p<0.001 Urge UI: OR, 1.5 (95% CI, 1.2 to 1.8); p<0.001 Stress UI: OR, 1.7 (95% CI, 1.5 to 2.1); p<0.00 Cumulative 4-year risk Weekly UI: 64% vs. 49%; excess risk, 15% Urge UI: 48% vs. 36%; excess risk, 12% Stress UI: 54% vs. 38%; excess risk, 16% Number needed to harm Weekly UI: 6.9 (95% CI, 5.0 to 11.1) Urge UI: 8.6 (95% CI, 5.8 to 16.6) Stress UI: 6.2 (95% CI, 4.6 to 9.4)
Waetjen, 2005;^71^ The effect of ultra-low dose transdermal estradiol on urinary incontinence in postmenopausal women. ULTRA Estrogen only trial | Women enrolled in ULTRA trial who were continent at baseline: 605 Eligible 208 Estrogen 209 Placebo | 39.0% vs. 36.8%; OR, 1.2 (95% CI, 0.7 to 2.2); p=0.74

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; HERS II=Heart and Estrogen/Progestin Replacement Study Phase II; HR=hazard ratio; OR=odds ratio; RR=relative risk; UI=urinary incontinence; ULTRA=Ultra Low-Dose Transdermal Estrogen Replacement Assessment; WHI=Women’s Health Initiative.

Appendix C13 Evidence Table of Trials Reporting Outcomes by Subgroups

Author, year; title | Population | Results (Treatment vs. Placebo)
Colorectal cancer
Ritenbaugh, 2008;^50^ Conjugated equine estrogens and colorectal cancer incidence and survival: the Women’s Health Initiative randomized clinical trial. WHI Estrogen only trial | Excluded women with history of breast cancer and medical conditions likely to result in death in the next 3 years. 10,739 Enrolled 5,310 Estrogen 5,429 Placebo | Incidence (annualized rate) of invasive colorectal cancer [underlined: Overall:] 58 (0.15%) vs. 53 (0.14%); HR, 1.12 (95% CI, 0.77 to 1.63) [underlined: History of polyp removal] No: 40 (0.13%) vs. 46 (0.15%); HR, 0.87 (95% CI, 0.57 to 1.33) Yes: 9 (0.29%) vs. 0 (0.00); HR, not reported [underlined: Height (cm);] p=0.03 96.0–158.6: 26 (0.21%) vs. 12 (0.10%); HR, 2.12 (95% CI, 1.074 to 4.19) 158.7–163.9: 18 (0.15%) vs. 15 (0.12%); HR, 1.27 (95% CI, 0.64 to 2.52) 164.0–188.3: 14 (0.11%) vs. 26 (0.20%); HR, 0.57 (95% CI, 0.29 to 1.10) [underlined: Waist circumference (cm);] p=0.03 37.1–84.9: 22 (0.17%) vs. 11 (0.09%); HR, 2.03 (95% CI, 0.98 to 4.19) 85.0–96.9: 18 (0.15%) vs. 17 (0.13%); HR, 1.14 (95% CI, 0.59 to 2.22) 97.0–191.6: 18 (0.14%) vs. 25 (0.20%); HR, 0.68 (95% CI, 0.37 to 1.25)
LaCroix, 2011;^49^ Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy postintervention. WHI Estrogen only trial | All women enrolled in WHI trial followed after completion of trial (postintervention phase): 10,739 Enrolled 5,310 Estrogen 5,429 Placebo | Cumulative annualized rates for colorectal cancer [underlined: Age at screening (years)] 50–59: 14 vs. 18; HR, 0.80 (95% CI, 0.40 to 1.61); p=0.04 60–69: 37 vs. 43 ; HR, 0.90 (95% CI, 0.58 to 1.39); p =0.04 70–79: 38 vs. 21; HR, 1.83 (95% CI, 1.08 to 3.12); p=0.04
Anderson, 2004;^42^ Effects of conjugated equine estrogen in postmenopausal women with hysterectomy. WHI Estrogen only trial | Women enrolled in WHI trial (intervention phase): 10,739 Enrolled 5,310 Estrogen 5,429 Plaecbo | Colorectal cancer [underlined: Age at screening (years);] p=0.048 50–59: 8 vs. 14; HR, 0.59 (95% CI, 0.25 to 1.41) 60–69: 26 vs. 31; HR, 0.88 (95% CI, 0.52 to 1.48) 70–79: 27 vs. 13; HR, 2.09 (95% CI, 1.08 to 4.04)
Breast cancer
Chlebowski, 2010;^25^ Estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women. WHI Estrogen plus progestin trial | All women enrolled in WHI trial followed after completion of trial (postintervention and extension phase). Estrogen plus progestin Intervention phase: 8,506 Postintervention phase: 8,056 Extension phase analyzed: 8,506 Placebo Intervention phase: 8,102 Postintervention phase: 7,682 Extension phase analyzed: 8,102 | Prior menopausal hormone therapy use (annualized %) No prior use: 312 (0.42%) vs. 257 (0.36%); HR, 1.16 (95% CI, 0.98 to 1.37) Prior use (current/past): 73 (0.44%) vs. 36 (0.23%); HR,1.85 (95% CI, 1.25 to 2.80); p=0.03
Chlebowski, 2003;^26^ Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative randomized trial. WHI Estrogen plus progestin trial | Women enrolled in WHI trial: 16,608 Enrolled 8,506 Estrogen plus progestin 8,102 Placebo | Invasive breast cancer [underlined: Without prior menopausal hormone therapy use] Treatment (6,277) vs. placebo (6,020) Year 1 after entry: 7 (0.11%) vs. 14 (0.23%); HR, 0.48 (95% CI, 0.19 to 1.20) Year 2 after entry: 15 (0.24%) vs. 22 (0.37%); HR, 0.65 (95% CI, 0.34 to 1.25) Year 3 after entry: 19 (0.31%) vs. 19 (0.33%); HR, 0.96 (95% CI, 0.51 to 1.82) Year 4 after entry: 35 (0.58%) vs. 23 (0.40%); HR, 1.45 (95% CI, 0.85 to 2.45) Year 5 after entry: 28 (0.54%) vs.17 (0.34%); HR, 1.61 (95% CI, 0.88 to 2.94) Year 6 or more after entry: 37 (0.69%) vs. 26 (0.56%); HR, 1.24 (95% CI, 0.75 to 2.05) z score=2.31 [underlined: With prior menopausal hormone therapy use] Treatment (2,225) vs. placebo (2,079) Year 1 after entry: 5 (0.23%) vs. 5 (0.24%); HR, 0.90 (95% CI, 0.26 to 3.15) Year 2 after entry: 11 (0.50%) vs. 10 (0.49%); HR, 1.10 (95% CI, 0.47 to 2.61) Year 3 after entry: 10 (0.46%) vs. 3 (0.15%); HR, 3.09 (95% CI, 0.84 to 11.27) Year 4 after entry: 9 (0.42%) vs. 4 (0.20%); HR, 2.16 (95% CI, 0.66 to 7.05) Year 5 after entry: 15 (0.82%) vs. 4 (0.23%); HR, 3.56 (95% CI, 1.18 to 10.73) Year 6 or more after entry: 8 (0.39%) vs. 3 (0.17%); HR, 1.99 (95% CI, 0.52 to 7.60) z score=1.62 [underlined: Overall] Year 1 after entry: 12 (0.14%) vs. 19 (0.24%); HR, 0.60 (95% CI, 0.29 to 1.23) Year 2 after entry: 26 (0.31%) vs. 32 (0.40%); HR, 0.77 (95% CI, 0.46 to 1.30) Year 3 after entry: 29 (0.35%) vs. 22 (0.28%); HR, 1.26 (95% CI, 0.73 to 2.20) Year 4 after entry: 44 (0.54%) vs. 27 (0.35%); HR, 1.54 (95% CI, 0.95 to 2.49) Year 5 after entry: 43 (0.61%) vs. 21 (0.32%); HR, 1.99 (95% CI, 1.18 to 3.35) Year 6 or more after entry: 45 (0.61%) vs. 29 (0.45%); HR, 1.35 (95% CI, 0.85 to 2.16) z score=2.56 All p values >0.05 for: Age at screening, Gail risk assessment, prior oral contraceptive use, prior menopausal hormone use, prior estrogen only use, prior estrogen plus progestin use, recency of hormone use, BMI, smoking, NSAID use (Note: prior menopausal hormone therapy use ≥5 years: HR, 2.27 (95% CI, 1.00 to 5.15); border significance
LaCroix, 2011;^49^ Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy postintervention. WHI Estrogen only trial | All women enrolled in WHI trial followed up after completetion of trial (postintervention phase): 10,739 Enrolled 5,310 Estrogen 5,429 Placebo | Cumulative annualized rates for invasive breast cancer [underlined: Age at screening (years)] 50–59: 43 vs 54; HR, 0.80 (95% CI, 0.53 to 1.19); p=0.96 60–69: 68 vs. 95; HR, 0.73 (95% CI, 0.54 to 1.00); p=0.96 70–79: 40 vs. 50; HR, 0.81 (95% CI, 0.53 to 1.23); p=0.96
Rossouw, 2002;^12^ Risks and benefits of estrogen plus progestin in healthy postmenopausal women. WHI Estrogen plus progestin trial | Women enrolled in WHI trial (intervention phase): 16,608 Enrolled 8,506 Estrogen plus progestin 8,102 Placebo | Invasive breast cancer (annualized %) [underlined: By followup year] Year 1: 11 (0.13) vs. 17 (0.21); HR, 0.62 Year 2: 26 (0.31) vs. 30 (0.38); HR, 0.83 Year 3: 28 (0.34) vs. 23 (0.29); HR, 1.16 Year 4: 40 (0.50) vs. 22 (0.29); HR, 1.73 Year 5: 34 (0.57) vs. 12 (0.22); HR, 2.64 Year 6 and later: 27 (0.53) vs. 20 (0.47); HR, 1.12
Anderson, 2004;^42^ Effects of conjugated equine estrogen in postmenopausal women with hysterectomy. WHI Estrogen only trial | Women enrolled in WHI trial (intervention phase): 10,739 Enrolled 5,310 Estrogen 5,429 Plaecbo | Invasive breast cancer [underlined: Age at screening (years);] p=0.51 50–59: 25 vs. 35; HR, 0.72 (95% CI, 0.43 to 1.21) 60–69: 42 vs. 60; HR, 0.72 (95% CI, 0.49 to 1.07) 70–79: 27 vs. 29; HR, 0.94 (95% CI, 0.56 to 1.60)
Gramling, 2009;^31^ Hormone replacement therapy, family history, and breast cancer risk among postmenopausal women. WHI Estrogen plus progestin trial | Women enrolled in WHI trial (longitudinal followup): 16,608 Enrolled 8,506 Estrogen plus progestin 8,102 Placebo | Incidence of invasive breast cancer in those with first-degree family member with breast cancer (n=1,009 vs. 895) Overall: 35 (3.5%) vs. 25 (2.7%) Incidence of invasive breast cancer in those without first-degree family member with breast cancer (n=7,497 vs. 7,202) Overall: 164 (2.2%) vs. 125 (1.7%)
Urinary incontinence
Hendrix, 2005;^35^ Effects of estrogen with and without progestin on urinary incontinence. WHI Estrogen plus progestin trial | Analysis focused on women with urinary incontinence data at baseline and 1 year: 16,608 Enrolled in WHI 7,247 Estrogen plus progestin (2,675 continent at baseline) 7,056 Placebo (2,507 continent at baseline) | Stress urinary incontinence [underlined: Age at screening (years)] 50–54: RR, 0.90 (95% CI, 0.58 to 1.40) 55–59: RR, 1.63 (95% CI, 1.18 to 2.27); p<0.001 60–69: RR, 2.11 (95% CI, 1.70 to 2.62); p<0.001 70–79: RR, 2.59 (95% CI, 1.77 to 3.81); p<0.001 [underlined: Duration since menopause (years)] <5: RR, 1.21 (95% CI, 0.83 to 1.77) 5 to <10: RR, 1.70 (95% CI, 1.19 to 2.44); p=0.005 10 to <15: RR, 2.00 (95% CI, 1.45 to 2.77); p=0.005 ≥15: RR, 2.33 (95% CI, 1.79 to 3.03); p=0.005 [underlined: Menopaual hormone therapy use] Never: RR, 1.87 (95% CI, 1.57 to 2.24); p=0.008 Past: RR, 2.41 (95% CI, 1.71 to 3.41); p=0.008 Current: RR, 0.85 (95% CI, 0.48 to 1.50) [underlined: Beta blocker use] Absent: RR, 1.81 (95% CI, 1.55 to 2.11); p=0.03 Present: RR, 6.69 (95% CI, 2.03 to 22.05); p=0.03 Urge urinary incontinence [underlined: Age at screening (years)] 50–54: RR, 1.18 (95% CI, 0.75 to 1.88) 55–59: RR, 0.90 (95% CI, 0.63 to 1.30) 60–69: RR, 1.26 (95% CI, 1.01 to 1.58) 70–79: RR, 1.20 (95% CI, 0.89 to 1.61) [underlined: Duration since menopause (years)] <5: RR, 1.25 (95% CI, 0.80 to 1.93) 5 to <10: RR, 1.17 (95% CI, 0.80 to 1.70) 10 to <15: RR, 1.17 (95% CI, 0.81 to 1.67) ≥15: RR, 1.17 (95% CI, 0.93 to 1.46) [underlined: Menopausal hormone therapy use] Never: RR, 1.14 (95% CI, 0.96 to 1.36) Past: RR, 1.16 (95% CI, 0.83 to 1.62) Current: RR, 1.38 (95% CI, 0.65 to 2.96) [underlined: Diabetes] Absent: RR, 1.21 (95% CI, 1.21 to 1.03); p=0.03 Present: RR, 0.59 (95% CI, 0.32 to 1.09) Mixed urinary incontinence [underlined: Age at screening (years)] 50–54: RR, 2.11 (95% CI, 0.55 to 8.06) 55–59: RR, 1.05 (95% CI, 0.58 to 1.91) 60–69: RR, 1.46 (95% CI, 0.94 to 2.26) 70–79: RR, 2.24 (95% CI, 1.17 to 4.30); p=0.26 [underlined: Duration since menopause (years)] <5: RR,1.32 (95% CI, 0.59 to 2.96) 5 to <10: RR, 1.53 (95% CI, 0.71 to 3.29) 10 to <15: RR, 1.31 (95% CI, 0.67 to 2.56) ≥15: RR, 1.58 (95% CI, 0.99 to 2.50); p=0.73 [underlined: Menopausal hormone therapy use] Never: RR, 1.43 (95% CI, 1.01 to 2.02); p=0.49 Past: RR, 1.39 (0.69 to 2.79) Current: RR, 3.64 (0.79 to 16.79)
Hendrix, 2005;^35^ Effects of estrogen with and without progestin on urinary incontinence. WHI Estrogen only trial | Analysis focused on women with urinary incontinence data at baseline and 1 year: 10,739 Enrolled in WHI 4,476 Estrogen (1,526 continent at baseline) 4,517 Placebo (1,547 continent at baseline) | Stress urinary incontinence [underlined: Age at screening (years)] 50–54: RR, 1.13 (95% CI, 0.69 to 1.86) 55–59: RR, 2.32 (95% CI, 1.42 to 3.77); p=0.002 60–69: RR, 2.10 (95% CI, 1.60 to 2.74); p=0.002 70–79: RR, 3.91 (95% CI, 2.31 to 6.60); p=0.002 [underlined: Duration since menopause (years)] <5: RR, 0.95 (95% CI, 0.47 to 1.90) 5 to <10: RR, 2.18 (95% CI, 1.04 to 4.57); p=0.02 10 to <15: RR, 2.01 (95% CI, 1.17 to 3.44); p=0.02 ≥15: RR, 2.56 (95% CI, 1.93 to 3.39); p=0.02 [underlined: Menopausal hormone therapy use] Never: RR, 2.25 (95% CI, 1.72 to 2.95); p=0.55 Past: RR, 2.24 (95% CI, 1.62 to 3.10); p=0.55 Current: RR, 1.60 (95% CI, 0.93 to 2.75) Urge urinary incontinence [underlined: Age at screening (years)] 50–54: RR, 0.85 (95% CI, 0.44 to 1.66) 55–59: RR, 0.94 (95% CI, 0.56 to 1.57) 60–69: RR, 1.49 (95% CI, 1.14 to 1.95); p=0.05 70–79: RR, 1.45 (95% CI, 1.07 to 1.98); p=0.05 [underlined: Duration since menopause (years)] <5: RR, 1.37 (95% CI, 0.60 to 3.12) 5 to <10: RR, 1.26 (95% CI, 0.62 to 2.58) 10 to <15: RR, 0.74 (95% CI, 0.43 to 1.26) ≥15: RR, 1.46 (95% CI, 1.16 to 1.84); p=0.35 [underlined: Menopausal hormone therapy use] Never: RR, 1.33 (95% CI, 1.03 to 1.70); p=0.58 Past: RR, 1.23 (95% CI, 0.92 to 1.64) Current: RR, 1.81 (95% CI, 0.94 to 3.49) Mixed urinary incontinence [underlined: Age at screening (years)] 50–54: RR, 1.07 (95% CI, 0.38 to 2.99) 55–59: RR, 0.69 (95% CI, 0.23 to 2.06) 60–69: RR, 2.05 (95% CI, 1.25 to 3.35); p=0.04 70–79: RR, 2.63 (95% CI, 1.32 to 5.25); p=0.04 [underlined: Duration since menopause (years)] <5: RR, 2.62 (95% CI, 0.94 to 7.30) 5 to <10: RR, 0.36 (95% CI, 0.7 to 1.74) 10 to <15: RR, 0.89 (95% CI, 0.36 to 2.20) ≥15: RR, 2.11 (95% CI, 1.35 to 3.30); p=0.46 [underlined: Menopausal hormone therapy use] Never: RR, 1.36 (95% CI, 0.85 to 2.18) Past: RR, 2.65 (95% CI, 1.47 to 4.79); p=0.15 Current: RR, 1.75 (95% CI, 0.57 to 5.35) [underlined: Smoking status] Never: RR, 2.57 (95% CI, 1.55 to 4.27); p=0.05 Past: RR, 1.51 (95% CI, 0.89 to 2.58) Current: RR, 0.38 (0.08 to 1.86)
Diabetes
Margolis, 2004;^38^ Effect of oestrogen plus progestin on the incidence of diabetes in postmenopausal women: results from the Women’s Health Initiative hormone trial. Estrogen plus progestin trial | Excluded women with self-reported diabetes at baseline: 15,641 Eligible from WHI 8,014 Estrogen plus progestin 7,627 Placebo | Incidence of new diabetes diagnosis BMI <25: 32 vs. 34; HR, 1.00 BMI 25–29: 57 vs. 75; HR, 1.77 (95% CI, 1.32 to 2.38); p=0.0002 BMI ≥30: 123 vs. 143; HR, 4.06 (95% CI, 3.09 to 5.35); p<0.0001 Waist circumference >88 cm: 138 vs. 189; HR, 3.57 (95% CI, 2.90 to 4.39); p<0.0001 Change in waist circumference from baseline to year 1 of >2.0 cm: 59 vs. 78; HR, 1.31 (95% CI, 1.04 to 1.65); p=0.020
Bonds, 2006;^43^ The effect of conjugated equine oestrogen on diabetes incidence: the Women’s Health Initiative randomised trial. Estrogen only trial | Excluded women with self-reported diabetes at baseline: 9,712 Eligible from WHI 4,806 Estrogen 4,906 Placebo | Incidence of new diabetes diagnosis Current smoker: 31 (0.6%) vs. 59 (1.2%); HR, 0.54 (95% CI, 0.35 to 0.84); p=0.02

Abbreviations: BMI=body mass index; CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; HERS II=Heart and Estrogen/Progestin Replacement Study Phase II; HR=hazard ratio; ITT=intention-to-treat; NSAID=nonsteroidal anti-inflammatory drug; RR=relative risk; WHI=Women’s Health Initiative; WISDOM=Women’s International Study of Long-Duration Oestrogen After Menopause.