# Detailed Methods

## Appendix B1 Search Strategies

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) <1947 to November Week 3 2011> Search Strategy
1. exp Hormone Replacement Therapy/(18014)
2. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (61635)
3. exp Estrogens/ad, tu, ae, to (30285)
4. exp Estradiol Congeners/ad, tu, ae, to (16224)
5. 1 or 2 or 3 or 4 (83066)
6. exp climacteric/(42184)
7. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (71436)
8. 6 or 7 (73433)
9. 5 and 8 (21705)
10. limit 5 to yr=“2002 -Current” (30216)
11. limit 10 to randomized controlled trial (2532)
12. systematic review.ti. or meta-analysis.pt. or meta-analysis.ti. or systematic literature review.ti. or (systematic review.ti,ab. and review.pt.) or consensus development conference.pt. or practice guideline.pt. or cochrane database syst rev.jn. or acp journal club.jn. or health technol assess.jn. or evid rep technol assess summ.jn. (62504)
13. evidence based.ti. or exp Evidence-Based Medicine/or best practice$.ti. or evidence synthesis.ti,ab. (43717)
14. review.pt. or exp “diseases (non mesh)”/or exp “behavior and behavior mechanisms”/or exp therapeutics/or evaluation studies.pt. or validation studies.pt. or guideline.pt. (12073345)
15. 13 and 14 (35235)
16. (systematic or systematically).mp. or critical.ti,ab. or study selection.mp. or ((predetermined or inclusion) and criteri$).mp. or exclusion criteri$.mp. or main outcome measures.mp. or standard of care.mp. or standards of care.mp. (493608)
17. (survey or surveys).ti,ab. or overview$.mp. or review.ti,ab. or reviews.ti,ab. or search$.mp. or handsearch.mp. or analysis.ti,ab. or critique.ti,ab. or appraisal.mp. or (reduction.mp. and (exp risk/or risk.mp.) and (exp death/or death.mp. or exp recurrence/or recurrence.mp.)) (2675017)
18. (literature or articles or publications or publication or bibliography or bibliographies or published).ti,ab. or unpublished.mp. or citation.mp. or citations.mp. or database.ti,ab. or internet.ti,ab. or textbooks.ti,ab. or references.mp. or scales.mp. or papers.mp. or datasets.mp. or trials.ti,ab. or meta-analy$.mp. or (clinical and studies).ti,ab. or exp treatment outcome/or treatment outcome.mp. (1559459)
19. 16 and 17 and 18 (74949)
20. 12 or 15 or 19 (143395)
21. (letter or newspaper article or comment).pt. (861393)
22. 20 not 21 (137375)
23. 10 and 22 (1119)
24. 11 or 23 (3629)
25. exp Randomized Controlled Trials as Topic/(69462)
26. 10 and 25 (1384)
27. 24 or 26 (4709)
28. exp Mental Processes/(611118)
29. exp Cognition Disorders/(45056)
30. exp Dementia/(94310)
31. exp memory/(77691)
32. exp Memory Disorders/(17597)
33. 28 or 29 or 30 or 31 or 32 (721314)
34. 27 and 33 (319)
35. exp Breast Neoplasms/(176281)
36. 27 and 35 (762)
37. exp Cardiovascular Diseases/(1598559)
38. heart disease$.tw. (100444)
39. (cardiovascular disease$ or myocardial infarct$).tw. (176571)
40. 37 or 38 or 39 (1639524)
41. 27 and 40 (1055)
42. exp Osteoporosis/(37080)
43. exp Fractures, Bone/(119047)
44. fractur$.tw. (135977)
45. bone density.mp. (38276)
46. 42 or 43 or 44 or 45 (212984)
47. 27 and 46 (685)
48. exp Cerebrovascular Disorders/(226197)
49. stroke.mp. (127016)
50. 48 or 49 (286153)
51. 27 and 50 (215)
52. (tamoxifen or raloxifene).mp. (19548)
53. Bone density/or “bone density”.mp. (38276)
54. exp osteoporosis/or “osteoporosis”.mp. (47690)
55. exp fractures/or fracture$.mp. (175011)
56. 53 or 54 or 55 (223064)
57. 27 and 56 (748)
58. 34 or 36 or 41 or 47 or 51 or 57 (2353)
59. limit 58 to english language (2184)
60. limit 58 to abstracts (2022)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <3^rd^ Quarter 2011> Search Strategy
1. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (7834)
2. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$ or climacter$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (10925)
3. (mental$ or cognit$ or dement$ or alzheim$ or memor$ or amnes$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (35737)
4. ((breast$ or mamma$) adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcinom$ or adenocarcinom$ or malig$ or metastas$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (11801)
5. (heart$ or cardi$ or myocardi$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (76479)
6. (osteopor$ or fractur$ or ((bone$ or osteo$) adj3 dens$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (9454)
7. (cerebrovasc$ or stroke$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (17295)
8. (tamoxifen or raloxifene).mp. (3103)
9. 1 and 2 (3940)
10. 3 and 9 (180)
11. 4 and 9 (596)
12. 5 and 9 (748)
13. 6 and 9 (771)
14. 7 and 9 (76)
15. 8 and 9 (479)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <3^rd^ Quarter 2011> Search Strategy
1. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (7834)
2. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$ or climacter$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (10925)
3. (mental$ or cognit$ or dement$ or alzheim$ or memor$ or amnes$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (35737)
4. ((breast$ or mamma$) adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcinom$ or adenocarcinom$ or malig$ or metastas$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (11801)
5. (heart$ or cardi$ or myocardi$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (76479)
6. (osteopor$ or fractur$ or ((bone$ or osteo$) adj3 dens$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (9454)
7. (cerebrovasc$ or stroke$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (17295)
8. (tamoxifen or raloxifene).mp. (3103)
9. 1 and 2 (3940)
10. 3 and 9 (180)
11. 4 and 9 (596)
12. 5 and 9 (748)
13. 6 and 9 (771)
14. 7 and 9 (76)
15. 8 and 9 (479)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <3^rd^ Quarter 2011> Search Strategy
1. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (7834)
2. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$ or climacter$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (10925)
3. (mental$ or cognit$ or dement$ or alzheim$ or memor$ or amnes$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (35737)
4. ((breast$ or mamma$) adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcinom$ or adenocarcinom$ or malig$ or metastas$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (11801)
5. (heart$ or cardi$ or myocardi$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (76479)
6. (osteopor$ or fractur$ or ((bone$ or osteo$) adj3 dens$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (9454)
7. (cerebrovasc$ or stroke$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (17295)
8. (tamoxifen or raloxifene).mp. (3103)
9. 1 and 2 (3940)
10. 3 and 9 (180)
11. 4 and 9 (596)
12. 5 and 9 (748)
13. 6 and 9 (771)
14. 7 and 9 (76)
15. 8 and 9 (479)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <3^rd^ Quarter 2011> Search Strategy
1. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (7834)
2. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$ or climacter$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (10925)
3. (mental$ or cognit$ or dement$ or alzheim$ or memor$ or amnes$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (35737)
4. ((breast$ or mamma$) adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcinom$ or adenocarcinom$ or malig$ or metastas$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (11801)
5. (heart$ or cardi$ or myocardi$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (76479)
6. (osteopor$ or fractur$ or ((bone$ or osteo$) adj3 dens$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (9454)
7. (cerebrovasc$ or stroke$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (17295)
8. (tamoxifen or raloxifene).mp. (3103)
9. 1 and 2 (3940)
10. 3 and 9 (180)
11. 4 and 9 (596)
12. 5 and 9 (748)
13. 6 and 9 (771)
14. 7 and 9 (76)
15. 8 and 9 (479)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <3^rd^ Quarter 2011> Search Strategy
1. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (7834)
2. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$ or climacter$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (10925)
3. (mental$ or cognit$ or dement$ or alzheim$ or memor$ or amnes$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (35737)
4. ((breast$ or mamma$) adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcinom$ or adenocarcinom$ or malig$ or metastas$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (11801)
5. (heart$ or cardi$ or myocardi$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (76479)
6. (osteopor$ or fractur$ or ((bone$ or osteo$) adj3 dens$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (9454)
7. (cerebrovasc$ or stroke$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (17295)
8. (tamoxifen or raloxifene).mp. (3103)
9. 1 and 2 (3940)
10. 3 and 9 (180)
11. 4 and 9 (596)
12. 5 and 9 (748)
13. 6 and 9 (771)
14. 7 and 9 (76)
15. 8 and 9 (479)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <3^rd^ Quarter 2011> Search Strategy
1. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (7834)
2. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$ or climacter$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (10925)
3. (mental$ or cognit$ or dement$ or alzheim$ or memor$ or amnes$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (35737)
4. ((breast$ or mamma$) adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcinom$ or adenocarcinom$ or malig$ or metastas$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (11801)
5. (heart$ or cardi$ or myocardi$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (76479)
6. (osteopor$ or fractur$ or ((bone$ or osteo$) adj3 dens$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (9454)
7. (cerebrovasc$ or stroke$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (17295)
8. (tamoxifen or raloxifene).mp. (3103)
9. 1 and 2 (3940)
10. 3 and 9 (180)
11. 4 and 9 (596)
12. 5 and 9 (748)
13. 6 and 9 (771)
14. 7 and 9 (76)
15. 8 and 9 (479)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <3^rd^ Quarter 2011> Search Strategy
1. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (7834)
2. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$ or climacter$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (10925)
3. (mental$ or cognit$ or dement$ or alzheim$ or memor$ or amnes$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (35737)
4. ((breast$ or mamma$) adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcinom$ or adenocarcinom$ or malig$ or metastas$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (11801)
5. (heart$ or cardi$ or myocardi$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (76479)
6. (osteopor$ or fractur$ or ((bone$ or osteo$) adj3 dens$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (9454)
7. (cerebrovasc$ or stroke$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (17295)
8. (tamoxifen or raloxifene).mp. (3103)
9. 1 and 2 (3940)
10. 3 and 9 (180)
11. 4 and 9 (596)
12. 5 and 9 (748)
13. 6 and 9 (771)
14. 7 and 9 (76)
15. 8 and 9 (479)

Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to November 2011> Search Strategy
1. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=title, abstract, full text, keywords, caption text] (401)
2. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$ or climacter$).mp. [mp=title, abstract, full text, keywords, caption text] (294)
3. (mental$ or cognit$ or dement$ or alzheim$ or memor$ or amnes$).mp. [mp=title, abstract, full text, keywords, caption text] (1913)
4. ((breast$ or mamma$) adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcinom$ or adenocarcinom$ or malig$ or metastas$)).mp. [mp=title, abstract, full text, keywords, caption text] (265)
5. (heart$ or cardi$ or myocardi$).mp. [mp=title, abstract, full text, keywords, caption text] (2665)
6. (osteopor$ or fractur$ or ((bone$ or osteo$) adj3 dens$)).mp. [mp=title, abstract, full text, keywords, caption text] (738)
7. (cerebrovasc$ or stroke$).mp. [mp=title, abstract, full text, keywords, caption text] (959)
8. (tamoxifen or raloxifene).mp. (64)
9. 1 and 2 (164)
10. 3 and 9 (48)
11. 4 and 9 (64)
12. 5 and 9 (72)
13. 6 and 9 (62)
14. 7 and 9 (35)
15. 8 and 9 (33)
16. 10 or 11 or 12 or 13 or 14 or 15 (130)

Database: EBM Reviews - Cochrane Methodology Register <3^rd^ Quarter 2011> Search Strategy
1. ((oestrogen$ or estrogen$ or hormon$) adj3 (replac$ or treat$ or therap$ or interven$)).mp. [mp=title, abstract, subject heading word] (92)
2. (menopaus$ or postmenopaus$ or premenopaus$ or perimenopaus$ or climacter$).mp. [mp=title, abstract, subject heading word] (86)
3. (mental$ or cognit$ or dement$ or alzheim$ or memor$ or amnes$).mp. [mp=title, abstract, subject heading word] (364)
4. ((breast$ or mamma$) adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcinom$ or adenocarcinom$ or malig$ or metastas$)).mp. [mp=title, abstract, subject heading word] (418)
5. (heart$ or cardi$ or myocardi$).mp. [mp=title, abstract, subject heading word] (721)
6. (osteopor$ or fractur$ or ((bone$ or osteo$) adj3 dens$)).mp. [mp=title, abstract, subject heading word] (83)
7. (cerebrovasc$ or stroke$).mp. [mp=title, abstract, subject heading word] (197)
8. (tamoxifen or raloxifene).mp. (43)
9. 1 and 2 (40)
10. 3 and 9 (1)
11. 4 and 9 (10)
12. 5 and 9 (15)
13. 6 and 9 (7)
14. 7 and 9 (4)
15. 8 and 9 (2)
16. 10 or 11 or 12 or 13 or 14 or 15 (24)

## Appendix B2 Inclusion and Exclusion Criteria

| Include | Exclude
Population | Generally healthy postmenopausal women eligible for menopausal hormone therapy. Characteristics of enrolled participants are applicable to the U.S. primary care population. | Animals, men, premenopausal women, postmenopausal women with contraindications for hormone therapy use, or populations not applicable to U.S. primary care.
Interventions | Estrogen only or combined with progestin for prevention of chronic conditions. Medications are available for use in the United States. | Contraceptives, other hormones, or treatment of menopausal symptoms.
Outcomes | Health outcomes include mortality, fractures; coronary heart disease; stroke; venous thromboembolism; breast, colorectal, endometrial, and ovarian cancer; cholecystitis; cognition; urinary incontinence; and others. | Menopausal symptoms; intermediate health outcomes, such as lipid levels or bone mineral density.
Study types and designs | English-language randomized, controlled trials published in 2002 or later. | Observational studies (case-control and cohort) or case studies.
Duration | 1 year of treatment. | Less than 1 year of treatment.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria for Randomized, Controlled Trials

### Randomized, Controlled Trials (RCTs)

#### Criteria

- Initial assembly of comparable groups: adequate randomization, including concealment and whether potential confounders were distributed equally among groups.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Important differential loss to followup or overall high loss to followup.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment).
- Clear definition of interventions.
- Important outcomes considered.
- Analysis: intention-to-treat analysis; for cluster RCTs, correction for correlation coefficient.

#### Definition of ratings based on above criteria

Good: | Meets all criteria: Ccomparable groups are assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Any or all of the following problems occur, without the important limitations noted in the “poor” category below: generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Any of the following major limitations exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Source: Harris et al, 2001^22^

## Appendix B4 List of Reviewers of Draft Report

### Outside Experts

JoAnn Manson, M.D., M.P.H., Dr.P.H., Chief, Division of Preventive Medicine; Co-Director, Connors Center for Women’s Health and Gender Biology; Elizabeth F. Brigham Professor of Women’s Health and Professor of Medicine, Harvard Medical School

Elizabeth Barrett-Connor, M.D., Professor and Division Chief of Epidemiology, Department of Family and Preventive Medicine, University of California, San Diego School of Medicine

Diana Petitti, M.D., M.P.H., Professor of Biomedical Informatics, Arizona State University

### Collaborative Partners

Jacques Rossouw, M.D., Chief, Women’s Health Initiative Branch, National Heart, Lung and Blood Institute

Leslie Ford, M.D., Associate Director for Clinical Research, Division of Cancer Prevention, National Cancer Institute

Worta McCaskill-Stevens, M.D., Program Director, Division of Cancer Prevention, Community Oncology and Prevention Trials Research Group, National Cancer Institute

Joseph Chin, M.D., M.S., Medical Officer, Coverage and Analysis Group, Centers for Medicare and Medicaid Services

## Appendix B5 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Identified from reference lists, suggested by experts.

‡ Studies that provided data and contributed to the body of evidence were considered “included.”

Abbreviations: EMS=Estrogen Memory Study; ESPRIT=Oestrogen in the Prevention of Reinfarction Trial; HERS=Heart and Estrogen/Progestin Replacement Study; ULTRA=Ultra-Low-Dose Transdermal Estrogen Replacement Assessment; WHI=Women’s Health Initiative; WHIMS=Women’s Health Initiative Memory Study; WHISCA=Women’s Health Initiative Study of Cognitive Aging; WISDOM=Women’s International Study of Long-Duration Oestrogen After Menopause.

Appendix B5 is a flow chart that summarizes the search and selection of articles related to menopausal hormone therapy for prevention of chronic conditions. Citations were identified through bibliographic databases, including MEDLINE, Cochrane Central Register of Controlled Trials, and Cochrane Database of Systematic Reviews, as well as through other sources, including experts, reference lists, and gray literature. There were 4,524 abstracts of potentially relevant articles reviewed. After excluding 3,820 abstracts that were not relevant to key questions, and identifying additional hand-searched references, gray literature, and references from experts, 704 full-text articles were reviewed for relevance. A total of 653 full-text articles were excluded. In total, 51 articles were included. The sources of those 51 articles were eight key trials: 29 from WHI; five from WHIMS; three from WHISCA; seven from HERS; one from ESPRIT; one from EMS; four from ULTRA: and one from WISDOM.

## Appendix B6 List of Excluded Full-Text Articles

Key to exclusion codes

2 | Background
3 | Wrong population
4 | Wrong intervention
5 | Wrong outcome
6 | Wrong study design
7 | Wrong publication type
8 | Wrong indication
9 | Conducted prior to 2002
10 | Foreign language
11 | Focus on intermediate outcomes
12 | Superseded by review; no new data
13 | Followup less than 1 year
14 | Less than 100 subjects

### List of excluded articles

Reports from the Swedish Council on Technology Assessment In Health Care (SBU). Treatment of asthma and COPD: an evidence-based review. Int J Technol Assess Health Care. 2002;18(4):832-860. Exclusion code: 7. [pmid: 12602084].
Hormone therapy is no heart helper The latest chapter in the sage of hormone replacement therapy warns that it may harm, not help, the heart. Harv Heart Lett. 2002;13(2):2-3. Exclusion code: 7.
Hormone replacement therapy. Med Lett Drugs Ther. 2002;44(1138):78. Exclusion code: 7. [pmid: 12238487].
Has lower-dose HRT come of age?. Harv Womens Health Watch. 2002;9(10):1-2. Exclusion code: 7.
Stunning HRT research points providers in new directions. Dis Manag Advis. 2002;8(8):113-117. Exclusion code: 7. [pmid: 12233139].
Getting to the HRT of the matter. Johns Hopkins Med Lett Health After 50. 2002;14(5):4-5. Exclusion code: 7.
Hormones and heart disease—down, not out. Harv Heart Lett. 2002;12(7):3-5. Exclusion code: 7.
Facts About Menopausal Hormone Therapy. US Department of Health and Human Services National Heart, Lung, and Blood Institute. revised 2005. 2002;05-5200:1-24. Exclusion code: 7.
Canadian consensus on osteoporosis. Preventing osteoporosis among postmenopausal women. Can Fam Physician. 2003;49:487. Exclusion code: 7. [pmid: 12729244].
HRT: Update on the risk of breast cancer and long-term safety. Curr Probl Pharmacovigilance. 2003;29:1-3. Exclusion code: 2.
Post-menopausal hormone replacement therapy (cont’d): risk-benefit balance in the hot seat. Prescrire Int. 2004;13(71):106-109. Exclusion code: 7. [pmid: 15233153].
Menostar: a low-dose estrogen patch for osteoporosis. Med Lett Drugs Ther. 2004;46(1190):69-70. Exclusion code: 7. [pmid: 15375352].
NIH State-of-the-Science Conference Statement on management of menopause-related symptoms. NIH Consens State Sci Statements. 2005;22(1):1-38. Exclusion code: 7.
Estrogen raises risk of blood clots and stroke. Replacing this powerful hormone after menopause has more risks than first thought. Heart Advis. 2008;11(10):7. Exclusion code: 7.
Drugs for postmenopausal osteoporosis. Treat Guidel Med Lett. 2008;6(74):67-74. Exclusion code: 7. [pmid: 18800025].
Hormone therapy: an update on risks and benefits. Mayo Clin Womens Healthsource. 2009;(Suppl):1-8. Exclusion code: 7.
Timing of hormone therapy influences breast cancer risk. Harv Womens Health Watch. 2011;18(8):7. Exclusion code: 7.
Abramov Y, Borik S, Yahalom C, et al. The effect of hormone therapy on the risk for age-related maculopathy in postmenopausal women. Menopause. 2004;11(1):62-68. Exclusion code: 6. [pmid: 14716184].
Abramson BL. Postmenopausal hormone replacement therapy and the prevention of cardiovascular disease: a review. J Cardiovasc Risk. 2002;9(6):309-314. Exclusion code: 7. [pmid: 12478199].
Abramson BL. Canadian Task Force on Preventive Health Care. Postmenopausal hormone replacement therapy for primary prevention of cardiovascular and cerebrovascular disease: recommendation statement from the Canadian Task Force on Preventive Health Care. CMAJ. 2004;170(9):1388-1389. Exclusion code: 2. [pmid: 15111467].
Adis International Ltd. ALX 111: ALX1-11, parathyroid hormone (1–84)—NPS Allelix PREOS, PTH, recombinant human parathyroid hormone, rhPTH (1–84). Drugs R D. 2003;4(4):231-235. Exclusion code: 4. [pmid: 12848587].
Al Kadri H, Hassan S, Al-Fozan HM, Hajeer A. Hormone therapy for endometriosis and surgical menopause. Cochrane Database Syst Rev. 2009;(1):CD005997. Exclusion code: 8. [pmid: 19160262].
Al-Azzawi F, Thompson J, Stevenson J. Which progestogen is more likely to increase the risk of fatal myocardial infarction: a combination of epidemiological and trial evidence. Maturitas. 2006;54(2):154-163. Exclusion code: 11. [pmid: 16364575].
Albert MA, Glynn RJ, Buring J, Ridker PM. C-reactive protein levels among women of various ethnic groups living in the United States (from the Women’s Health Study). Am J Cardiol. 2004;93(10):1238-1242. Exclusion code: 11. [pmid: 15135696].
Aldrighi JM, Alecrin IN, Caldas MA, et al. Effects of estradiol on myocardial global performance index in hypertensive postmenopausal women. Gynecol Endocrinol. 2004;19(5):282-292. Exclusion code: 9. [pmid: 15726917].
Aldrighi JM, Calvoso-Junior R, Alecrin IN, et al. Estrogen replacement and exercise capacity in postmenopausal women: a randomized placebo-controlled study. Gynecol Endocrinol. 2005;21(6):324-329. Exclusion code: 11. [pmid: 16390780].
Alexandersen P, Tanko LB, Bagger YZ, et al. The long-term impact of 2–3 years of hormone replacement therapy on cardiovascular mortality and atherosclerosis in healthy women. Climacteric. 2006;9(2):108-118. Exclusion code: 9. [pmid: 16698657].
Alhola P, Tuomisto H, Saarinen R, et al. Estrogen + progestin therapy and cognition: a randomized placebo-controlled double-blind study. J Obstet Gynaecol Res. 2010;36(4):796-802. Exclusion code: 14. [pmid: 20666948].
Allison MA, Manson JE, Langer RD, et al. Oophorectomy, hormone therapy, and subclinical coronary artery disease in women with hysterectomy: the Women’s Health Initiative coronary artery calcium study. Menopause. 2008;15(4 Pt 1):639-647. Exclusion code: 11. [pmid: 18458645].
Alpert MA. Hormone replacement therapy to reduce cardiovascular risk: a concept whose time has passed?. South Med J. 2002;95(9):959-961. Exclusion code: 7. [pmid: 12356133].
Althuis MD, Fergenbaum JH, Garcia-Closas M, et al. Etiology of hormone receptor-defined breast cancer: a systematic review of the literature. Cancer Epidemiol Biomarkers Prev. 2004;13(10):1558-1568. Exclusion code: 7. [pmid: 15466970].
Alving B. NIH asks participants in Women’s Health Initiative estrogen-alone study to stop study pills, begin follow-up phase. South Med J. 2004;97(4):425-426. Exclusion code: 7. [pmid: 15108846].
American Association of Clinical Endocrinologists Reproductive Medicine Committee. Position statement on hormone replacement therapy (HRT) and cardiovascular risk. 2008. Exclusion code: 2.
American College of Obstetricians and Gynecologists Women’s Health Care Physicians. Osteoporosis. Obstet Gynecol. 2004;104(4 Suppl):66S-76S. Exclusion code: 7. [pmid: 15458936].
American College of Obstetricians and Gynecologists Women’s Health Care Physicians. Venous thromboembolic disease. Obstet Gynecol. 2004;104(4 Suppl):118S-127S. Exclusion code: 7. [pmid: 15458942].
American College of Obstetricians and Gynecologists Women’s Health Care Physicians. Stroke. Obstet Gynecol. 2004;104(4 Suppl):97S-105S. Exclusion code: 7. [pmid: 15458940].
American College of Obstetricians and Gynecologists Women’s Health Care Physicians. Coronary heart disease. Obstet Gynecol. 2004;104(4 Suppl):41S-48S. Exclusion code: 7. [pmid: 15458932].
American College of Obstetricians and Gynecologists Women’s Health Care Physicians. Cognition and dementia. Obstet Gynecol. 2004;104(4 Suppl):25S-40S. Exclusion code: 7. [pmid: 15458931].
American College of Obstetricians and Gynecologists. ACOG issues state-of-the-art guide to hormone therapy. 2004. Exclusion code: 7.
American College of Obstetricians and Gynecologists. ACOG Committee Opinion No. 420, November 2008: hormone therapy and heart disease. Obstet Gynecol. 2008;112(5):1189-1192. Exclusion code: 2. [pmid: 18978127].
American College of Obstetricians and Gynecologists Committee on Practice Bulletins. ACOG Practice Bulletin: clinical management guidelines for obstetrician-gynecologists. Osteoporosis. Obstet Gynecol. 2004;103:203-216. Exclusion code: 2. [pmid: 14704265].
American College of Obstetricians and Gynecologists Women’s Health Care Physicians. Executive summary: hormone therapy. Obstet Gynecol. 2004;104(4 Suppl):1S-4S. Exclusion code: 6. [pmid: 15458927].
American Medical Association. Health risks outweigh benefits for combined estrogen plus progestin. Clinical trial stopped early in major study. Ginecol Obstet Mex. 2002;70:411-412. Exclusion code: 7. [pmid: 12449905].
American Medical Association. Postmenopausal hormone therapy offers no protection against heart attacks. Ginecol Obstet Mex. 2002;70:404-405. Exclusion code: 10. [pmid: 12448045].
Ancelin ML, Ritchie K. Lifelong endocrine fluctuations and related cognitive disorders. Curr Pharm Des. 2005;11(32):4229-4252. Exclusion code: 7. [pmid: 16375742].
Ancelin ML, Berr C. Hormonal replacement therapy and Alzheimer’s disease. All quiet on the western front?. Psychol. 2003;1(4):251-257. Exclusion code: 7.
Anderer P, Saletu B, Gruber D, et al. Age-related cognitive decline in the menopause: effects of hormone replacement therapy on cognitive event-related potentials. Maturitas. 2005;51(3):254-269. Exclusion code: 6. [pmid: 15978969].
Anderer P, Saletu B, Saletu-Zyhlarz G, et al. Brain regions activated during an auditory discrimination task in insomniac postmenopausal patients before and after hormone replacement therapy: low-resolution brain electromagnetic tomography applied to event-related potentials. Neuropsychobiology. 2004;49(3):134-153. Exclusion code: 11. [pmid: 15034229].
Anderer P, Semlitsch HV, Saletu B, et al. Effects of hormone replacement therapy on perceptual and cognitive event-related potentials in menopausal insomnia. Psychoneuroendocrinology. 2003;28(3):419-445. Exclusion code: 11. [pmid: 12573306].
Anderson GL, Chlebowski RT, Rossouw JE, et al. Prior hormone therapy and breast cancer risk in the Women’s Health Initiative randomized trial of estrogen plus progestin. Maturitas. 2006;55(2):103-115. Exclusion code: 12. [pmid: 16815651].
Anderson GL, Limacher M, Assaf AR, et al. Effects of conjugated equine estrogen in postmenopausal women with hysterectomy. JAMA. 2004;291(14):1701-1712. Exclusion code: 12. [pmid: 15082697].
Anderson GL, Manson J, Wallace R, et al. Implementation of the Women’s Health Initiative study design. Ann Epidemiol. 2003;13(9 Suppl):S5-17. Exclusion code: 2. [pmid: 14575938].
Andresen MS, Eilertsen AL, Abildgaard U, Sandset PM. Hormone therapy and raloxifene reduce the coagulation inhibitor potential. Blood Coagul Fibrinolysis. 2007;18(5):455-460. Exclusion code: 5. [pmid: 17581320].
Angerer P, Stork S, Kothny W, von Schacky C. Effect of postmenopausal hormone replacement on atherosclerosis in femoral arteries. Maturitas. 2002;41(1):51-60. Exclusion code: 11. [pmid: 11809343].
Hormone therapy with oestrogen or oestrogen plus progesterone does not reduce the risk of dementia or mild cognitive impairment in older postmenopausal women. Evid Based Healthcare Pub Health. 2004;8(6):396-397. Exclusion code: 7.
Antoine C, Liebens F, Carly B, et al. Influence of HRT on prognostic factors for breast cancer: a systematic review after the Women’s Health Initiative trial. Human Reproduction. 2004;19(3):741-756. Exclusion code: 11. [pmid: 14998980].
Antonicelli R, Olivieri F, Morichi V, et al. Prevention of cardiovascular events in early menopause: a possible role for hormone replacement therapy. Int J Cardiol. 2008;130(2):140-146. Exclusion code: 7. [pmid: 18617278].
Apgar BS, Weismiller DG. Hormone therapy: continuing discussion and debate. Am Fam Physician. 2003;67(7):1444. Exclusion code: 7. [pmid: 12722847].
Ardila E, Echevery J, Sanchez R. Phytoestrogens in the treatment of postmenopausal osteoporosis. Cochrane Database Syst Rev. 2009;(1). Exclusion code: 7.
Ariesen MJ, Claus SP, Rinkel GJ, Algra A. Risk factors for intracerebral hemorrhage in the general population: a systematic review. Stroke. 2003;34(8):2060-2065. Exclusion code: 9. [pmid: 12843354].
Arjmandi BH, Khalil DA, Smith BJ, et al. Soy protein has a greater effect on bone in postmenopausal women not on hormone replacement therapy, as evidenced by reducing bone resorption and urinary calcium excretion. J Clin Endocrinol Metab. 2003;88(3):1048-1054. Exclusion code: 4. [pmid: 12629084].
Armitage M, Nooney J, Evans S. Recent concerns surrounding HRT. Clin Endocrinol (Oxf). 2003;59(2):145-155. Exclusion code: 7. [pmid: 12864790].
Arora S, Jain A, Chitra R. Effects of short-term hormone replacement on atherogenic indices in Indian postmenopausal women. Indian J Clin Biochem. 2006;21(1):41-47. Exclusion code: 11.
Ashraf MS, Vongpatanasin W. Estrogen and hypertension. Curr Hypertens Rep. 2006;8(5):368-376. Exclusion code: 11. [pmid: 16965722].
Askanase AD. Estrogen therapy in systemic lupus erythematosus. Treat. 2004;3(1):19-26. Exclusion code: 3.
Atsma F, Bartelink ML, Grobbee DE, van der Schouw YT. Postmenopausal status and early menopause as independent risk factors for cardiovascular disease: a meta-analysis. Menopause. 2006;13(2):265-279. Exclusion code: 6. [pmid: 16645540].
Bagger YZ, Tanko LB, Alexandersen P, et al. Two to three years of hormone replacement treatment in healthy women have long-term preventive effects on bone mass and osteoporotic fractures: the PERF study. Bone. 2004;34(4):728-735. Exclusion code: 9. [pmid: 15050905].
Bagger YZ, Tanko LB, Alexandersen P, et al. Early postmenopausal hormone therapy may prevent cognitive impairment later in life. Menopause. 2005;12(1):12-17. Exclusion code: 6. [pmid: 15668595].
Bahl VK, Naik N. Hormone replacement therapy and coronary artery disease: buried alive?. Indian Heart J. 2002;54(1):23-30. Exclusion code: 7. [pmid: 11999084].
Bain CA, Walters MR, Lees KR, Lumsden MA. The effect of HRT on cerebral haemodynamics and cerebral vasomotor reactivity in post-menopausal women. Human Reproduction. 2004;19(10):2411-2414. Exclusion code: 11. [pmid: 15284214].
Baker LD, Sambamurti K, Craft S, et al. 17β-estradiol reduces plasma Aβ40 for HRT-naive postmenopausal women with Alzheimer disease: a preliminary study. Am J Geriatr Psychiatry. 2003;11(2):239-244. Exclusion code: 11. [pmid: 12611754].
Ballard VL, Edelberg JM. Harnessing hormonal signaling for cardioprotection. Sci Aging Knowl Environ. 2005;2005(51):6. Exclusion code: 7.
Banach T, Dobrek L, Milewicz T, et al. Effect of hormonal replacement therapy on autonomic regulation of the heart. Przegl Lek. 2004;61(5):509-513. Exclusion code: 11. [pmid: 15515816].
Banks E, Beral V, Reeves G. Published results on breast cancer and hormone replacement therapy in the Million Women Study are correct. Climacteric. 2004;7(4):415-7. Exclusion code: 7. [pmid: 15799614].
Banks E, Beral V, Reeves G, et al. Fracture incidence in relation to the pattern of use of hormone therapy in postmenopausal women. JAMA. 2004;291(18):2212-2220. Exclusion code: 6. [pmid: 15138243].
Banks E, Canfell K, Reeves G. HRT and breast cancer: recent findings in the context of the evidence to date. Womens Health. 2008;4(5):427-431. Exclusion code: 7.
Banks E, Reeves G, Evans S. Disease incidence associated with long-term use of hormone replacement therapy. Menopause and Hormone Replacement: Proceedings of the Forty Seventh Study Group of the Royal College of Obstetricians and Gynaecologists. 2004:241-254. Exclusion code: 7.
Barad D, Kooperberg C, Wactawski-Wende J, et al. Prior oral contraception and postmenopausal fracture: a Women’s Health Initiative observational cohort study. Fertil Steril. 2005;84(2):374-383. Exclusion code: 4. [pmid: 16084878].
Barr RJ, Stewart A, Torgerson DJ, Reid DM. Population screening for osteoporosis risk: a randomised control trial of medication use and fracture risk. Osteoporos Int. 2010;21(4):561-568. Exclusion code: 4. [pmid: 19565176].
Barrett-Connor E, Grady D, Sashegyi A, et al. Raloxifene and cardiovascular events in osteoporotic postmenopausal women: four-year results from the MORE (Multiple Outcomes of Raloxifene Evaluation) randomized trial. JAMA. 2002;287(7):847-857. Exclusion code: 4. [pmid: 11851576].
Barrett-Connor E, Grady D, Stefanick ML. The rise and fall of menopausal hormone therapy. Annu Rev Public Health. 2005;26:115-140. Exclusion code: 7. [pmid: 15760283].
Basile JN. Estrogen replacement does not prevent recurrent stroke or death in postmenopausal women after an ischemic stroke. J Clin Hypertens. 2002;4(1):48-49. Exclusion code: 7.
Bath PM, Gray LJ. Association between hormone replacement therapy and subsequent stroke: a meta-analysis. BMJ. 2005;330(7487):342. Exclusion code: 12. [pmid: 15640250].
Battaglia C, Cianciosi A, Mancini F, et al. Angeliq versus Activelle in normotensive postmenopausal women: a prospective, randomized pilot study. Menopause. 2009;16(4):803-809. Exclusion code: 11. [pmid: 19194341].
Bauer DC, Mundy GR, Jamal SA, et al. Use of stains and fracture: results of 4 prospective studies and cumulative meta-analysis of observational studies and controlled trials. Arch Intern Med. 2004;164(2):146-152. Exclusion code: 4. [pmid: 14744837].
Baum M. Breast cancer survival and the use of HRT. Breast. 2005;14(3):178-180. Exclusion code: 7. [pmid: 15927826].
Benschop L, Farquhar C, van der Poel N, Heineman MJ. Interventions for women with endometrioma prior to assisted reproductive technology. Cochrane Database Syst Rev. 2010;(11):CD008571. Exclusion code: 8. [pmid: 21069706].
Benster B, Carey A, Wadsworth F, et al. Double-blind placebo-controlled study to evaluate the effect of pro-juven progesterone cream on atherosclerosis and bone density. Menopause Int. 2009;15(3):100-106. Exclusion code: 4. [pmid: 19723679].
Beral V, Banks E, Reeves G. Evidence from randomised trials on the long-term effects of hormone replacement therapy. Lancet. 2002;360(9337):942-944. Exclusion code: 9. [pmid: 12354487].
Beral V, Banks E, Reeves G. Long-term effects of hormone replacement therapy. Lancet. 2003;361(9353):254-255. Exclusion code: 7. [pmid: 12547557].
Beral V, Bull D, Green JB, et al. Ovarian cancer and hormone replacement therapy in the Million Women Study. Lancet. 2007;369(9574):1703-1710. Exclusion code: 6. [pmid: 17512855].
Beral V. Million Women Study Collaborators. Breast cancer and hormone-replacement therapy in the Million Women Study. Lancet. 2003;362(9382):419-427. Exclusion code: 6. [pmid: 12927427].
Beral V, Reeves G, Banks E. Current evidence about the effect of hormone replacement therapy on the incidence of major conditions in postmenopausal women. BJOG. 2005;112(6):692-695. Exclusion code: 7. [pmid: 15924521].
Beral V, Reeves G, Bull D, et al. Breast cancer risk in relation to the interval between menopause and starting hormone therapy. J Natl Cancer Inst. 2011;103(4):296-305. Exclusion code: 6. [pmid: 21278356].
Berg AO. U.S. Preventive Services Task Force. Postmenopausal hormone replacement therapy for the primary prevention of chronic conditions: recommendations and rationale. Am J Nurs. 2003;103(6):83-91. Exclusion code: 2. [pmid: 12802162].
Bergert FW, Conrad D, Ehrenthal K, et al. Pharmacotherapy guidelines for the aged by family doctors for the use of family doctors: part C—special pharmacology. Int J Clin Pharmacol Ther. 2009;47(3):141-152. Exclusion code: 7. [pmid: 19281722].
Bernstein L. The risk of breast, endometrial and ovarian cancer in users of hormonal preparations. Basic Clin Pharmacol Toxicol. 2006;98(3):288-296. Exclusion code: 7. [pmid: 16611204].
Bhattoa HP, Bettembuk P, Balogh A, et al. The effect of 1-year transdermal estrogen replacement therapy on bone mineral density and biochemical markers of bone turnover in osteopenic postmenopausal systemic lupus erythematosus patients: a randomized, double-blind, placebo-controlled trial. Osteoporos Int. 2004;15(5):396-404. Exclusion code: 11. [pmid: 14676992].
Bhavnani BR, Strickler RC. Menopausal hormone therapy. J Obstet Gynaecol Can. 2005;27(2):137-162. Exclusion code: 7. [pmid: 15937590].
Bibbins-Domingo K, Lin F, Vittinghoff E, et al. Predictors of heart failure among women with coronary disease. Circulation. 2004;110(11):1424-1430. Exclusion code: 5. [pmid: 15353499].
Bibbins-Domingo K, Lin F, Vittinghoff E, et al. Effect of hormone therapy on mortality rates among women with heart failure and coronary artery disease. Am J Cardiol. 2005;95(2):289-291. Exclusion code: 4. [pmid: 15642574].
Billeci AM, Paciaroni M, Caso V, Agnelli G. Hormone replacement therapy and stroke. Curr Vasc Pharmacol. 2008;6(2):112-123. Exclusion code: 7. [pmid: 18393913].
Birkhauser MH, Panay N, Archer DF, et al. Updated practical recommendations for hormone replacement therapy in the peri- and postmenopause. Climacteric. 2008;11(2):108-123. Exclusion code: 2. [pmid: 18365854].
Biscup P. Risks and benefits of long-term hormone replacement therapy. Am J Health-Syst Pharm. 2003;60(14):1419-1425. Exclusion code: 7. [pmid: 12892026].
Bittner V. Postmenopausal hormone therapy and the risk of cardiovascular disease. Expert Opin Pharmacother. 2009;10(13):2041-2053. Exclusion code: 7. [pmid: 19563274].
Bjarnason NH, Alexandersen P, Christiansen C. Number of years since menopause: spontaneous bone loss is dependent but response to hormone replacement therapy is independent. Bone. 2002;30(4):637-642. Exclusion code: 11. [pmid: 11934658].
Blake J. Menopause: evidence-based practice. Best Pract Res Clin Obstet Gynaecol. 2006;20(6):799-839. Exclusion code: 7. [pmid: 17084674].
Blake JM, Collins JA, Reid RL, et al. The SOGC statement on the WHI report on estrogen and progestin use in postmenopausal women. J Obstet Gynaecol Can. 2002;24(10):783-790. Exclusion code: 10. [pmid: 12399806].
Bliss JM, Gray R. Breast cancer and hormone-replacement therapy: the Million Women Study. Lancet. 2003;362(9392):1328-1329. Exclusion code: 7. [pmid: 14575984].
Blumel JE, Castelo-Branco C, Leal T, et al. Effects of transdermal estrogens on endothelial function in postmenopausal women with coronary disease. Climacteric. 2003;6(1):38-44. Exclusion code: 11. [pmid: 12725663].
Boone RH, Cheung AM, Girlan LM, Heathcote EJ. Osteoporosis in primary biliary cirrhosis: a randomized trial of the efficacy and feasibility of estrogen/ progestin. Dig Dis Sci. 2006;51(6):1103-1112. Exclusion code: 8. [pmid: 16865577].
Booth EA, Lucchesi BR. Estrogen-mediated protection in myocardial ischemia-reperfusion injury. Cardiovasc Toxicol. 2008;8(3):101-113. Exclusion code: 6. [pmid: 18683081].
Botlero R, Urquhart DM, Davis SR, Bell RJ. Prevelance and incidence of urinary incontinence in women: review of the literature and investigation of methodological issues. Int J Urol. 2008;15:230-234. Exclusion code: 5. [pmid: 18304218].
Bots ML, Evans GW, Riley W, et al. The effect of tibolone and continuous combined conjugated equine oestrogens plus medroxyprogesterone acetate on progression of carotid intima-media thickness: the Osteoporosis Prevention and Arterial effects of tiboLone (OPAL) study. Eur Heart J. 2006;27(6):746-755. Exclusion code: 11. [pmid: 16415304].
Bots ML, Evans GW, Riley W, et al. The Osteoporosis Prevention and Arterial effects of tiboLone (OPAL) study: design and baseline characteristics. Control Clin Trials. 2003;24(6):752-775. Exclusion code: 7. [pmid: 14662281].
Bozkurt B. Where do we currently stand with advice on hormone replacement therapy for women?. Methodist Debakey Cardiovasc J. 2010;6(4):21-25. Exclusion code: 7. [pmid: 21088655].
Braendle W. The Million Women Study, an additional observational study with the implications and limits of an observational study. Maturitas. 2003;46(2):101-102. Exclusion code: 7. [pmid: 14559376].
Brandao CM, Lima MG, Silva AL, et al. Treatment of postmenopausal osteoporosis in women: a systematic review. Cad Saude Publica. 2008;24(Suppl 4):s592-606. Exclusion code: 8. [pmid: 18797733].
Brandin LM, Gustafsson H, Ghanoum B, et al. Effects of estrogen plus progesterone on hemodynamic and vascular reactivity in hypertensive postmenopausal women. Blood Press. 2010;19(3):156-163. Exclusion code: 11. [pmid: 19958076].
Brass LM. Hormone replacement therapy and stroke: clinical trials review. Stroke. 2004;35(11 Suppl 1):2644-2647. Exclusion code: 7. [pmid: 15459443].
Bray PF, Howard TD, Vittinghoff E, et al. Effect of genetic variations in platelet glycoproteins Ibα and VI on the risk for coronary heart disease events in postmenopausal women taking hormone therapy. Blood. 2007;109(5):1862-1869. Exclusion code: 5. [pmid: 17105818].
Brinton EA, Hodis HN, Merriam GR, et al. Can menopausal hormone therapy prevent coronary heart disease?. Trends Endocrinol Metab. 2008;19(6):206-212. Exclusion code: 7. [pmid: 18450469].
Bromley SE, de Vries CS, Thomas D, Farmer RD. Hormone replacement therapy and risk of acute myocardial infarction: a review of the literature. Drug Saf. 2005;28(6):473-493. Exclusion code: 7. [pmid: 15924502].
Brosnan JF, Sheppard BL, Norris LA. Haemostatic activation in post-menopausal women taking low-dose hormone therapy: less effect with transdermal administration?. Thromb Haemostas. 2007;97(4):558-565. Exclusion code: 11.
Brown CM, Suzuki S, Jelks KA, Wise PM. Estradiol is a potent protective, restorative, and trophic factor after brain injury. Semin Reprod Med. 2009;27(3):240-249. Exclusion code: 11. [pmid: 19401955].
Brown JS. Epidemiology and changing demographics of overactive bladder: a focus on the postmenopausal woman. Geriatrics. 2002;57(Suppl 1):6-12. Exclusion code: 7. [pmid: 12040602].
Brown NJ, Abbas A, Byrne D, et al. Comparative effects of estrogen and angiotensin-converting enzyme inhibition on plasminogen activator inhibitor-1 in healthy postmenopausal women. Circulation. 2002;105(3):304-309. Exclusion code: 4. [pmid: 11804984].
Brown S. WHI Memory Study fails to find oestrogen benefit in dementia. J Br Menopause Soc. 2004;10(3):93. Exclusion code: 7.
Brown S. Transdermal hormone replacement therapy not associated with an increased risk of stroke. Menopause Int. 2010;16(2):48-49. Exclusion code: 7. [pmid: 20729492].
Brownley KA, Hinderliter AL, West SG, et al. Cardiovascular effects of 6 months of hormone replacement therapy versus placebo: differences associated with years since menopause. Am J Obstet Gynecol. 2004;190(4):1052-1058. Exclusion code: 11. [pmid: 15118640].
Bruce D, Frick A, Rymer J, et al. A comparison of hormone therapies on the urinary excretion of prostacyclin and thromboxane A2. Climacteric. 2008;11(6):447-453. Exclusion code: 4. [pmid: 18821092].
Bruyere O, Reginster JY. Fracture prevention in postmenopausal women. Clin Evid. 2002;(7):979-982. Exclusion code: 9. [pmid: 12230720].
Buchholz S, Horn F, Ortmann O. Hormone replacement therapy in peri- and postmenopausal women and breast cancer risk. Ther Umsch. 2008;65(4):231-234. Exclusion code: 10. [pmid: 18622916].
Burger H. Hormone replacement therapy in the post-Women’s Health Initiative era: report at a meeting. Funchal, Madeira. February 24–25, 2003. Climacteric. 2003;6(Suppl 1):11-36. Exclusion code: 7.
Burger HG. WHI risks: any relevance to menopause management?. Maturitas. 2007;57(1):6-10. Exclusion code: 7. [pmid: 17368974].
Burkhardt MS, Foster JK, Laws SM, et al. Oestrogen replacement therapy may improve memory functioning in the absence of APOE ɛ4. J Alzheimers Dis. 2004;6(3):221-228. Exclusion code: 6. [pmid: 15201477].
Bushnell CD. The Women’s Health Initiative trial and stroke risk. Lancet Neurol. 2002;1(5):277. Exclusion code: 7. [pmid: 12849423].
Bushnell CD. Oestrogen and stroke in women: assessment of risk. Lancet Neurol. 2005;4(11):743-751. Exclusion code: 7. [pmid: 16239181].
Bushnell CD. Hormone replacement therapy and stroke: the current state of knowledge and directions for future research. Semin Neurol. 2006;26(1):123-130. Exclusion code: 7. [pmid: 16479451].
Bushnell CD, Newby LK, Goldstein LB, et al. Statin use and stroke outcomes in the Heart and Estrogen-Progestin Replacement Study (HERS). Neurology. 2004;62(6):968-970. Exclusion code: 4. [pmid: 15037702].
Byington RP, Furberg CD, Herrington DM, et al. Effect of estrogen plus progestin on progression of carotid atherosclerosis in postmenopausal women with heart disease: HERS B-mode substudy. Arterioscler Thromb Vasc Biol. 2002;22(10):1692-1697. Exclusion code: 5. [pmid: 12377751].
Byrjalsen I, Leeming DJ, Qvist P, et al. Bone turnover and bone collagen maturation in osteoporosis: effects of antiresorptive therapies. Osteoporos Int. 2008;19(3):339-348. Exclusion code: 11. [pmid: 17846859].
Cagnacci A, Tarquini R, Perfetto F, et al. Endothelin-1 and nitric oxide levels are related to cardiovascular risk factors but are not modified by estradiol replacement in healthy postmenopausal women. A cross-sectional and a randomized cross-over study. Maturitas. 2003;44(2):117-124. Exclusion code: 6. [pmid: 12590007].
Campagnoli C, Colombo P, De Aloysio D, et al. Positive effects on cardiovascular and breast metabolic markers of oral estradiol and dydrogesterone in comparison with transdermal estradiol and norethisterone acetate. Maturitas. 2002;41(4):299-311. Exclusion code: 11. [pmid: 12034517].
Campbell IA, Douglas JG, Francis RM, et al. Hormone replacement therapy (HRT) or etidronate for osteoporosis in postmenopausal asthmatics on glucocorticoids: a randomised factorial trial. Scott Med J. 2009;54(1):21-25. Exclusion code: 8. [pmid: 19291931].
Campisi R, Nathan L, Pampaloni MH, et al. Noninvasive assessment of coronary microcirculatory function in postmenopausal women and effects of short-term and long-term estrogen administration. Circulation. 2002;105(4):425-430. Exclusion code: 11. [pmid: 11815423].
Campos-Outcalt D. Clarifying the US Preventive Services Task Force’s 2005 recommendations. J Fam Pract. 2006;55(5):425-428. Exclusion code: 7. [pmid: 16670038].
Canderelli R, Leccesse LA, Miller NL, Unruh Davidson J. Benefits of hormone replacement therapy in postmenopausal women. J Am Acad Nurse Pract. 2007;19(12):635-641. Exclusion code: 7. [pmid: 18042129].
Canonico M, Oger E, Conrad J, et al. Obesity and risk of venous thromboembolism among postmenopausal women: differential impact of hormone therapy by route of estrogen administration. J Thromb Haemost. 2006;4(6):1259-1265. Exclusion code: 6. [pmid: 16706969].
Canonico M, Oger E, Plu-Bureau G, et al. Hormone therapy and venous thromboembolism among postmenopausal women: Impact of the route of estrogen administration and progestogens: the ESTHER study. Circulation. 2007;115(7):840-845. Exclusion code: 6. [pmid: 17309934].
Canonico M, Plu-Bureau G, Lowe GD, Scarabin PY. Hormone replacement therapy and risk of venous thromboembolism in postmenopausal women: systematic review and meta-analysis. BMJ. 2008;336(7655):1227-1231. Exclusion code: 12. [pmid: 18495631].
Cardozo L, Lose G, McClish D, Versi E. A systematic review of the effects of estrogens for symptoms suggestive of overactive bladder. Acta Obstet Gynecol Scand. 2004;83:892-897. Exclusion code: 9. [pmid: 15453881].
Carwile E, Wagner AK, Crago E, Alexander SA. Estrogen and stroke: a review of the current literature. J Neurosci Nurs. 2009;41(1):18-25. Exclusion code: 7. [pmid: 19368068].
Castiglione-Gertsch M. Hormone replacement and breast cancer. Ann Oncol. 275. 2004;15(Suppl 4):iv-277. Exclusion code: 7.
Cauley JA, LaCroix AZ, Robbins JA, et al. Baseline serum estradiol and fracture reduction during treatment with hormone therapy: the Women’s Health Initiative randomized trial. Osteoporos Int. 2010;21(1):167-177. Exclusion code: 5. [pmid: 19436934].
Cauley JA, Song J, Dowsett SA, et al. Risk factors for breast cancer in older women: the relative contribution of bone mineral density and other established risk factors. Breast Cancer Res Treat. 2007;102(2):181-188. Exclusion code: 4. [pmid: 17028986].
Centre for Reviews and Dissemination. Preventing fractures in postmenopausal women with osteoporosis: a review of recent controlled trials of antiresorptive agents [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 7.
Centre for Reviews and Dissemination. Postmenopausal hormone therapy and the risk of colorectal cancer: a review and meta-analysis [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 7.
Centre for Reviews and Dissemination. Mortality associated with hormone replacement therapy in younger and older women: a meta-analysis [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 7.
Centre for Reviews and Dissemination. Hormone replacement therapy and cognitive performance in postmenopausal women: a review by cognitive domain [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 6.
Centre for Reviews and Dissemination. Hormone replacement therapy and cognition [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 7.
Centre for Reviews and Dissemination. Estrogen therapy in postmenopausal women: effects on cognitive function and dementia [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 7.
Centre for Reviews and Dissemination. The effect of estrogen replacement therapy on cognitive function in women: a critical review of the literature [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 7.
Centre for Reviews and Dissemination. Combined continuous hormone replacement therapy: a critical review [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 7.
Centre for Reviews and Dissemination. Brief report: coronary heart disease events associated with hormone therapy in younger and older women. A meta-analysis [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 7.
Centre for Reviews and Dissemination. Association between hormone replacement therapy and subsequent stroke: a meta-analysis [abstract]. Database Abstr Rev Effects. 2011;(2). Exclusion code: 7.
Cerquetani E, Vitale C, Mercuro G, et al. Comparative vascular effects of hormone replacement therapy and raloxifene in women at increased cardiovascular risk. Gynecol Endocrinol. 2004;18(6):291-298. Exclusion code: 11. [pmid: 15497491].
Chan WS, Ray J, Wai EK, et al. Risk of stroke in women exposed to low-dose oral contraceptives: a critical evaluation of the evidence. Arch Intern Med. 2004;164(7):741-747. Exclusion code: 4. [pmid: 15078643].
Chang C, Lin CH. Hormone replacement therapy and menopause: a review of randomized, double-blind, placebo-controlled trials. Kaohsiung J Med Sci. 2003;19(6):257-270. Exclusion code: 7. [pmid: 12873034].
Chao HT, Kuo CD, Su YJ, et al. Short-term effect of transdermal estrogen on autonomic nervous modulation in postmenopausal women. Fertil Steril. 2005;84(5):1477-1483. Exclusion code: 11. [pmid: 16275247].
Chen CL, Weiss NS, Newcomb P, et al. Hormone replacement therapy in relation to breast cancer. JAMA. 2002;287(6):734-741. Exclusion code: 6. [pmid: 11851540].
Chen WY, Colditz GA, Rosner B, et al. Use of postmenopausal hormones, alcohol, and risk for invasive breast cancer. Ann Intern Med. 2002;137(10):798-804. Exclusion code: 9. [pmid: 12435216].
Chen WY, Manson JE, Hankinson SE, et al. Unopposed estrogen therapy and the risk of invasive breast cancer. Arch Intern Med. 2006;166:1027-1032. Exclusion code: 6. [pmid: 16682578].
Cheung AM, Feig DS, Kapral M, et al. Prevention of osteoporosis and osteoporotic fractures in postmenopausal women: recommendation statement from the Canadian Task Force on Preventive Health Care. CMAJ. 2004;170(11):1665-1667. Exclusion code: 2. [pmid: 15159360].
Chlebowski RT. Menopausal hormone therapy, hormone receptor status, and lung cancer in women. Semin Oncol. 2009;36(6):566-571. Exclusion code: 7. [pmid: 19995648].
Chlebowski RT, Anderson G, Manson JE, et al. Estrogen alone in postmenopausal women and breast cancer detection by means of mammography and breast biopsy. J Clin Oncol. 2010;28(16):2690-2697. Exclusion code: 12. [pmid: 20439627].
Chlebowski RT, Anderson GL, Lane DS, et al. Predicting risk of breast cancer in postmenopausal women by hormone receptor status. J Natl Cancer Inst. 2007;99(22):1695-1705. Exclusion code: 5. [pmid: 18000216].
Chlebowski RT, Schwartz AG, Wakelee H, et al. Oestrogen plus progestin and lung cancer in postmenopausal women (Women’s Health Initiative trial): a post-hoc analysis of a randomised controlled trial. Lancet. 2009;374(9697):1243-1251. Exclusion code: 12. [pmid: 19767090].
Cho L, Mukherjee D. Hormone replacement therapy and secondary cardiovascular prevention: a meta-analysis of randomized trials. Cardiology. 2005;104(3):143-147. Exclusion code: 8. [pmid: 16118493].
Chou ET, Schulman SP, Thiemann DR, et al. Effect of short-term estrogen with and without progesterone therapy on circulating markers of endothelial activation and injury in postmenopausal women with unstable angina pectoris. Am J Cardiol. 2003;91(10):1240-1242. Exclusion code: 11. [pmid: 12745110].
Christodoulakos G, Panoulis C, Kouskouni E, et al. Effects of estrogen-progestin and raloxifene therapy on nitric oxide, prostacyclin and endothelin-1 synthesis. Gynecol Endocrinol. 2002;16(1):9-17. Exclusion code: 11. [pmid: 11915588].
Cirillo DJ, Wallace RB, Wu L, Yood RA. Effect of hormone therapy on risk of hip and knee joint replacement in the Women’s Health Initiative. Arthritis Rheum. 2006;54(10):3194-3204. Exclusion code: 11. [pmid: 17009251].
Clarke SC, Kelleher J, Lloyd-Jones H, et al. A study of hormone replacement therapy in postmenopausal women with ischaemic heart disease: the Papworth HRT atherosclerosis study. BJOG. 2002;109(9):1056-1062. Exclusion code: 8. [pmid: 12269682].
Close P, Neuprez A, Reginster JY. Developments in the pharmacotherapeutic management of osteoporosis. Expert Opin Pharmacother. 2006;7(12):1603-1615. Exclusion code: 4. [pmid: 16872263].
Cody JD, Richardson K, Moehrer B, et al. Oestrogen therapy for urinary incontinence in post-menopausal women. Cochrane Database Syst Rev. 2009;(4):CD001405. Exclusion code: 8. [pmid: 19821277].
Coker LH, Espeland MA, Rapp SR, et al. Postmenopausal hormone therapy and cognitive outcomes: the Women’s Health Initiative Memory Study (WHIMS). J Steroid Biochem Mol Biol. 2010;118(4–5):304-310. Exclusion code: 12. [pmid: 19932751].
Coker LH, Hogan PE, Bryan NR, et al. Postmenopausal hormone therapy and subclinical cerebrovascular disease: the WHIMS-MRI Study. Neurology. 2009;72(2):125-134. Exclusion code: 11. [pmid: 19139363].
Col NF, Bowlby LA, McGarry K. The role of menopausal hormone therapy in preventing osteoporotic fractures: a critical review of the clinical evidence. Minerva Med. 2005;96(5):331-342. Exclusion code: 7. [pmid: 16227948].
Col NF, Pauker SG. The discrepancy between observational studies and randomized trials of menopausal hormone therapy: did expectations shape experience?. Ann Intern Med. 2003;139(11):923-929. Exclusion code: 7. [pmid: 14644895].
Colenda CC, Legault C, Rapp SR, et al. Psychiatric disorders and cognitive dysfunction among older, postmenopausal women: results from the Women’s Health Initiative Memory Study. Am J Geriatr Psychiatry. 2010;18(2):177-186. Exclusion code: 6. [pmid: 20104074].
Collins JA, Blake JM, Crosignani PG. Breast cancer risk with postmenopausal hormonal treatment. Hum Reprod Update. 2005;11(6):545-560. Exclusion code: 5. [pmid: 16150813].
Collins P. Risk factors for cardiovascular disease and hormone therapy in women. Heart. 24. 2006;92(Suppl III):iii-28. Exclusion code: 7.
Committee on Safety of Medicines. Further advice on safety of HRT: risk:benefit unfavourable for first-line use in prevention of osteoporosis. Medicines and Healthcare Products Regulatory Agency. 2003. Exclusion code: 7.
Compston J. How to manage osteoporosis after the menopause. Baillieres Best Pract Res Clin Rheumatol. 2005;19(6):1007-1019. Exclusion code: 7.
Compston JE, Watts NB. Combination therapy for postmenopausal osteoporosis. Clin Endocrinol. 2002;56(5):565-569. Exclusion code: 9.
Conner P, Soderqvist G, Skoog L, et al. Breast cell proliferation in postmenopausal women during HRT evaluated through fine needle aspiration cytology. Breast Cancer Res Treat. 2003;78(2):159-165. Exclusion code: 11. [pmid: 12725416].
Corson SL. HRT: forever or never?. Int J Fertil Womens Med. 2002;47(4):150-151. Exclusion code: 7. [pmid: 12199410].
Cosman F, Baz-Hecht M, Cushman M, et al. Short-term effects of estrogen, tamoxifen and raloxifene on hemostasis: a randomized-controlled study and review of the literature. Thromb Res. 2005;116(1):1-13. Exclusion code: 11. [pmid: 15850603].
Couzin J. Estrogen research. The great estrogen conundrum. Science. 2003;302(5648):1136-1138. Exclusion code: 7. [pmid: 14615508].
Cowley G, Springen K, Reconsidering HRT. Newsweek. 2002;139(17):71. Exclusion code: 7.
Craig MC, Maki PM, Murphy DG. The Women’s Health Initiative Memory Study: findings and implications for treatment. Lancet Neurol. 2005;4(3):190-194. Exclusion code: 12. [pmid: 15721829].
Crandall C. Combination treatment of osteoporosis: a clinical review. J Womens Health Gend Based Med. 2002;11(3):211-224. Exclusion code: 7. [pmid: 11988132].
Crandall C. Low-dose estrogen therapy for menopausal women: a review of efficacy and safety. J Womens Health. 2003;12(8):723-747. Exclusion code: 7.
Crandall CJ, Aragaki AK, Chlebowski RT, et al. New-onset breast tenderness after initiation of estrogen plus progestin therapy and breast cancer risk. Arch Intern Med. 2009;169(18):1684-1691. Exclusion code: 11. [pmid: 19822825].
Cranney A, Guyatt G, Griffith L, et al. Meta-analyses of therapies for postmenopausal osteoporosis, IX: summary of meta-analyses of therapies for postmenopausal osteoporosis. Endocr Rev. 2002;23(4):570-578. Exclusion code: 7. [pmid: 12202472].
Creasman WT. Breast cancer: the role of hormone therapy. Semin Reprod Med. 2005;23(2):167-171. Exclusion code: 7. [pmid: 15852202].
Csizmadi I, Collet JP, Benedetti JF, Hanley JA. The effect of transdermal and oral oestrogen replacement therapy on colorectal cancer risk in postmenopausal women. Br J Cancer. 2004;90:76-81. Exclusion code: 6. [pmid: 14710210].
Cummings SR, Karpf DB, Harris F, et al. Improvement in spine bone density and reduction in risk of vertebral fractures during treatment with antiresorptive drugs. Am J Med. 2002;112(4):281-289. Exclusion code: 9. [pmid: 11893367].
Cutolo M, Sulli A, Seriolo B. Estrogens, autoimmunity and the heart. Lupus. 2005;14(9):675-678. Exclusion code: 11. [pmid: 16218465].
Cuzick J, Powles T, Veronesi U, et al. Overview of the main outcomes in breast-cancer prevention trials. Lancet. 2003;361(9354):296-300. Exclusion code: 4. [pmid: 12559863].
Czlonkowska A, Ciesielska A, Joniec I. Influence of estrogens on neurodegenerative processes. Med Sci Monit. 2003;9(10):RA247-256. Exclusion code: 7. [pmid: 14523340].
Dalal D, Robbins JA. Management of hyperlipidemia in the elderly population: an evidence-based approach. South Med J. 2002;95(11):1255-1261. Exclusion code: 7. [pmid: 12539990].
Davey DA. Menopause and HRT—keeping perspective. S Afr Med J. 2004;94(1):23-25. Exclusion code: 7. [pmid: 14971224].
Davis SR, Stuckey BG, Norman RJ, et al. Effects of the route of estrogen administration on insulinlike growth factor-I, IGF binding protein-3, and insulin resistance in healthy postmenopausal women: results from a randomized, controlled study. Menopause. 2008;15(6):1065-1069. Exclusion code: 11. [pmid: 18806686].
Day A. Lessons from the Women’s Health Initiative: primary prevention and gender health. CMAJ. 2002;167(4):361-362. Exclusion code: 7. [pmid: 12197691].
de Klerk BM, Schiphof D, Groeneveld FP, et al. Limited evidence for a protective effect of unopposed oestrogen therapy for osteoarthritis of the hip: a systematic review. Rheumatology (Oxford). 2009;48:104-112. Exclusion code: 7. [pmid: 19000994].
de Kraker AT, Kenemans P, Smolders RG, et al. Short-term effects of two continuous combined oestrogen-progestogen therapies on several cardiovascular risk markers in healthy postmenopausal women: a randomised controlled trial. Eur J Obstet Gynecol Reprod Biol. 2009;142(2):139-144. Exclusion code: 11. [pmid: 19095343].
de Villiers T. The role of menopausal hormone therapy in osteoporosis. Climacteric. 2007;10(Suppl 2):71-73. Exclusion code: 7. [pmid: 17882677].
de Villiers TJ. Bone health and osteoporosis in postmenopausal women. Best Pract Res Clin Obstet Gynaecol. 2009;23(1):73-85. Exclusion code: 7. [pmid: 19027366].
Decensi A, Bonanni B, Baglietto L, et al. A two-by-two factorial trial comparing oral with transdermal estrogen therapy and fenretinide with placebo on breast cancer biomarkers. Clin Cancer Res. 2004;10(13):4389-4397. Exclusion code: 11. [pmid: 15240527].
Decensi A, Omodei U, Robertson C, et al. Effect of transdermal estradiol and oral conjugated estrogen on C-reactive protein in retinoid-placebo trial in healthy women. Circulation. 2002;106(10):1224-1228. Exclusion code: 11. [pmid: 12208797].
Dehn B. Care of the menopausal patient: a nurse practitioner’s view. J Am Acad Nurse Pract. 2007;19(8):427-437. Exclusion code: 7. [pmid: 17655572].
Denes P, Larson JC, Lloyd-Jones DM, et al. Major and minor ECG abnormalities in asymptomatic women and risk of cardiovascular events and mortality. JAMA. 2007;297(9):978-985. Exclusion code: 11. [pmid: 17341712].
Deo R, Lin F, Vittinghoff E, et al. Kidney dysfunction and sudden cardiac death among women with coronary heart disease. Hypertension. 2008;51(6):1578-1582. Exclusion code: 11. [pmid: 18391103].
Derman RJ. Estrogens and bone. Int J Fertil Womens Med. 2003;48(3):102-105. Exclusion code: 7. [pmid: 12839139].
Derry PS. Time trends in the HERS secondary prevention trial: much ado about nothing?. J Am Med Womens Assoc. 2002;57(4):215-216. Exclusion code: 7. [pmid: 12405240].
Dezarnaulds G, Fraser IS. Vaginal ring delivery of hormone replacement therapy: a review. Expert Opin Pharmacother. 2003;4:201-212. Exclusion code: 7. [pmid: 12562310].
Di Carlo C, Tommaselli GA, Sammartino A, et al. Serum leptin levels and body composition in postmenopausal women: effects of hormone therapy. Menopause. 2004;11(4):466-473. Exclusion code: 11. [pmid: 15243285].
Diamanti-Kandarakis E. Hormone replacement therapy and risk of malignancy. Curr Opin Obstet Gynecol. 2004;16(1):73-78. Exclusion code: 7. [pmid: 15128011].
Dick SE, DeWitt DE, Anawalt BD. Postmenopausal hormone replacement therapy and major clinical outcomes: a focus on cardiovascular disease, osteoporosis, dementia, and breast and endometrial neoplasia. Am J Manag Care. 2002;8(1):95-104. quiz 105–106. Exclusion code: 6. [pmid: 11814176].
Dimai HP, Pietschmann P, Resch H, et al. Guidelines for drug therapy of postmenopausal osteoporosis. Wien Med Wochenschr. 2002;152(23–24):596-612. Exclusion code: 10. [pmid: 12530170].
Ding EL, Mehta S, Fawzi WW, Giovannucci EL. Interaction of estrogen therapy with calcium and vitamin D supplementation on colorectal cancer risk: reanalysis of Women’s Health Initiative randomized trial. Int J Cancer. 2008;122(8):1690-1694. Exclusion code: 5. [pmid: 18092326].
Doherty JA, Cushing-Haugen KL, Saltzman BS, et al. Long-term use of postmenopausal estrogen and progestin hormone therapies and the risk of endometrial cancer. Am J Obstet Gynecol. 2007;197:139.e131-7. Exclusion code: 6. [pmid: 17689625].
Doren M. Estrogen therapy for prevention and treatment of osteoporosis. Maturitas. 2002;43(Suppl 1):S53-56. Exclusion code: 7. [pmid: 12361888].
Doty TJ. Postmenopausal hormone replacement therapy after the Women’s Health Initiative. JAAPA. 2005;18(1):30-37. Exclusion code: 7. [pmid: 15675117].
Duan DH. Different dose hormone-replacement therapy in treatment of postmenopausal osteoporosis. Acta Acad Med Shanghai. 2003;30(5):477-479. Exclusion code: 11.
Dubey RK, Imthurn B, Barton M, Jackson EK. Vascular consequences of menopause and hormone therapy: importance of timing of treatment and type of estrogen. Cardiovasc Res. 2005;66(2):295-306. Exclusion code: 11. [pmid: 15820198].
Dubey RK, Tofovic SP, Jackson EK. Cardiovascular pharmacology of estradiol metabolites. J Pharmacol Exp Ther. 2004;308(2):403-409. Exclusion code: 11. [pmid: 14657266].
Dull P. Hormone replacement therapy. Prim Care. 2006;33(4):953-963. Exclusion code: 7. [pmid: 17169676].
Dumas J, Hancur-Bucci C, Naylor M, et al. Estrogen treatment effects on anticholinergic-induced cognitive dysfunction in normal postmenopausal women. Neuropsychopharmacology. 2006;31(9):2065-2078. Exclusion code: 13. [pmid: 16482084].
Dumas J, Hancur-Bucci C, Naylor M, et al. Estradiol interacts with the cholinergic system to affect verbal memory in postmenopausal women: evidence for the critical period hypothesis. Horm Behav. 2008;53(1):159-169. Exclusion code: 14. [pmid: 17964576].
Dumas JA, Kutz AM, Naylor MR, et al. Increased memory load-related frontal activation after estradiol treatment in postmenopausal women. Horm Behav. 2010;58(5):929-935. Exclusion code: 11. [pmid: 20849856].
Dunkin J, Rasgon N, Zeller M, et al. Estrogen replacement and cognition in postmenopausal women: effect of years since menopause on response to treatment. Drug Dev Res. 2005;66(2):150-159. Exclusion code: 13.
Duvernoy C, Martin J, Briesmiester K, et al. Myocardial blood flow and flow reserve in response to hormone therapy in postmenopausal women with risk factors for coronary disease. J Clin Endocrinol Metab. 2004;89(6):2783-2788. Exclusion code: 11. [pmid: 15181058].
Duvernoy CS, Rose PA, Kim HM, et al. Combined continuous ethinyl estradiol/ norethindrone acetate does not improve forearm blood flow in postmenopausal women at risk for cardiovascular events: a pilot study. J Womens Health. 2007;16(7):963-970. Exclusion code: 11.
Edinburgh RCoPo. Consensus Conference on Hormone Replacement Therapy. 2003. Exclusion code: 7.
Edmonds MJ, Crichton TJ, Runciman WB, Pradhan M. Evidence-based risk factors for postoperative deep vein thrombosis. ANZ J Surg. 2004;74(12):1082-1097. Exclusion code: 5. [pmid: 15574153].
Eichner SF, Lloyd KB, Timpe EM. Comparing therapies for postmenopausal osteoporosis prevention and treatment. Ann Pharmacother. 2003;37(5):711-724. Exclusion code: 7. [pmid: 12708951].
Eilertsen AL, Qvigstad E, Andersen TO, et al. Conventional-dose hormone therapy (HT) and tibolone, but not low-dose HT and raloxifene, increase markers of activated coagulation. Maturitas. 2006;55(3):278-287. Exclusion code: 11. [pmid: 16713143].
Enserink M. Women’s health. The vanishing promises of hormone replacement. Science. 2002;297(5580):325-326. Exclusion code: 7. [pmid: 12130763].
Espeland MA, Tindle HA, Bushnell CA, et al. Brain volumes, cognitive impairment, and conjugated equine estrogens. J Gerontol A Biol Sci Med Sci. 2009;64(12):1243-1250. Exclusion code: 11. [pmid: 19729392].
Espie M, Daures JP, Chevallier T, et al. Breast cancer incidence and hormone replacement therapy: results from the MISSION study, prospective phase. Gynecol Endocrinol. 2007;23(7):391-397. Exclusion code: 6. [pmid: 17701770].
Evio S, Pekkarinen T, Sintonen H, et al. The effect of hormone therapy on the health-related quality of life in elderly women. Maturitas. 2007;56(2):122-128. Exclusion code: 5. [pmid: 17158003].
Fait T, Vrablik M, Zizka Z, Kostirova M. Changes in hemostatic variables induced by estrogen replacement therapy: comparison of transdermal and oral administration in a crossover-designed study. Gynecol Obstet Invest. 2008;65(1):47-51. Exclusion code: 11. [pmid: 17713346].
Farag NH, Mahata M, Ziegler MG, et al. Hormone replacement therapy increases renal kallikrein excretion in healthy postmenopausal women. Life Sci. 2003;72(11):1279-1288. Exclusion code: 11. [pmid: 12570928].
Farag NH, Nelesen RA, Parry BL, et al. Autonomic and cardiovascular function in postmenopausal women: the effects of estrogen versus combination therapy. Am J Obstet Gynecol. 2002;186(5):954-961. Exclusion code: 11. [pmid: 12015521].
Farquhar C, Marjoribanks J, Lethaby A, et al. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2009;(2):CD004143. Exclusion code: 12. [pmid: 19370593].
Feigin VL, Rinkel GJ, Lawes CM, et al. Risk factors for subarachnoid hemorrhage: an updated systematic review of epidemiological studies. Stroke. 2005;36(12):2773-2780. Exclusion code: 7. [pmid: 16282541].
Fenkci V, Yilmazer M, Alpaslan M, et al. The short-term effects of different regimens of hormone replacement therapy on left ventricular structure and performance in healthy postmenopausal women: a prospective, controlled echocardiographic study. Gynecol Obstet Invest. 2003;55(3):139-144. Exclusion code: 9. [pmid: 12865592].
Fenton A, Panay N. Communication: do we have a problem?. Climacteric. 2008;11(4):265-266. Exclusion code: 7. [pmid: 18645690].
Fenton A, Panay N. Hormone therapy and colorectal cancer. Climacteric. 2009;12(2):89-90. Exclusion code: 7. [pmid: 19259852].
Fernandez H, Lucas C, Hedon B, et al. One year comparison between two add-back therapies in patients treated with a GnRH agonist for symptomatic endometriosis: a randomized double-blind trial. Human Reproduction. 2004;19(6):1465-1471. Exclusion code: 8. [pmid: 15105403].
File SE, Heard JE, Rymer J. Trough oestradiol levels associated with cognitive impairment in post-menopausal women after 10 years of oestradiol implants. Psychopharmacology (Berl). 2002;161(1):107-112. Exclusion code: 6. [pmid: 11967638].
Fillit HM. The role of hormone replacement therapy in the prevention of Alzheimer disease. Arch Intern Med. 2002;162:1934-1942. Exclusion code: 7. [pmid: 12230415].
Fink K, Clark B. Screening for osteoporosis in postmenopausal women. Am Fam Physician. 2004;69(1):139-140. Exclusion code: 7. [pmid: 14727831].
Fletcher SW, Colditz GA. Failure of estrogen plus progestin therapy for prevention. JAMA. 2002;288:366-368. Exclusion code: 7. [pmid: 12117403].
Folsom AR, Anderson JP, Ross JA. Estrogen replacement therapy and ovarian cancer. Epidemiology. 2004;15(1):100-104. Exclusion code: 6. [pmid: 14712153].
Freda MC. What a surprise. MCN Am J Matern Child Nurs. 2007;32(3):137. Exclusion code: 7. [pmid: 17479045].
Freeman EE, Munoz B, Bressler SB, West SK. Hormone replacement therapy, reproductive factors, and age-related macular degeneration: the Salisbury eye evaluation project. Ophthalmic Epidemiol. 2005;12:37-45. Exclusion code: 6. [pmid: 15848919].
Frye CA. Steroids, reproductive endocrine function, and cognition: a review. Minerva Ginecol. 2009;61(6):563-585. Exclusion code: 7. [pmid: 19942841].
Fuchs FD. Hormonal replacement and cardiovascular disease: a guideline against the evidence. Arq Bras Cardiol. 2009;93(1):e11-13. Exclusion code: 10. [pmid: 19838458].
Fugh-Berman A, Scialli AR. Gynecologists and estrogen: an affair of the heart. Perspect Biol Med. 2006;49(1):115-130. Exclusion code: 7. [pmid: 16489281].
Furberg CD, Vittinghoff E, Davidson M, et al. Subgroup interactions in the Heart and Estrogen/Progestin Replacement Study: lessons learned. Circulation. 2002;105(8):917-922. Exclusion code: 6. [pmid: 11864918].
Furness S, Roberts H, Marjoribanks J, et al. Hormone therapy in postmenopausal women and risk of endometrial hyperplasia. Cochrane Database Syst Rev. 2009;(2):CD000402. Exclusion code: 11. [pmid: 19370558].
Fylstra DL. Postmenopausal hormone replacement therapy: does the progestin make a difference?. J S C Med Assoc. 2002;98(1):12-19. Exclusion code: 4. [pmid: 11859600].
Gabriel SR, Carmona L, Roque M, et al. Hormone replacement therapy for preventing cardiovascular disease in post-menopausal women. Cochrane Database Syst Rev. 2005;(2):CD002229. Exclusion code: 12. [pmid: 15846631].
Gabriel-Cox K. Hormone replacement therapy and primary prevention: alas, again. Prev Cardiol. 2003;6(1):61-62. Exclusion code: 7. [pmid: 12624565].
Gallus S, Negri E, Chatenoud L, et al. Post-menopausal hormonal therapy and gallbladder cancer risk. Int J Cancer. 2002;99:762-763. Exclusion code: 6. [pmid: 12115514].
Gambacciani M, Genazzani AR. The missing R. Gynecol Endocrinol. 2003;17(2):91-94. Exclusion code: 7. [pmid: 12741416].
Gambacciani M, Monteleone P, Sacco A, Genazzani AR. Hormone replacement therapy and endometrial, ovarian and colorectal cancer. Baillieres Best Pract Res Clin Endocrinol Metab. 2003;17:139-147. Exclusion code: 7.
Gambone JC. How we got to the Women’s Health Initiative hormone replacement trial. J Am Osteopath Assoc. 2003;103(2 Suppl 2):S1-2. Exclusion code: 7. [pmid: 12625630].
Gami AS, Wright S, Ballman KV, et al. Hormone replacement therapy and risk of acute myocardial infarction in postmenopausal women with diabetes mellitus. Am J Cardiol. 2003;91:1275-1277. Exclusion code: 6. [pmid: 12745121].
Garbe E, Levesque L, Suissa S. Variability of breast cancer risk in observational studies of hormone replacement therapy: a meta-regression analysis. Maturitas. 2004;47(3):175-183. Exclusion code: 7. [pmid: 15036487].
Garbe E, Suissa S. Hormone replacement therapy and acute coronary outcomes: methodological issues between randomized and observational studies. Human Reproduction. 2004;19(1):8-13. Exclusion code: 7. [pmid: 14688150].
Garnero P, Jamin C, Benhamou CL, et al. Effects of tibolone and combined 17β-estradiol and norethisterone acetate on serum C-reactive protein in healthy post-menopausal women: a randomized trial. Human Reproduction. 2002;17(10):2748-2753. Exclusion code: 4. [pmid: 12351557].
Gatto NM, Hodis HN, Liu CR, et al. Brachial artery vasoreactivity is associated with cross-sectional and longitudinal anatomical measures of atherosclerosis in postmenopausal women with coronary artery disease. Atherosclerosis. 2008;196(2):674-681. Exclusion code: 11. [pmid: 17803999].
Genazzani AR, Gambacciani M. A personal initiative for women’s health: to challenge the Women’s Health Initiative. Gynecol Endocrinol. 2002;16(4):255-257. Exclusion code: 7. [pmid: 12396552].
Genazzani AR, Gambacciani M, Schneider HP, et al. Postmenopausal osteoporosis: therapeutic options. Climacteric. 2005;8(2):99-109. Exclusion code: 7. [pmid: 16096166].
Giangregorio L, Papaioannou A, Cranney A, et al. Fragility fractures and the osteoporosis care gap: an international phenomenon. Semin Arthritis Rheum. 2006;35(5):293-305. Exclusion code: 5. [pmid: 16616152].
Gibbons RJ, Abrams J, Chatterjee K, et al. ACC/AHA 2002 guideline update for the management of patients with chronic stable angina—summary article: a report of the American College of Cardiology/American Heart Task Force on Practice Guidelines (Committee on the Management of Patients With Chronic Stable Angina). Circulation. 2003;107(1):149-158. Exclusion code: 7. [pmid: 12515758].
Gibson CL, Gray LJ, Murphy SP, Bath PM. Estrogens and experimental ischemic stroke: a systematic review. J Cereb Blood Flow Metab. 2006;26(9):1103-1113. Exclusion code: 3. [pmid: 16437060].
Giersig C. Progestin and breast cancer. The missing pieces of a puzzle. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. 2008;51(7):782-786. Exclusion code: 7. [pmid: 18592338].
Girdler SS, Hinderliter AL, Wells EC, et al. Transdermal versus oral estrogen therapy in postmenopausal smokers: hemodynamic and endothelial effects. Obstet Gynecol. 2004;103(1):169-180. Exclusion code: 11. [pmid: 14704262].
Glud E, Kjaer SK, Thomsen BL, et al. Hormone therapy and the impact of estrogen intake on the risk of ovarian cancer. Arch Intern Med. 2004;164:2253-2259. Exclusion code: 6. [pmid: 15534163].
Goderie-Plomp HW, van der Klift M, de Ronde W, et al. Endogenous sex hormones, sex-hormone binding globulin, and the risk of incident vertebral fractures in elderly men and women: the Rotterdam study. J Clin Endocrinol Metab. 2004;89(7):3261-3269. Exclusion code: 6. [pmid: 15240601].
Goldstein LB, Adams R, Alberts MJ, et al. Primary prevention of ischemic stroke: a guideline from the American Heart Association/American Stroke Association Stroke Council: cosponsored by the Atherosclerotic Peripheral Vascular Disease Interdisciplinary Working Group; Cardiovascular Nursing Council; Clinical Cardiology Council; Nutrition, Physical Activity, and Metabolism Council; and the Quality of Care and Outcomes Research Interdisciplinary Working Group. Circulation. 2006;113(24):e873-923. Exclusion code: 2. [pmid: 16785347].
Goldzieher JW. Hormone replacement therapy and the Women’s Health Initiative: the emperor has no clothes. Endocr Pract. 2004;10(5):448-449. Exclusion code: 7. [pmid: 15760795].
Gomberg-Maitland M, Wenger NK, Feyzi J, et al. Anticoagulation in women with non-valvular atrial fibrillation in the stroke prevention using an oral thrombin inhibitor (SPORTIF) trials. Eur Heart J. 2006;27(16):1947-1953. Exclusion code: 4. [pmid: 16774980].
Gompel A, Plu-Bureau G. Is the decrease in breast cancer incidence related to a decrease in postmenopausal hormone therapy?. Ann N Y Acad Sci. 2010;1205:268-276. Exclusion code: 7. [pmid: 20840283].
Gorins A. Progestins and risk of breast cancer. Much ado about nothing?. Eur J Gynaecol Oncol. 2003;24(5):345-350. Exclusion code: 7. [pmid: 14584641].
Grady D, Herrington D, Bittner V, et al. Cardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/Progestin Replacement Study follow-up (HERS II). JAMA. 2002;288(1):49-57. Exclusion code: 2. [pmid: 12090862].
Graff-Iversen S, Hammar N, Thelle DS, Tonstad S. Hormone therapy and mortality during a 14-year follow-up of 14,324 Norwegian women. J Intern Med. 2004;256(5):437-445. Exclusion code: 6. [pmid: 15485480].
Greenspan SL, Resnick NM, Parker RA. Early changes in biochemical markers of bone turnover are associated with long-term changes in bone mineral density in elderly women on alendronate, hormone replacement therapy, or combination therapy: a three-year, double-blind, placebo-controlled, randomized clinical trial. J Clin Endocrinol Metab. 2005;90(5):2762-2767. Exclusion code: 11. [pmid: 15713726].
Greenspan SL, Resnick NM, Parker RA. The effect of hormone replacement on physical performance in community-dwelling elderly women. Am J Med. 2005;118(11):1232-1239. Exclusion code: 9. [pmid: 16271907].
Greiser CM, Greiser EM, Doren M. Menopausal hormone therapy and risk of breast cancer: a meta-analysis of epidemiological studies and randomized controlled trials. Hum Reprod Update. 2005;11(6):561-573. Exclusion code: 7. [pmid: 16150812].
Greiser CM, Greiser EM, Doren M. Menopausal hormone therapy and risk of ovarian cancer: systematic review and meta-analysis. Hum Reprod Update. 2007;13(5):453-463. Exclusion code: 6. [pmid: 17573406].
Grodstein F, Manson J, Stampfer M, Rexrode KM. Postmenopausal hormone therapy and stroke: role of time since menopause and age at intiation of hormone therapy. Arch Intern Med. 2008;168:861-866. Exclusion code: 6. [pmid: 18443262].
Grodstein F, Manson JE, Stampfer M. Hormone therapy and coronary heart disease: the role of time since menopause and age at hormone initiation. J Womens Health. 2006;15:35-44. Exclusion code: 9.
Guaschino S, Grimaldi E, Sartore A, et al. Visual function in menopause: the role of hormone replacement therapy. Menopause. 2003;10(1):53-57. Exclusion code: 11. [pmid: 12544677].
Guay MP, Dragomir A, Pilon D, et al. Changes in pattern of use, clinical characteristics and persistence rate of hormone replacement therapy among postmenopausal women after the WHI publication. Pharmacoepidemiol Drug Saf. 2007;16(1):17-27. Exclusion code: 6. [pmid: 16794994].
Guvenal T, Durna A, Erden O, et al. Effects of different postmenopausal hormone therapy regimens on cerebral blood flow and cognitive functions. Adv Ther. 2009;26(8):805-811. Exclusion code: 14. [pmid: 19672567].
Hachul H, Bittencourt LR, Andersen ML, et al. Effects of hormone therapy with estrogen and/or progesterone on sleep pattern in postmenopausal women. Int J Gynaecol Obstet. 2008;103(3):207-212. Exclusion code: 5. [pmid: 18812241].
Hale G, Paul-Labrador M, Dwyer JH, Merz CN. Isoflavone supplementation and endothelial function in menopausal women. Clin Endocrinol (Oxf). 2002;56(6):693-701. Exclusion code: 4. [pmid: 12072038].
Hamada AL, Maruo T, Samoto T, et al. Estradiol/progesterone-releasing vaginal rings for hormone replacement therapy in postmenopausal women. Gynecol Endocrinol. 2003;17:247-254. Exclusion code: 5. [pmid: 12857433].
Harman SM, Vittinghoff E, Brinton EA, et al. Timing and duration of menopausal hormone treatment may affect cardiovascular outcomes. Am J Med. 2011;124(3):199-205. Exclusion code: 7. [pmid: 21396500].
Heinrich AB, Wolf OT. Investigating the effects of estradiol or estradiol/progesterone treatment on mood, depressive symptoms, menopausal symptoms and subjective sleep quality in older healthy hysterectomized women: a questionnaire study. Neuropsychobiology. 2005;52(1):17-23. Exclusion code: 5. [pmid: 15942259].
Hellgren M, Conard J, Norris L, Kluft C. Cardiovascular risk markers during treatment with estradiol and trimegestone or dydrogesterone. Maturitas. 2009;62(3):287-293. Exclusion code: 11. [pmid: 19268506].
Henderson VW. Aging, estrogens, and episodic memory in women. Cogn Behav Neurol. 2009;22(4):205-214. Exclusion code: 7. [pmid: 19996872].
Henderson VW. Action of estrogens in the aging brain: dementia and cognitive aging. Biochim Biophys Acta. 2010;1800(10):1077-1083. Exclusion code: 7. [pmid: 19913598].
Hernandez-Avila M, Liang MH, Willett WC, et al. Exogenous sex hormones and the risk of rheumatoid arthritis. Arthritis Rheum. 1990;33:947-953. Exclusion code: 6. [pmid: 2369431].
Hirai K, Tsuda H. Estrogen and urinary incontinence. Int J Urol. 2009;16(1):45-48. Exclusion code: 7. [pmid: 19120525].
Hogervorst E, Bandelow S. Sex steroids to maintain cognitive function in women after the menopause: a meta-analyses of treatment trials. Maturitas. 2010;66(1):56-71. Exclusion code: 8. [pmid: 20202765].
Hogervorst E, Yaffe K, Richards M, Huppert F. Hormone replacement therapy to maintain cognitive function in women with dementia. Cochrane Database Syst Rev. 2002;(3):CD003799. Exclusion code: 12. [pmid: 12137718].
Hoibraaten E, Qvigstad E, Arnesen H, et al. Increased risk of recurrent venous thromboembolism during hormone replacement therapy: results of the randomized, double-blind, placebo-controlled estrogen in venous thromboembolism trial (EVTET). Thromb Haemost. 2000;84(6):961-967. Exclusion code: 8. [pmid: 11154141].
Howell A, Evans GD. Hormone replacement therapy and breast cancer. Recent Results Cancer Res. 2011;188:115-124. Exclusion code: 7. [pmid: 21253794].
Hsia J, Alderman EL, Verter JI, et al. Women’s angiographic vitamin and estrogen trial: design and methods. Control Clin Trials. 2002;23(6):708-727. Exclusion code: 7. [pmid: 12505248].
Hsia J, Criqui MH, Herrington DM, et al. Conjugated equine estrogens and peripheral arterial disease risk: the Women’s Health Initiative. Am Heart J. 2006;152(1):170-176. Exclusion code: 12. [pmid: 16824852].
Huang AJ, Ettinger B, Vittinghoff E, et al. Endogenous estrogen levels and the effects of ultra-low-dose transdermal estradiol therapy on bone turnover and BMD in postmenopausal women. J Bone Miner Res. 2007;22(11):1791-1797. Exclusion code: 11. [pmid: 17620054].
Humphrey LL. Hormone Replacement Therapy and Breast Cancer. Agency for Healthcare Research and Quality. 2002. Exclusion code: 2.
Humphrey LL, Chan BK, Sox HC. Postmenopausal hormone replacement therapy and the primary prevention of cardiovascular disease. Ann Intern Med. 2002;137(4):273-284. Exclusion code: 12. [pmid: 12186518].
Humphrey LL, Takano LM, Chan BK. Postmenopausal Hormone Replacement Therapy and Cardiovascular Disease. US Preventive Services Task Force. 2002. Exclusion code: 2.
Hundrup YA, Hoidrup S, Ekholm O, et al. Risk of low-energy hip, wrist, and upper arm fractures among current and previous users of hormone replacement therapy: the Danish nurse cohort study. Eur J Epidemiol. 2004;19(12):1089-1095. Exclusion code: 6. [pmid: 15678788].
Ishida Y, Kawai S. Comparative efficacy of hormone replacement therapy, bisphosphonates, calcitonin, vitamin D and vitamin K in postmenopausal women with osteoporosis. J Bone Min Res. 2002;18(Suppl 2):S158. Exclusion code: 4.
Ishida Y, Kawai S. A two-year randomized controlled trial of hormone replacement therapy, etidronate, calcitonin, vitamin D, or vitamin K, in women with postmenopausal osteoporosis. J Bone Min Res. 2002;17(Suppl 1):S478. Exclusion code: 11.
Ishida Y, Kawai S. Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, vitamin D and vitamin K in postmenopausal osteoporosis. Bone. 2003;33(5 Suppl 1):S220. Exclusion code: 7.
Ishida Y, Soh H, Tsuchida S, et al. Effectiveness of hormone replacement therapy, etidronate, calcitonin, vitamin D, and vitamin K in postmenopausal women with osteoporosis. Bone. 2002;3(Suppl):S50. Exclusion code: 7.
Janicka K. The influence of hormone therapy upon cognitive style and depression in menopausal women. Przegl Menopauz. 2008;7(2):61-68. Exclusion code: 5.
Joffe H. The impact of estrogen therapy on cognition in perimenopausal and postmenopausal women. 2001. Exclusion code: 7.
Joffe H, Hall JE, Gruber S, et al. Estrogen therapy selectively enhances prefrontal cognitive processes: a randomized, double-blind, placebo-controlled study with functional magnetic resonance imaging in perimenopausal and recently postmenopausal women. Menopause. 2006;13(3):411-422. Exclusion code: 13. [pmid: 16735938].
John SC, Malcolm W. Oral versus non-oral hormone replacement therapy: how important is the route of administration?. Ginekol Pol. 2007;78(7):514-520. Exclusion code: 7. [pmid: 17915406].
Johnson JR, Lacey JV Jr, Lazovich D, et al. Menopausal hormone therapy and risk of colorectal cancer. Cancer Epidemiol Biomarkers Prev. 2009;18(1):196-203. Exclusion code: 6. [pmid: 19124498].
Kang JH, Weuve J, Grodstein F. Postmenopausal hormone therapy and risk of cognitive decline in community-dwelling aging women. Neurology. 2004;63(1):101-107. Exclusion code: 6. [pmid: 15249618].
Karakorpi M, Alhola P, Urrila AS, et al. Hormone treatment gives no benefit against cognitive changes caused by acute sleep deprivation in postmenopausal women. Neuropsychopharmacology. 2006;31(9):2079-2088. Exclusion code: 8. [pmid: 16541085].
Katzman R, Brown R, Fuld P, et al. Validation of a short Orientation-Memory Concentration Test of cognitive impairment. Am J Psychiatry. 1983;140:734-739. Exclusion code: 7. [pmid: 6846631].
Kesslak JP. Can estrogen play a significant role in the prevention of Alzheimer’s disease?. J Neural Transm Suppl. Supplementum. 2002;(62):227-239. Exclusion code: 7. [pmid: 12456066].
Khan MA, Hlatky MA, Liu MW, et al. Effect of postmenopausal hormone therapy on coronary heart disease events after percutaneous transluminal coronary angioplasty. Am J Cardiol. 2003;91(8):989-991. Exclusion code: 8. [pmid: 12686345].
Kirsh V, Kreiger N. Estrogen and estrogen-progestrin replacement therapy and risk of postmenopausal breast cancer in Canada. Cancer Causes Control. 2002;13:583-590. Exclusion code: 6. [pmid: 12195648].
Klein KP, Rapp SR. Women’s cognitive health: postmenopausal dementia and the Women’s Health Initiative memory study. Womens Health Issues. 2004;14(3):71-74. Exclusion code: 7. [pmid: 15193634].
Kloosterboer HJ, Ederveen AG. Pros and cons of existing treatment modalities in osteoporosis: a comparison between tibolone, SERMs and estrogen (+/− progestogen) treatments. J Steroid Biochem Mol Biol. 2003;83:157-165. Exclusion code: 7. [pmid: 12650712].
Kocoska-Maras L, Zethraeus N, Radestad AF, et al. A randomized trial of the effect of testosterone and estrogen on verbal fluency, verbal memory, and spatial ability in healthy postmenopausal women. Fertil Steril. 2011;95(1):152-157. Exclusion code: 4. [pmid: 20667535].
Koh KK. Effects of estrogen on the vascular wall: vasomotor function and inflammation. Cardiovasc Res. 2002;55(4):714-726. Exclusion code: 7. [pmid: 12176121].
Krikorian R, Welge J, Shidler M, et al. Estrogen therapy does not improve cognitive function in early menopause. Fertil Steril. 2003;80(3):S16-17. Exclusion code: 7. [pmid: 12831914].
Kurt M, Bekci B, Karakas S. Hormone replacement therapy and cognitive function in postmenopausal women. Maturitas. 2006;53(1):39-48. Exclusion code: 6. [pmid: 16325023].
La Vecchia C. Menopause, hormone therapy and breast cancer risk. Eur J Cancer Prev. 2003;12(5):437-438. Exclusion code: 7. [pmid: 14512811].
La Vecchia C, Gallus S, Fernandez E. Hormone replacement therapy and colorectal cancer: an update. J Br Menopause Soc. 2005;11(4):166-172. Exclusion code: 7. [pmid: 16354462].
Lacey JV Jr, Kreimer AR, Buys SS, et al. Breast cancer epidemiology according to recognized breast cancer risk factors in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial cohort. BMC Cancer. 2009;9:84. Exclusion code: 6. [pmid: 19292893].
Lacey JV Jr, Mink PJ, Lubin JH, et al. Menopausal hormone replacement therapy and risk of ovarian cancer. JAMA. 2002;288(3):334-341. Exclusion code: 6. [pmid: 12117398].
LaCroix AZ. Estrogen with and without progestin: benefits and risks of short-term use. Am J Med. 2005;118(Suppl 12B):79-87. Exclusion code: 7. [pmid: 16414331].
Lamon-Fava S, Herrington DM, Horvath KV, et al. Effect of hormone replacement therapy on plasma lipoprotein levels and coronary atherosclerosis progression in postmenopausal women according to type 2 diabetes mellitus status. Metabolism. 2010;59(12):1794-1800. Exclusion code: 11. [pmid: 20580029].
Landa MC. Role of hormone replacement therapy in the prevention and treatment of menopausal osteoporosis. An Sist Sanit Navar. 2003;26(Suppl 3):99-105. Exclusion code: 10. [pmid: 14716362].
Langer RD. Hormone replacement and the prevention of cardiovascular disease. Am J Cardiol. 2002;89(12A):36E-46E. Exclusion code: 7.
Lawlor DA, Smith GD. Cardiovascular risk and hormone replacement therapy. Curr Opin Obstet Gynecol. 2006;18(6):658-665. Exclusion code: 7. [pmid: 17099339].
LeBlanc ES. Hormone therapy with oestrogen or oestrogen plus progesterone decreases cognitive function in older postmenopausal women. Evid Based Healthcare Pub Health. 2004;8(6):398-401. Exclusion code: 7.
LeBlanc ES, Chan BK, Nelson HD. Hormone Replacement Therapy and Cognition. Agency for Healthcare Research and Quality. 2002. Exclusion code: 2.
LeBlanc ES, Janowsky J, Chan BK, Nelson HD. Hormone replacement therapy and cognition: systematic review and meta-analysis. JAMA. 2001;285(11):1489-1499. Exclusion code: 2. [pmid: 11255426].
Lee S, Kolonel L, Wilkens L, et al. Postmenopausal hormone therapy and breast cancer risk: the mulitethnic cohort. Int J Cancer. 2006;118(5):1285-1291. Exclusion code: 6. [pmid: 16170777].
Lemaitre RN, Heckbert SR, Psaty BM, et al. Hormone replacement therapy and associated risk of stroke in postmenopausal women. Arch Intern Med. 2002;162(17):1954-1960. Exclusion code: 6. [pmid: 12230417].
Lemaitre RN, Weiss NS, Smith NL, et al. Esterified estrogen and conjugated equine estrogen and the risk of incident myocardial infarction and stroke. Arch Intern Med. 2006;166(4):399-404. Exclusion code: 6. [pmid: 16505258].
Lethaby A, Hogervorst E, Richards M, et al. Hormone replacement therapy for cognitive function in postmenopausal women. Cochrane Database Syst Rev. 2008;(1). Exclusion code: 12.
Li CL, Malone KE, Porter PL, et al. Relationship between long durations and different regimens of hormone therapy and risk of breast cancer. JAMA. 2003;289(24):3254-3263. Exclusion code: 6. [pmid: 12824206].
Li WJ, Xu LZ, Liu HW, et al. Effects of Kuntai capsule and hormone replacement therapy on cognitive function and mental symptoms of early postmenopausal women: a randomized controlled trial. Chin J Integr Med. 2010;8(4):321-327. Exclusion code: 4.
Lindsay R. Hormone therapy and osteoporosis. Menopaus Med. 2003;11(2):1-4. Exclusion code: 7.
Lobo RA. Evaluation of cardiovascular event rates with hormone therapy in healthy, early postmenopausal women: results from 2 large clinical trials. Arch Intern Med. 2004;164(5):482-484. Exclusion code: 7. [pmid: 15006823].
Lokkegard E, Jovanovic Z, Heitmann BL, et al. Increased risk of stroke in hypertensive women using hormone therapy. Arch Neurol. 2003;60:1379-1384. Exclusion code: 6. [pmid: 14568807].
Low LF, Anstey KJ. Hormone replacement therapy and cognitive performance in postmenopausal women—a review by cognitive domain. Neurosci Biobehav Rev. 2006;30(1):66-84. Exclusion code: 7. [pmid: 16122800].
Lyytinen H, Pukkula E, Ylikorkala O. Breast cancer risk in postmenopausal women using estrogen-only therapy. Obstet Gynecol. 2006;108(6):1354-1360. Exclusion code: 6. [pmid: 17138766].
MacLennan A, Sturdee DW. The end of WISDOM. Climacteric. 2002;5:313-316. Exclusion code: 7. [pmid: 12626208].
Magee SR, Taylor JS. Hormone therapy in postmenopausal and perimenopausal women. Am Fam Physician. 2006;74(9):1501-1503. Exclusion code: 7. [pmid: 17111886].
Magliano DJ, Rogers SL, Abramson MJ, Tonkin AM. Hormone therapy and cardiovascular disease: a systematic review and meta-analysis. BJOG. 2006;113(1):5-14. Exclusion code: 12. [pmid: 16398764].
Maki PM. A systematic review of clinical trials of hormone therapy on cognitive function: effects of age at initiation and progestin use. Ann N Y Acad Sci. 2005;1052:182-197. Exclusion code: 12. [pmid: 16024761].
Maki PM. Hormone therapy and cognitive function: is there a critical period for benefit?. Neuroscience. 2006;138(3):1027-1030. Exclusion code: 7. [pmid: 16488547].
Maki PM, Sundermann E. Hormone therapy and cognitive function. Hum Reprod Update. 2009;15(6):667-681. Exclusion code: 2. [pmid: 19468050].
Manwaring P, Phoon S, Diamond T, Howes LG. Effects of hormone replacement therapy on cardiovascular responses in postmenopausal women with and without type 2 diabetes. Maturitas. 2002;43(3):157-164. Exclusion code: 11. [pmid: 12443833].
Marinho RM, Soares JM Jr, Santiago RC, et al. Effects of estradiol on the cognitive function of postmenopausal women. Maturitas. 2008;60(3–4):230-234. Exclusion code: 9. [pmid: 18775608].
Marsden J, A’Hern R, Whitehead M. More breast cancer findings from the Women’s Health Initiative. J Br Menopause Soc. 2003;9(3):97-99. Exclusion code: 7. [pmid: 14959718].
Merz CN, Olson MB, McClure C, et al. A randomized controlled trial of low-dose hormone therapy on myocardial ischemia in postmenopausal women with no obstructive coronary artery disease: results from the National Institutes of Health/National Heart, Lung, and Blood Institute-sponsored Women;s Ischemia Syndrome Evaluation (WISE). Am Heart J. 2010;159(6):987.e981-987. Exclusion code: 5. [pmid: 20569710].
Miller J, Chan BK, Nelson HD. Hormone Replacement Therapy and Risk of Venous Thromboembolism. Agency for Healthcare Research and Quality. 2002. Exclusion code: 2.
Miller J, Chan BK, Nelson HD. Postmenopausal estrogen replacement and risk for venous thromboembolism: a systematic review and meta-analysis for the U. S Preventive Services Task Force. Ann Intern Med. 2002;136(9):680-690. Exclusion code: 12. [pmid: 11992304].
Miller KJ, Conney JC, Rasgon NL, et al. Mood symptoms and cognitive performance in women estrogen users and nonusers and men. J Am Geriatr Soc. 2002;50(11):1826-1830. Exclusion code: 6. [pmid: 12410901].
Million Women Study Collaborators. Endometrial cancer and hormone-replacement therapy in the Million Women Study. Lancet. 2005;365:1543-1551. Exclusion code: 9. [pmid: 15866308].
Montgomery Rice V. Hormone replacement therapy: optimising the dose and route of administration. Drugs Aging. 2002;19(11):807-818. Exclusion code: 7. [pmid: 12428992].
Moorman PG, Schildkraut JM, Calingaert B, et al. Menopausal hormones and risk of ovarian cancer. Am J Obstet Gynecol. 2005;193:76-82. Exclusion code: 6. [pmid: 16021062].
Morch LS, Lokkegaard E, Andreasen AH, et al. Hormone therapy and ovarian cancer. JAMA. 2009;302:298-305. Exclusion code: 6. [pmid: 19602689].
Murkes D, Conner P, Leifland K, et al. Effects of percutaneous estradiol-oral progesterone versus oral conjugated equine estrogens-medroxyprogesterone acetate on breast cell proliferation and bcl-2 protein in healthy women. Fertil Steril. 2011;95(3):1188-1191. Exclusion code: 11. [pmid: 21067727].
Naftolin F, Schneider HP, Sturdee DW, et al. Guidelines for hormone treatment of women in the menopausal transition and beyond. Climacteric. 2004;7(4):333-337. Exclusion code: 7. [pmid: 15799604].
Nair GV, Chaput LA, Vittinghoff E, et al. Pulse pressure and cardiovascular events in postmenopausal women with coronary heart disease. Chest. 2005;127(5):1498-1506. Exclusion code: 5. [pmid: 15888820].
Nash HA, Alvarez-Sanchez F, Mishell DR, et al. Estradiol-delivering vaginal rings for hormone replacement therapy. Am J Obstet Gynecol. 1999;181:1400-1406. Exclusion code: 5. [pmid: 10601920].
Nelson HD. Assessing benefits and harms of hormone replacement therapy: clinical applications. JAMA. 2002;288(7):882-884. Exclusion code: 2. [pmid: 12186606].
Nelson HD. Hormone Replacement Therapy and Osteoporosis. Agency for Healthcare Research and Quality. 2002. Exclusion code: 2.
Nelson HD, Helfand M, Woolf SH, Allan JD. Screening for postmenopausal osteoporosis: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137:529-541. Exclusion code: 2. [pmid: 12230356].
Nelson HD, Humphrey LL, Nygren P, et al. Postmenopausal hormone replacement therapy: scientific review. JAMA. 2002;288(7):872-881. Exclusion code: 2. [pmid: 12186605].
Nelson HD, Rizzo J, Harris E, et al. Osteoporosis and fractures in postmenopausal women using estrogen. Arch Intern Med. 2002;162:2278-2284. Exclusion code: 6. [pmid: 12418942].
Newcomb P, Titus-Ernstoff L, Egan K, et al. Postmenopausal estrogen and progestin use in relation to breast cancer risk. Cancer Epidemiol Biomarkers Prev. 2002;11(7):593-600. Exclusion code: 6. [pmid: 12101105].
Noller KL. Estrogen replacement therapy and risk of ovarian cancer. JAMA. 2002;288(3):368-369. Exclusion code: 7. [pmid: 12117404].
Norbury R, Cutter WJ, Compton J, et al. The neuroprotective effects of estrogen on the aging brain. Exp Gerontol. 2003;38:109-117. Exclusion code: 7. [pmid: 12543268].
North American Menopause Society. Amended report from the NAMS Advisory Panel on Postmenopausal Hormone Therapy. Menopause. 2003;10(1):6-12. Exclusion code: 12. [pmid: 12544671].
North American Menopause Society. Role of progestogen in hormone therapy for postmenopausal women: position statement of the North American Menopause Society. Menopause. 2003;10(2):113-132. Exclusion code: 12. [pmid: 12627037].
North American Menopause Society. The role of testosterone therapy in postmenopausal women: position statement of the North American Menopause Society. Menopause. 2005;12(5):496-511. Exclusion code: 4. [pmid: 16145303].
North American Menopause Society. Estrogen and progestogen use in postmenopausal women: 2010 position statement of the North American Menopause Society. Menopause. 2010;17(2):242-255. Exclusion code: 2. [pmid: 20154637].
North American Menopause Society. Estrogen and progestogen use in peri- and postmenopausal women: September 2003 position statement of the North American Menopause Society. Menopause. 2003;10(6):497-506. Exclusion code: 12. [pmid: 14627857].
North American Menopause Society. Recommendations for estrogen and progestogen use in peri- and postmenopausal women: October 2004 position statement of the North American Menopause Society. Menopause. 2004;11(6):589-600. Exclusion code: 12. [pmid: 15545786].
North American Menopause Society. Estrogen and progestogen use in postmenopausal women: 2010 position statement of the North American Menopause Society. Menopause. 2010;17(2):242-255. Exclusion code: 2. [pmid: 20154637].
Oh JY, Barrett-Connor E, Wedick NM, Wingard DL. Endogenous sex hormones and the development of type 2 diabetes in older men and women: the Rancho Bernardo Study. Diabetes Care. 2002;25(1):55-60. Exclusion code: 6. [pmid: 11772901].
Olsson H, Ingvar C, Bladstrom A. Hormone replacement therapy containing progestins and given continuously increases breast carcinoma risk in Sweden. Cancer. 2003;97(6):1387-1392. Exclusion code: 6. [pmid: 12627501].
Pace DT. Menopause: studying the research. Nurse Pract. 2006;31(8):17-23. Exclusion code: 7. [pmid: 16966972].
Palacios S. Advances in hormone replacement therapy: making the menopause manageable. BMC Womens Health. 2008;8:22. Exclusion code: 7. [pmid: 19038018].
Pan HA, Wang ST, Pai MC, et al. Cognitive function variations in postmenopausal women treated with continuous, combined HRT or tibolone: a comparison. J Reprod Med. 2003;48(5):375-380. Exclusion code: 4. [pmid: 12815913].
Panay N. Hormone replacement therapy: the way forward. J Fam Plann Reprod Health Care. 2004;30(1):21-24. Exclusion code: 7. [pmid: 15006308].
Panay N. New products and regimens (since 2003). Climacteric. 2007;10(Suppl 2):109-114. Exclusion code: 7. [pmid: 17882685].
Panay N. Estrogen dose: the cardiovascular impact. Climacteric. 2009;12(Suppl 1):91-95. Exclusion code: 7. [pmid: 19811250].
Park A. Clarifying the hazards of HRT. Time. 2010;176(18):20. Exclusion code: 7.
Park BD, Lookinland S, Beckstrand RL, Chasson S. Factor V Leiden and venous thromboembolism: risk associated with hormone replacement therapy. J Am Acad Nurse Pract. 2003;15(10):458-466. Exclusion code: 7. [pmid: 14606135].
Parry BL, Meliska CJ, Martinez LF, et al. Menopause: neuroendocrine changes and hormone replacement therapy. J Am Med Womens Assoc. 2004;59(2):135-145. Exclusion code: 4. [pmid: 15134429].
Parsons E, Newby LK, Bhapkar MV, et al. Postmenopausal hormone use in women with acute coronary syndromes. J Womens Health. 2004;13(8):863-871. Exclusion code: 8.
Paschalis EP, Boskey AL, Kassem M, Eriksen EF. Effect of hormone replacement therapy on bone quality in early postmenopausal women. J Bone Miner Res. 2003;18(6):955-959. Exclusion code: 11. [pmid: 12817747].
Pedersen AT, Ottesen B. Issues to debate on the Women’s Health Initiative (WHI) study: epidemiology or randomized clinical trials—time out for hormone replacement therapy studies?. Human Reproduction. 2003;18(11):2241-2244. Exclusion code: 7. [pmid: 14585866].
Peeyananjarassri K, Baber R. Effects of low-dose hormone therapy on menopausal symptoms, bone mineral density, endometrium, and the cardiovascular system: a review of randomized clinical trials. Climacteric. 2005;8(1):13-23. Exclusion code: 11. [pmid: 15804728].
Pefanco MA, Kenny AM, Kaplan RF, et al. The effect of 3-year treatment with 0.25 mg/day of micronized 17β-estradiol on cognitive function in older postmenopausal women. J Am Geriatr Soc. 2007;55(3):426-431. Exclusion code: 14. [pmid: 17341247].
Peiris A, Iskandar S. Hormone replacement therapy and lipids: time to reconsider our options?. South Med J. 2002;95(9):961-963. Exclusion code: 7. [pmid: 12356134].
Penckofer SM, Hackbarth D, Schwertz DW. Estrogen plus progestin therapy: the cardiovascular risks exceed the benefits. J Cardiovasc Nurs. 2003;18(5):347-355. Exclusion code: 7. [pmid: 14680337].
Perez-Lopez FR, Chedraui P, Gilbert JJ, Perez-Roncero G. Cardiovascular risk in menopausal women and prevalent related co-morbid conditions: facing the post-Women’s Health Initiative era. Fertil Steril. 2009;92(4):1171-1186. Exclusion code: 7. [pmid: 19700149].
Perrotta C, Aznar M, Mejia R, et al. Oestrogens for preventing recurrent urinary tract infection in postmenopausal women. Cochrane Database Syst Rev. 2009;(1). Exclusion code: 8.
Persad CC, Zubieta JK, Love T, et al. Enhanced neuroactivation during verbal memory processing in postmenopausal women receiving short-term hormone therapy. Fertil Sterility. 2009;92(1):197-204. Exclusion code: 11.
Petitti D, Buckwalter JG, Crooks VC, Chiu V. Prevelance of dementia in users of hormone replacement therapy as defined by prescription data. J Gerontol. 2002;57A(8):M532-538. Exclusion code: 6.
Peverill RE. Hormone therapy and venous thromboembolism. Baillieres Best Pract Res Clin Endocrinol Metab. 2003;17:149-164. Exclusion code: 7.
Phillips LS, Langer RD. Postmenopausal hormone therapy: critical reappraisal and a unified hypothesis. Fertil Steril. 2005;83(3):558-566. Exclusion code: 7. [pmid: 15749481].
Pickar JH, Yeh I, Wheeler JE, et al. Endometrial effects of lower doses of conjugated equine estrogens and medroxyprogesterone acetate. Fertil Steril. 2001;76(1):25-31. Exclusion code: 11. [pmid: 11438315].
Pickar JH, Yeh IT, Wheeler JE, et al. Endometrial effects of lower doses of conjugated equine estrogens and medroxyprogesterone acetate: two-year substudy results. Fertil Steril. 2003;80(5):1234-1240. Exclusion code: 9. [pmid: 14607581].
Pines A. WHI and aftermath: looking beyond the figures. Maturitas. 2005;51(1):48-50. Exclusion code: 7. [pmid: 15883109].
Pines A, Sturdee DW, Birkhaeuser MH, et al. IMS updated recommendations on postmenopausal hormone therapy. Climacteric. 2007;10:181-194. Exclusion code: 2. [pmid: 17487645].
Pines A, Sturdee DW, Birkhauser M. International Menopause Society. More data on hormone therapy and coronary artery disease: comments on recent publications from the WHI and Nurses’ Study. Climacteric. 2006;9(2):75-76. Exclusion code: 7. [pmid: 16715592].
Pines A, Sturdee DW, Birkhauser MH, et al. HRT in the early menopause: scientific evidence and common perceptions. Climacteric. 2008;11(4):267-272. Exclusion code: 7. [pmid: 18645691].
Pines A, Sturdee DW, Birkhauser MH. International Menopause Society. Hormone therapy and cardiovascular disease in the early postmenopause: the WHI data revisited. Climacteric. 2007;10(3):195-196. Exclusion code: 7. [pmid: 17487646].
Pinkerton JV, Henderson VW. Estrogen and cognition, with a focus on Alzheimer’s disease. Semin Reprod Med. 2005;23(2):172-179. Exclusion code: 7. [pmid: 15852203].
Pinkerton JV, Santen R. Use of alternatives to estrogen for treatment of menopause. Minerva Endocrinol. 2002;27(1):21-41. Exclusion code: 7. [pmid: 11845111].
Pitkin J, Rees MC, Gray S, et al. Managing the menopause: BMS Council Consensus statement on HRT. J Br Menopause Soc. 2004;10(1):33-36. Exclusion code: 7. [pmid: 15107210].
Pitkin J, Rees MC, Gray S, et al. Managing the menopause: British Menopause Society Council consensus statement on hormone replacement therapy. J Br Menopause Soc. 2005;11(4):152-156. Exclusion code: 7. [pmid: 16354459].
Pitkin J, Rees MC, Gray S, et al. Management of premature menopause. Menopause Int. 2007;13(1):44-45. Exclusion code: 7. [pmid: 17448268].
Pitkin J, Rees MC, Gray S, et al. Managing the menopause: British Menopause Society Council consensus statement on hormone replacement therapy. J Br Menopause Soc. 2003;9(3):129-131. Exclusion code: 7. [pmid: 14670199].
Plonczynski DJ, Plonczynski KJ. Hormone therapy in perimenopausal and postmenopausal women: examining the evidence on cardiovascular disease risks. J Gerontol Nurs. 2007;33(5):48-55. Exclusion code: 7. [pmid: 17511335].
Poirier-Solomon L. HRT: findings from the Women’s Health Initiative. Diabetes Forecast. 2002;55(12):34-36. Exclusion code: 7. [pmid: 14768617].
Ponzone R, Sismondi P. Selected highlights from the 27th San Antonio Breast Cancer Symposium. San Antonio, TX, USA. 8–11 December 2004. Expert Opin Pharmacother. 2005;6(7):1257-1267. Exclusion code: 7.
Popp AW, Bodmer C, Senn C, et al. Prevention of postmenopausal bone loss with long-cycle hormone replacement therapy. Maturitas. 2006;53(2):191-200. Exclusion code: 11. [pmid: 16368472].
Porch JV, Lee IM, Cook NR, et al. Estrogen-progestin replacement therapy and breast cancer risk: the Women’s Health Study (United States). Cancer Causes Control. 2002;13(9):847-854. Exclusion code: 6. [pmid: 12462550].
Practice Committee of the American Society for Reproductive Medicine. Estrogen and progestogen therapy in postmenopausal women. Fertil Steril. 2006;86(5 Suppl 1):S75-88. Exclusion code: 7. [pmid: 17055850].
Prelevic GM, Kocjan T, Markou A. Hormone replacement therapy in postmenopausal women. Minerva Endocrinol. 2005;30(1):27-36. Exclusion code: 7. [pmid: 15877011].
Prentice LL, Abramson MJ, Cicuttini FF, Wluka AA. Hormone replacement therapy for osteoarthritis in peri-menopausal and post-menopausal women. Cochrane Database Syst Rev. 2009;(1). Exclusion code: 7.
Prentice RL, Anderson GL. The Women’s Health Initiative: lessons learned. Annu Rev Public Health. 2008;29:131-150. Exclusion code: 7. [pmid: 18348708].
Prentice RL, Chlebowski RT, Stefanick ML, et al. Conjugated equine estrogens and breast cancer risk in the Women’s Health Initiative clinical trial and observational study. Am J Epidemiol. 2008;167(12):1407-1415. Exclusion code: 2. [pmid: 18448442].
Prentice RL, Chlebowski RT, Stefanick ML, et al. Estrogen plus progestin therapy and breast cancer in recently postmenopausal women. Am J Epidemiol. 2008;167(10):1207-1216. Exclusion code: 2. [pmid: 18372396].
Prentice RL, Langer R, Stefanick ML, et al. Combined postmenopausal hormone therapy and cardiovascular disease: toward resolving the discrepancy between observational studies and the Women’s Health Initiative clinical trial. Am J Epidemiol. 2005;162(5):404-414. Exclusion code: 2. [pmid: 16033876].
Prentice RL, Langer RD, Stefanick ML, et al. Combined analysis of Women’s Health Initiative observational and clinical trial data on postmenopausal hormone treatment and cardiovascular disease. Am J Epidemiol. 2006;163(7):589-599. Exclusion code: 2. [pmid: 16484450].
Prentice RL, Manson JE, Langer RD, et al. Benefits and risks of postmenopausal hormone therapy when it is initiated soon after menopause. Am J Epidemiol. 2009;170(1):12-23. Exclusion code: 2. [pmid: 19468079].
Prentice RL, Pettinger M, Anderson GL. Statistical issues arising in the Women’s Health Initiative. Biometrics. 2005;61(4):899-911. Exclusion code: 7. [pmid: 16401257].
Prentice RL, Pettinger M, Beresford SA, et al. Colorectal cancer in relation to postmenopausal estrogen and estrogen plus progestin in the Women’s Health Initiative clinical trial and observational study. Cancer Epidemiol Biomarkers Prev. 2009;18(5):1531-1537. Exclusion code: 2. [pmid: 19423530].
Prestwood KM, Kenny AM, Kleppinger A, Kulldorff M. Ultralow-dose micronized 17β-estradiol and bone density and bone metabolism in older women: a randomized controlled trial. JAMA. 2003;290(8):1042-1048. Exclusion code: 11. [pmid: 12941676].
Prisant LM. Preventing type II diabetes mellitus. J Clin Pharmacol. 2004;44(4):406-413. Exclusion code: 7. [pmid: 15051749].
Rabadi MH, Blass J. Randomized clinical stroke trials in 2003. Curr Atheroscler Rep. 2004;6(4):257-260. Exclusion code: 7. [pmid: 15191698].
Rabadi MH, Blass J. Randomized clinical stroke trials in 2004. Curr Atheroscler Rep. 2005;7(4):319-325. Exclusion code: 7. [pmid: 15975326].
Rachon D, Teede H. Postmenopausal hormone therapy and the risk of venous thromboembolism. Climacteric. 2008;11(4):273-279. Exclusion code: 7. [pmid: 18645692].
Randolph JF Jr. Women’s Health Initiative Estrogen/Progestin and HERS II Trials. Be careful of what you wish for: putting the WHI estrogen/progestin and HERS II trials in perspective. Medscape Womens Health. 2002;7(4):7. Exclusion code: 7. [pmid: 12466739].
Rasgon Natalie L, Dunkin J, Altshuler Lori L, Rapkin A. Estrogen-replacement therapy: cognition and depression in postmenopausal women. 155th Annual Meeting of the American Psychiatric Association. 2002. Exclusion code: 7.
Rasgon NL, Dunkin J, Altshuler LL, Rapkin A. Estrogen-replacement therapy: cognition and depression in postmenopausal women. 153rd Annual Meeting of the American Psychiatric Association. 2000. Exclusion code: 7.
Reed SD, Newton KM, Lacroix AZ. Indications for hormone therapy: the post-Women’s Health Initiative era. Endocrinol Metab Clin North Am. 2004;33(4):691-715. Exclusion code: 7. [pmid: 15501641].
Rees M, Stevenson J. British Menopause Society Council. Primary prevention of coronary heart disease in women. Menopause Int. 2008;14(1):40-45. Exclusion code: 7. [pmid: 18380961].
Reid RL. Hormone therapy: the Women’s Health Initiative has caused confusion and concern. Fertil Steril. 2003;80(3):491-493. Exclusion code: 7. [pmid: 12969684].
Resnick SM, Coker LH, Maki PM, et al. The Women’s Health Initiative Study of Cognitive Aging (WHISCA): a randomized clinical trial of the effects of hormone therapy on age-associated cognitive decline. Clinical Trials. 2004;1(5):440-450. Exclusion code: 7. [pmid: 16279282].
Resnick SM, Espeland MA, Jaramillo SA, et al. Postmenopausal hormone therapy and regional brain volumes: the WHIMS-MRI Study. Neurology. 2009;72(2):135-142. Exclusion code: 11. [pmid: 19139364].
Resnick SM, Henderson VW. Hormone therapy and risk of Alzheimer disease. JAMA. 2002;288:2170-2172. Exclusion code: 7. [pmid: 12413378].
Resnick SM, Pham DL, Kraut MA, et al. Longitudinal magnetic resonance imaging studies of older aldults: a shrinking brain. J Neuroscience. 2003;23(8):3295-3301. Exclusion code: 11.
Richman S, Edusa V, Fadiel A, Naftolin F. Low-dose estrogen therapy for prevention of osteoporosis: working our way back to monotherapy. Menopause. 2006;13(1):148-155. Exclusion code: 7. [pmid: 16607111].
Riman T, Dickman PW, Nilsson S, et al. Hormone replacement therapy and the risk of invasive epithelial ovarian cancer in swedish women. J Natl Cancer Inst. 2002;94(7):497-504. Exclusion code: 6. [pmid: 11929950].
Rivera R, Gousse A. Does postmenopausal hormone therapy cause urinary incontinence?. Nat Clin Pract Urol. 2006;3(6):304-305. Exclusion code: 7. [pmid: 16763639].
Rizzoli R. Osteoporosis: non-hormonal treatment. Climacteric. 2007;10(Suppl 2):74-78. Exclusion code: 7. [pmid: 17882678].
Roberts H, Lethaby A. Revised key messages for hormone replacement therapy from the New Zealand Guidelines Group. Aust N Z J Obstet Gynaecol. 2003;43(4):273-279. Exclusion code: 2. [pmid: 14714711].
Roberts SS. What your doctor is reading: hormone replacement therapy. Diabetes Self Manag. 2002;19(6):78-81. Exclusion code: 7. [pmid: 12561772].
Romero A, Alonso C, Rincon M, et al. Risk of venous thromboembolic disease in women: a qualitative systematic review. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):8-17. Exclusion code: 7. [pmid: 15950363].
Rosano G, Fini M. Postmenopausal women and cardiovascular risk: impact of hormone replacement therapy. Cardiol Rev. 2002;10:51-60. Exclusion code: 9. [pmid: 11790270].
Rosano GM, Maffei S, Andreassi MG, et al. Hormone replacement therapy and cardioprotection: a new dawn? A statement of the Study Group on Cardiovascular Disease in Women of the Italian Society of Cardiology on hormone replacement therapy in postmenopausal women. J Cardiovasc Med. 2009;10(1):85-92. Exclusion code: 7.
Rosano GM, Vitale C, Fini M. Hormone replacement therapy and cardioprotection: what is good and what is bad for the cardiovascular system?. Ann N Y Acad Sci. 2006;1092:341-348. Exclusion code: 7. [pmid: 17308159].
Rosano GM, Vitale C, Lello S. Postmenopausal hormone therapy: lessons from observational and randomized studies. Endocrine. 2004;24(3):251-254. Exclusion code: 7. [pmid: 15542893].
Rosano GM, Vitale C, Silvestri A, Fini M. Hormone replacement therapy and cardioprotection: the end of the tale?. Ann N Y Acad Sci. 2003;997:351-357. Exclusion code: 7. [pmid: 14644842].
Rosenberg L, Hoffman M. Hormone replacement therapy—finally, good data. S Afr Med J. 2004;94(1):26-27. Exclusion code: 7. [pmid: 14971225].
Rossing MA, Cushing-Haugen KL, Wicklund KG, et al. Menopausal hormone therapy and risk of epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2007;16:2548-2556. Exclusion code: 6. [pmid: 18086757].
Rossouw JE. Effect of postmenopausal hormone therapy on cardiovascular risk. J Hypertension. 2002;20(Suppl 2):62-65. Exclusion code: 7.
Rossouw JE. Coronary heart disease in menopausal women: implications of primary and secondary prevention trials of hormones. Maturitas. 2005;51(1):51-63. Exclusion code: 7. [pmid: 15883110].
Rossouw JE. Implications of recent clinical trials of postmenopausal hormone therapy for management of cardiovascular disease. Ann N Y Acad Sci. 2006;1089:444-453. Exclusion code: 7. [pmid: 17261787].
Rousseau ME. Hormone replacement therapy: short-term versus long-term use. J Midwifery Womens Health. 2002;47(6):461-470. Exclusion code: 7. [pmid: 12484668].
Ryan J, Scali J, Carriere I, et al. Hormonal treatment, mild cognitive impairment and Alzheimer’s disease. Int Psychogeriatr. 2008;20(1):47-56. Exclusion code: 7. [pmid: 18072983].
Sakuma I, Kitabatake A. Menopause and cardiovascular diseases in women. Intern Med. 2004;43(2):151-154. Exclusion code: 7. [pmid: 15005262].
Saletu B. Sleep, vigilance and cognition in postmenopausal women: placebo-controlled studies with 2 mg estradiol valerate, with and without 3 mg dienogest. Climacteric. 2003;6(Suppl 2):37-45. Exclusion code: 13. [pmid: 14669843].
Salpeter SR, Walsh JM, Greyber E, et al. Mortality associated with hormone replacement therapy in younger and older women: a meta-analysis. J Gen Intern Med. 2004;19(7):791-804. Exclusion code: 9. [pmid: 15209595].
Salpeter SR, Walsh JM, Greyber E, Salpeter EE. Brief report: coronary heart disease events associated with hormone therapy in younger and older women. A meta-analysis. J Gen Intern Med. 2006;21(4):363-366. Exclusion code: 12. [pmid: 16686814].
Sammartino A, Cirillo D, Mandato VD, et al. Osteoporosis and cardiovascular disease: benefit-risk of hormone replacement therapy. J Endocrinol Invest. 2005;28(10 Suppl):80-84. Exclusion code: 7. [pmid: 16550729].
Samsioe G. HRT and cardiovascular disease. Ann N Y Acad Sci. 2003;997:358-372. Exclusion code: 7. [pmid: 14644843].
Sano M, Jacobs D, Andrews H, et al. A multi-center, randomized, double blind placebo-controlled trial of estrogens to prevent Alzheimer’s disease and loss of memory in women: design and baseline characteristics. Clinical Trials. 2008;5(5):523-533. Exclusion code: 7. [pmid: 18827045].
Santen RJ. Risk of breast cancer with progestins: critical assessment of current data. Steroids. 2003;68(10–13):953-964. Exclusion code: 4. [pmid: 14667988].
Santen RJ, Allred DC, Ardoin SP, et al. Postmenopausal hormone therapy: an Endocrine Society scientific statement. J Clin Endocrinol Metab. 2010;95(7 Suppl 1):s1-s66. Exclusion code: 2. [pmid: 20566620].
Sare GM, Gray LJ, Bath PM. Association between hormone replacement therapy and subsequent arterial and venous vascular events: a meta-analysis. Eur Heart J. 2008;29(16):2031-2041. Exclusion code: 12. [pmid: 18599555].
Scalco MZ, van Reekum R. Prevention of Alzheimer disease: encouraging evidence. Can Fam Physician. 2006;52:200-207. Exclusion code: 7. [pmid: 16529393].
Scarabin PY, Oger E, Plu-Bureau G. Differential association of oral and transdermal oestrogen-replacement therapy with venous thromboembolism risk. Lancet. 2003;362(9382):428-432. Exclusion code: 6. [pmid: 12927428].
Schenck-Gustafsson K, Brincat M, Erel CT, et al. EMAS position statement: managing the menopause in the context of coronary heart disease. Maturitas. 2011;68(1):94-97. Exclusion code: 7. [pmid: 21156341].
Schiff R, Bulpitt CJ, Wesnes KA, Rajkumar C. Short-term transdermal estradiol therapy, cognition and depressive symptoms in healthy older women: a randomised placebo controlled pilot cross-over study. Psychoneuroendocrinology. 2005;30(4):309-315. Exclusion code: 13. [pmid: 15694110].
Schnatz PF. Hormonal therapy: does it increase or decrease cardiovascular risk?. Obstet Gynecol Surv. 2006;61(10):673-681. Exclusion code: 7. [pmid: 16978427].
Seeger H, Mueck AO. Are the progestins responsible for breast cancer risk during hormone therapy in the postmenopause? Experimental vs. clinical data. J Steroid Biochem Mol Biol. 2008;109(1–2):11-15. Exclusion code: 4. [pmid: 18206365].
Seifert-Klauss V, Kingwell E, Hitchcock CL, et al. Estrogen and progestogen use in peri- and postmenopausal women: March 2007 position statement of the North American Menopause Society. Menopause. 2008;15(1):203-205. Exclusion code: 7. [pmid: 18182940].
Seitzman RL, Mangione C, Ensrud KE, et al. Postmenopausal hormone therapy and age-related maculopathy in older women. Ophthalmic Epidemiology. 2008;15:308-316. Exclusion code: 6. [pmid: 18850467].
Selby P. Postmenopausal osteoporosis. Curr. 2004;2(3):101-106. Exclusion code: 7.
Serock MR, Wells AK, Khalil RA. Modulators of vascular sex hormone receptors and their effects in estrogen-deficiency states associated with menopause. Recent Patents Cardiovasc Drug Discov. 2008;3(3):165-186. Exclusion code: 7.
Shah NR, Borenstein J, Dubois RW. Postmenopausal hormone therapy and breast cancer: a systematic review and meta-analysis. Menopause. 2005;12(6):668-678. Exclusion code: 9. [pmid: 16278609].
Shapiro S. Risks of estrogen plus progestin therapy: a sensitivity analysis of findings in the Women’s Health Initiative randomized controlled trial. Climacteric. 2003;6(4):302-310. Exclusion code: 2. [pmid: 15006251].
Shapiro S. The Million Women Study: potential biases do not allow uncritical acceptance of the data. Climacteric. 2004;7(1):3-7. Exclusion code: 7. [pmid: 15259277].
Shapiro S. Risk of cardiovascular disease in relation to the use of combined postmenopausal hormone therapy: detection bias and resolution of discrepant findings in two Women’s Health Initiative studies. Climacteric. 2006;9(6):416-420. Exclusion code: 7. [pmid: 17085373].
Shapiro S. Recent epidemiological evidence relevant to the clinical management of the menopause. Climacteric. 2007;10(Suppl 2):2-15. Exclusion code: 7. [pmid: 17882666].
Shapiro S. Oral contraceptives, hormone therapy and cardiovascular risk. Climacteric. 2008;11(5):355-363. Exclusion code: 7. [pmid: 18781479].
Sharma S. Hormone replacement therapy in menopause: current concerns and considerations. Kathmandu Univ. 2003;1(4):288-293. Exclusion code: 7.
Shaywitz SE, Naftolin F, Zelterman D, et al. Better oral reading and short-term memory in midlife, postmenopausal women taking estrogen. Menopause. 2003;10(5):420-426. Exclusion code: 13. [pmid: 14501603].
Sherman AM, Shumaker SA, Sharp P, et al. No effect of HRT on health-related quality of life in postmenopausal women with heart disease. Minerva Ginecol. 2003;55(6):511-517. Exclusion code: 3. [pmid: 14676740].
Sherwin BB. Estrogen and cognitive functioning in women. Endocr Rev. 2003;24:133-151. Exclusion code: 7. [pmid: 12700177].
Sherwin BB. Estrogen and memory in women: how can we reconcile the findings?. Horm Behav. 2005;47(3):371-375. Exclusion code: 7. [pmid: 15708768].
Sherwin BB. Surgical menopause, estrogen, and cognitive function in women: what do the findings tell us?. Ann N Y Acad Sci. 2005;1052:3-10. Exclusion code: 7. [pmid: 16024746].
Sherwin BB. Estrogen and cognitive aging in women. Neuroscience. 2006;138(3):1021-1026. Exclusion code: 7. [pmid: 16310965].
Sherwin BB. The critical period hypothesis: can it explain discrepancies in the oestrogen-cognition literature?. J Neuroendocrinol. 2007;19(2):77-81. Exclusion code: 7. [pmid: 17214869].
Sherwin BB. Estrogen therapy: is time of initiation critical for neuroprotection?. Nat Rev Endocrinol. 2009;5(11):620-627. Exclusion code: 7. [pmid: 19844249].
Sherwin BB, Henry JF. Brain aging modulates the neuroprotective effects of estrogen on selective aspects of cognition in women: a critical review. Front Neuroendocrinol. 2008;29(1):88-113. Exclusion code: 7. [pmid: 17980408].
Shulman LP. The menopausal transition: how does route of delivery affect the risk/benefit ratio of hormone therapy?. J Fam Pract. Suppl. 2004:S13-17. Exclusion code: 7. [pmid: 15251108].
Shulman LP. Transdermal hormone therapy and bone health. Clin Interv Aging. 2008;3(1):51-54. Exclusion code: 7. [pmid: 18488878].
Shumaker S, Reboussin BA, Espeland MA, et al. The Women’s Health Initiative Memory Study (WHIMS): a trial of the effect of estrogen therapy in preventing and slowing the progression of dementia. Control Clin Trials. 1998;19:604-621. Exclusion code: 2. [pmid: 9875839].
Siddiqui NI, Rahman S, Mia AR, Shamsuzzaman AK. Evaluation of hormone replacement therapy. Mymensingh Med J. 2005;14(2):212-218. Exclusion code: 7. [pmid: 16056216].
Simon JA. Postmenopausal hormone therapy: risks versus benefits reassessed. Nat Rev Endocrinol. 2010;6(12):661-663. Exclusion code: 7. [pmid: 21102647].
Simon JA, Nahum GG, Stanislaw H, Gaines T. The breast cancer “plunge” after initial publication of the WHI results: an alternative explanation. Maturitas. 2010;66(3):277-284. Exclusion code: 7. [pmid: 20471761].
Simon JA, Snabes MC. Menopausal hormone therapy for vasomotor symptoms: balancing the risks and benefits with ultra-low doses of estrogen. Expert Opin Investig Drugs. 2007;16(12):2005-2020. Exclusion code: 7.
Simon JA, Wehren LE, Ascott-Evans BH, et al. Skeletal consequences of hormone therapy discontinuance: a systematic review. Obstet Gynecol Surv. 2006;61(2):115-124. Exclusion code: 11. [pmid: 16433935].
Sitruk-Ware R. New hormonal therapies and regimens in the postmenopause: routes of administration and timing of initiation. Climacteric. 2007;10(5):358-370. Exclusion code: 7. [pmid: 17852138].
Skouby SO, Al-Azzawi F, Barlow D, et al. Climacteric medicine: European Menopause and Andropause Society (EMAS) 2004/2005 position statements on peri- and postmenopausal hormone replacement therapy. Maturitas. 2005;51(1):8-14. Exclusion code: 2. [pmid: 15883103].
Skouby SO, Barlow D, Samsioe G, et al. Climacteric medicine: European Menopause and Andropause Society (EMAS) statements on postmenopausal hormonal therapy. Maturitas. 2004;48(1):19-25. Exclusion code: 12. [pmid: 15223104].
Skouby SO, Jespersen J. Progestins in HRT: sufferance or desire?. Maturitas. 2009;62(4):371-375. Exclusion code: 4. [pmid: 19203850].
Skouby SO, Jespersen J, Kluft C, et al. On the route to combined evidence from OC and HRT/ERT. Eur J Contracept Reprod Health Care. 2002;7(4):185-198. Exclusion code: 7. [pmid: 12656302].
Smith JD, Chakrabarti E, Levin-Allerhand JA. Drug discovery: estrogen-related compounds in mouse models of Alzheimer’s disease. J Mol Neurosci. 2004;24(1):145-147. Exclusion code: 7. [pmid: 15314263].
Smith NL, Heckbert SR, Lemaitre RN, et al. Esterified estrogens and conjugated equine estrogens and the risk of venous thrombosis. JAMA. 2004;292(13):1581-1587. Exclusion code: 6. [pmid: 15467060].
Smith YR, Love T, Persad CC, et al. Impact of combined estradiol and norethindrone therapy on visuospatial working memory assessed by functional magnetic resonance imaging. J Clin Endocrinol Metab. 2006;91(11):4476-4481. Exclusion code: 11. [pmid: 16912129].
Snow KK, Cote J, Yang W, et al. Association between reproductive and hormonal factors and age-related maculopathy in postmenopausal women. Am J Ophthalmol. 2002;134:842-848. Exclusion code: 6. [pmid: 12470752].
Sohrabji F. Estrogen: a neuroprotective or proinflammatory hormone? Emerging evidence from reproductive aging models. Ann N Y Acad Sci. 2005;1052:75-90. Exclusion code: 3. [pmid: 16024752].
Speroff L. The Million Women Study and breast cancer. Maturitas. 2003;46(1):1-6. Exclusion code: 7. [pmid: 12963165].
Speroff L. Postmenopausal hormone therapy and breast cancer: a clinician’s message for patients. Endocrine. 2004;24(3):211-216. Exclusion code: 7. [pmid: 15542887].
Speroff L. A clinician’s review of the WHI-related literature. Int J Fertil Womens Med. 2004;49(6):252-267. Exclusion code: 7. [pmid: 15751264].
Speroff L. Postmenopausal hormone therapy and the risk of breast cancer: a clinician’s view. Maturitas. 2004;49(1):51-57. Exclusion code: 7. [pmid: 15351096].
Speroff L. The future of postmenopausal hormone therapy: it’s time to move forward. Maturitas. 2007;57(1):103-106. Exclusion code: 7. [pmid: 17368975].
Speroff L. Transdermal hormone therapy and the risk of stroke and venous thrombosis. Climacteric. 2010;13(5):429-432. Exclusion code: 7. [pmid: 20670199].
Srinivasan KN, Satyamurthy I. Coronary artery disease in women. J Assoc Physicians India. 2002;50:259-264. Exclusion code: 7. [pmid: 12038659].
Standridge JB. Pharmacotherapeutic approaches to the prevention of Alzheimer’s disease. Am J Geriatr Pharmacother. 2004;2(2):119-132. Exclusion code: 7. [pmid: 15555488].
Staren ED, Omer S. Hormone replacement therapy in postmenopausal women. Am J Surg. 2004;188(2):136-149. Exclusion code: 7. [pmid: 15249239].
Stefanick ML. Estrogens and progestins: background and history, trends in use, and guidelines and regimes approved by the US Food and Drug Administration. Am J Med. 2005;118(12B):64S-73S. Exclusion code: 2.
Stefanick ML. Postmenopausal hormone therapy and cardiovascular disease in women. Nutr Metab Cardiovasc Dis. 2010;20(6):451-458. Exclusion code: 7. [pmid: 20554177].
Stefanick ML, Anderson GL, Margolis KL, et al. Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA. 2006;295(14):1647-1657. Exclusion code: 12. [pmid: 16609086].
Stefanick ML, Cochrane B, Hsia J, et al. The Women’s Health Initiative postmenopausal hormone trials: overview and baseline characteristics of participants. Ann Epidemiol. 2003;13(9 Suppl 1):S78-86. Exclusion code: 2. [pmid: 14575940].
Stevens MC, Clark VP, Prestwood KM. Low-dose estradiol alters brain activity. Psychiatry Res. 2005;139(3):199-217. Exclusion code: 14. [pmid: 16084069].
Stevenson J. Long term effects of hormone replacement therapy. Lancet. 2003;361(9353):253-254. Exclusion code: 7. [pmid: 12547556].
Stevenson JC. The metabolic basis for the effects of HRT on coronary heart disease. Endocrine. 2004;24(3):239-244. Exclusion code: 7. [pmid: 15542891].
Stevenson JC. Hormone replacement therapy: review, update, and remaining questions after the Women’s Health Initiative Study. Curr. 2004;2(1):12-16. Exclusion code: 7.
Stevenson JC. HRT and the primary prevention of cardiovascular disease. Maturitas. 2007;57(1):31-34. Exclusion code: 7. [pmid: 17383835].
Stevenson JC. HRT and cardiovascular disease. Best Pract Res Clin Obstet Gynaecol. 2009;23(1):109-120. Exclusion code: 7. [pmid: 19095500].
Stevenson JC, Hodis HN, Pickar JH, Lobo RA. Coronary heart disease and menopause management: the swinging pendulum of HRT. Atherosclerosis. 2009;207(2):336-340. Exclusion code: 7. [pmid: 19560146].
Stevenson M, Jones ML, De Nigris E, et al. A systematic review and economic evaluation of alendronate, etidronate, risedronate, raloxifene and teriparatide for the prevention and treatment of postmenopausal osteoporosis. Health Technol Assess. 2005;9(22):1-160. Exclusion code: 4. [pmid: 15929857].
Stovall DW, Pinkerton JV. Estrogen agonists/antagonists in combination with estrogen for prevention and treatment of menopause-associated signs and symptoms. Womens Health. 2008;4(3):257-268. Exclusion code: 4.
Stramba-Badiale M. Postmenopausal hormone therapy and the risk of cardiovascular disease. J Cardiovasc Med. 2009;10(4):303-309. Exclusion code: 7.
Strandberg TE, Ylikorkala O, Tikkanen MJ. Differing effects of oral and transdermal hormone replacement therapy on cardiovascular risk factors in healthy postmenopausal women. Am J Cardiol. 2003;92(2):212-214. Exclusion code: 11. [pmid: 12860228].
Strickler RC. Women’s Health Initiative results: a glass more empty than full. Fertil Steril. 2003;80(3):488-490. Exclusion code: 7. [pmid: 12969683].
Tan O, Harman SM, Naftolin F. What can we learn from design faults in the Women’s Health Initiative randomized clinical trial?. Bull NYU Hosp Jt Dis. 2009;67(2):226-229. Exclusion code: 7. [pmid: 19583558].
Tannen RL, Weiner MG, Xie D, Barnhart K. A simulation using data from a primary care practice database closely replicated the Women’s Health Initiative trial. J Clin Epidemiol. 2007;60(7):686-695. Exclusion code: 6. [pmid: 17573984].
Tannen RL, Weiner MG, Xie D, Barnhart K. Perspectives on hormone replacement therapy: the Women’s Health Initiative and new observational studies sampling the overall population. Fertil Steril. 2008;90(2):258-264. Exclusion code: 7. [pmid: 18672122].
Tansavatdi K, McClain B, Herrington DM. The effects of smoking on estradiol metabolism. Minerva Ginecol. 2004;56(1):105-114. Exclusion code: 7. [pmid: 14973414].
Taylor HS, Manson JE. Update in hormone therapy use in menopause. J Clin Endocrinol Metab. 2011;96(2):255-264. Exclusion code: 7. [pmid: 21296989].
Teede H. Hormone replacement therapy and the prevention of cardiovascular disease. Hum Reprod Update. 2002;8:201-215. Exclusion code: 6. [pmid: 12078832].
Teede HJ. Controversies in HRT. Aust Fam Physician. 2002;31(5):413-418. Exclusion code: 7. [pmid: 12043543].
Teede HJ. The menopause and HRT: hormone replacement therapy, cardiovascular and cerebrovascular disease. Baillieres Best Pract Res Clin Endocrinol Metab. 2003;17(1):73-90. Exclusion code: 7.
Theroux R. Postmenopausal hormone use: what does the latest evidence show?. Nurs Womens Health. 2008;12(1):56-61. Exclusion code: 7. [pmid: 18257887].
Thomas LH, Barrett J, Cross S, et al. Prevention and treatment of urinary incontinence after stroke in adults. Cochrane Database Syst Rev. 2005;(3):CD004462. Exclusion code: 12. [pmid: 16034933].
Thomas LH, Cross S, Barrett J, et al. Treatment of urinary incontinence after stroke in adults. Cochrane Database Syst Rev. 2009;(1). Exclusion code: 4.
Thorneycroft IH, Goldzieher JW. Venous thromboembolism: a review. J Reprod Med. 2003;48(Suppl 11):911-920. Exclusion code: 7. [pmid: 14686028].
Timins JK. Current issues in hormone replacement therapy. N J Med. 2004;101(3):21-27. Exclusion code: 7. [pmid: 15042800].
Tinelli FG, Tinelli A, Sena T. Clinical effects of hormone replacement therapy with estradiol valerate and cyproterone acetate in perimenopausal women. Minerva Ginecol. 2002;54(1):67-73. Exclusion code: 10. [pmid: 11828273].
Toles CA. The incidence of cardiovascular disease in menopausal women on hormone replacement therapy: a clinical evidence-based medicine review. J Natl Black Nurses Assoc. 2007;18(2):75-80. Exclusion code: 7. [pmid: 18318334].
Toth S, Blanchard E, Herman L, et al. Weighing the risks and benefits of hormone therapy. JAAPA. 2003;16(6):45-47. Exclusion code: 7. [pmid: 14968505].
Tsolaki M, Grammaticos P, Karanasou C, et al. Serum estradiol, progesterone, testosterone, FSH and LH levels in postmenopausal women with Alzheimer’s dementia. Hell J Nucl Med. 2005;8(1):39-42. Exclusion code: 6. [pmid: 15886752].
Turgeon JL, Carr MC, Maki PM, et al. Complex actions of sex steroids in adipose tissue, the cardiovascular system, and brain: insights from basic science and clinical studies. Endocr Rev. 2006;27(6):575-605. Exclusion code: 3. [pmid: 16763155].
U.S. Preventive Services Task Force. Postmenopausal hormone replacement therapy for primary prevention of chronic conditions: recommendations and rationale. Ann Intern Med. 2002;137(10):834-839. Exclusion code: 12. [pmid: 12435221].
U.S. Preventive Services Task Force. Postmenopausal hormone replacement therapy for the primary prevention of chronic conditions: recommendations and rationale. Am Fam Physician. 2003;67(2):358-364. Exclusion code: 2. [pmid: 12562158].
U.S. Preventive Services Task Force. Hormone therapy for the prevention of chronic conditions in postmenopausal women: recommendations from the U.S. Preventive Services Task Force. Ann Intern Med. 2005;142(10):855-860. Exclusion code: 12. [pmid: 15897536].
Uebelhart B, Frey D, Uebelhart D. Hormone replacement therapy: what is the evidence today?. Z Rheumatol. 2003;62(6):508-511. Exclusion code: 7. [pmid: 14685710].
Utian WH, Archer DF, Bachmann GA, et al. Estrogen and progestogen use in postmenopausal women: July 2008 position statement of the North American Menopause Society. Menopause. 2008;15(4 Pt 1):584-602. Exclusion code: 2. [pmid: 18580541].
Utian WH, Gass ML, Pickar JH. Body mass index does not influence response to treatment, nor does body weight change with lower doses of conjugated estrogens and medroxyprogesterone acetate in early postmenopausal women. Menopause. 2004;11(3):306-314. Exclusion code: 11. [pmid: 15167310].
van de Weijer PH. Risks of hormone therapy in the 50–59 year age group. Maturitas. 2008;60(1):59-64. Exclusion code: 7. [pmid: 18556157].
van der Mooren MJ, Kenemans P. The Million Women Study: a licence to kill other investigations?. Eur J Obstet Gynecol Reprod Biol. 2004;113(1):3-5. Exclusion code: 7. [pmid: 15036701].
van der Schouw YT, Grobbee DE. Menopausal complaints, oestrogens, and heart disease risk: an explanation for discrepant findings on the benefits of post-menopausal hormone therapy. Eur Heart J. 2005;26(14):1358-1361. Exclusion code: 7. [pmid: 15860515].
Vandenbroucke JP. The HRT controversy: observational studies and RCTs fall in line. Lancet. 2009;373(9671):1233-1235. Exclusion code: 7. [pmid: 19362661].
Varner RE. Menopausal hormone replacement therapy. Curr Womens Health Rep. 2003;3(5):410-417. Exclusion code: 7. [pmid: 12959701].
Veerus P, Hovi SL, Fischer K, et al. Results from the Estonian postmenopausal hormone therapy trial [ISRCTN35338757]. Maturitas. 2006;55(2):162-173. Exclusion code: 9. [pmid: 16504428].
Vercambre MN, Fournier A, Boutron-Ruault MC, et al. Differential dietary nutrient intake according to hormone replacement therapy use: an underestimated confounding factor in epidemiologic studies?. Am J Epidemiol. 2007;166(12):1451-1460. Exclusion code: 4. [pmid: 17698505].
Verkooijen HM, Bouchardy C, Vinh-Hung V, et al. The incidence of breast cancer and changes in the use of hormone replacement therapy: a review of the evidence. Maturitas. 2009;64(2):80-85. Exclusion code: 7. [pmid: 19709827].
Vestergaard P, Hermann AP, Stilgren L, et al. Effects of 5 years of hormonal replacement therapy on menopausal symptoms and blood pressure: a randomised controlled study. Maturitas. 2003;46(2):123-132. Exclusion code: 11. [pmid: 14559383].
Vickers M, Collins N. Progress on the WISDOM trial: Women’s International Study of the Long Duration Oestrogen After Menpause. Climacteric. 2002;5(Suppl):133-134. Exclusion code: 7.
Vickers M, Meade T, Darbyshire J. WISDOM: history and early demise—was it inevitable?. Climacteric. 2002;5(4):317-325. Exclusion code: 2. [pmid: 12626209].
Vickers MR, Martin J, Meade TW, et al. The Women’s International Study of Long-Duration Oestrogen After Menopause (WISDOM): a randomised controlled trial. BMC Womens Health. 2007;7(2). Exclusion code: 2.
Viscoli CM, Brass LM, Kernan WN, et al. A clinical trial of estrogen-replacement therapy after ischemic stroke. New Engl J Med. 2001;345(17):1243-1249. Exclusion code: 8. [pmid: 11680444].
Viscoli CM, Brass LM, Kernan WN, et al. Estrogen therapy and risk of cognitive decline: results from the Women’s Estrogen for Stroke Trial (WEST). Am J Obstet Gynecol. 2005;192(2):387-393. Exclusion code: 9. [pmid: 15695976].
Vogelvang TE, Mijatovic V, Kamp O, et al. Neither long-term treatment with raloxifene nor hormone replacement therapy modulate cardiac function in healthy postmenopausal women: two randomized, placebo-controlled, 2-year studies. Am J Obstet Gynecol. 2002;186(4):729-736. Exclusion code: 11. [pmid: 11967499].
Vogelvang TE, van der Mooren MJ, Mijatovic V. Hormone replacement therapy, selective estrogen receptor modulators, and tissue-specific compounds: cardiovascular effects and clinical implications. Treat. 2004;3(2):105-115. Exclusion code: 11.
Vukovic V, Lovrencic-Huzjan A, Solter VV, et al. Hormone replacement therapy—is there a place for its use in neurology?. Coll Antropol. 2003;27(1):413-424. Exclusion code: 7. [pmid: 12974172].
Waetjen LE, Dwyer PL. Estrogen therapy and urinary incontinence: what is the evidence and what do we tell our patients?. Int Urogynecol J Pelvic Floor Dysfunct. 2006;17:541-545. Exclusion code: 6. [pmid: 16538421].
Walitt B, Pettinger M, Weinstein A, et al. Effects of postmenopausal hormone therapy on rheumatoid arthritis: the Women’s Health Initiative randomized controlled trials. Arthritis Rheum. 2008;59(3):302-310. Exclusion code: 5. [pmid: 18311749].
Warner J, Butler R. Dementia. Clin Evid. 2002;(7):846-866. Exclusion code: 9. [pmid: 12230710].
Warren MP. A comparative review of the risks and benefits of hormone replacement therapy regimens. Am J Obstet Gynecol. 2004;190(4):1141-1167. Exclusion code: 7. [pmid: 15118656].
Warren MP. Historical perspectives in postmenopausal hormone therapy: defining the right dose and duration. Mayo Clin Proc. 2007;82(2):219-226. Exclusion code: 7. [pmid: 17290731].
Wasnich RD, Bagger YZ, Hosking DJ, et al. Changes in bone density and turnover after alendronate or estrogen withdrawal. Menopause. 2004;11(6 Pt 1):622-630. Exclusion code: 11. [pmid: 15545790].
Wathen CN, Feig DS, Feightner JW, et al. Hormone replacement therapy for the primary prevention of chronic diseases: recommendation statement from the Canadian Task Force on Preventive Health Care. CMAJ. 2004;170(10):1535-1537. Exclusion code: 2. [pmid: 15136543].
Weiner MG, Barnhart K, Xie D, Tannen RL. Hormone therapy and coronary heart disease in young women. Menopause. 2008;15(1):86-93. Exclusion code: 6. [pmid: 17502840].
Welty FK. Alternative hormone replacement regimens: is there a need for further clinical trials?. Curr Opin Lipidol. 2003;14(6):585-591. Exclusion code: 7. [pmid: 14624135].
Wenger NK. Menopausal hormone therapy: is there evidence for cardiac protection?. Int Urol Nephrol. 2004;36(4):617-623. Exclusion code: 7. [pmid: 15787348].
Whitehead M. Hormone replacement therapy with estradiol and drospirenone: an overview of the clinical data. J Br Menopause Soc. 2006;12(Suppl 1):4-7. Exclusion code: 7. [pmid: 16513012].
Wildemeersch D, Dhont M, Weyers S, Temmerman M. Miniature, low-dose, intrauterine drug-delivery systems. Ann N Y Acad Sci. 2003;997:174-184. Exclusion code: 4. [pmid: 14644824].
Wildemeersch D, Pylyser K, De Wever N, et al. Endometrial safety after 5 years of continuous combined transdermal estrogen and intrauterine levonorgestrel delivery for postmenopausal hormone substitution. Maturitas. 2007;57(2):205-209. Exclusion code: 11. [pmid: 17227699].
Williams JK, Suparto I. Hormone replacement therapy and cardiovascular disease: lessons from a monkey model of postmenopausal women. Ilar J. 2004;45(2):139-146. Exclusion code: 3. [pmid: 15111733].
Windler E. Cardiovascular risks under hormone replacement therapy. Internist (Berl). 2004;45(7):826-834. Exclusion code: 10. [pmid: 15205743].
Wise PM. Estrogens and neuroprotection. Trends Endocrinol Metab. 2002;13(6):229-230. Exclusion code: 7. [pmid: 12128278].
Wise PM. Estrogens and cerebrovascular stroke: what do animal models teach us?. Ann N Y Acad Sci. 2005;1052:225-232. Exclusion code: 3. [pmid: 16024765].
Wise PM, Dubal DB, Rau SW, et al. Are estrogens protective or risk factors in brain injury and neurodegeneration? Reevaluation after the Women’s Health Initiative. Endocr Rev. 2005;26(3):308-312. Exclusion code: 7. [pmid: 15851820].
Wolf OT, Heinrich AB, Hanstein B, Kirschbaum C. Estradiol or estradiol/ progesterone treatment in older women: no strong effects on cognition. Neurobiol Aging. 2005;26(7):1029-1033. Exclusion code: 13. [pmid: 15748783].
Woo J, Lau E, Ho SC, et al. Comparison of Pueraria lobata with hormone replacement therapy in treating the adverse health consequences of menopause. Menopause. 2003;10(4):352-361. Exclusion code: 13. [pmid: 12851519].
Writing Group for the 3rd European Conference on Sex Steroids and Cardiovascular Diseases. The European Consensus Development Conference 2002: sex steroids and cardiovascular diseases. On the route to combined evidence from OC and HRT/ERT. Maturitas. 2003;44(1):69-82. Exclusion code: 7. [pmid: 12568738].
Wu O. Postmenopausal hormone replacement therapy and venous thromboembolism. Gend Med. 2005;2(Suppl A):S18-27. Exclusion code: 7. [pmid: 16551553].
Wu ZL, Zhao YC, Yu CS, et al. Comparative study with three agents of hormone replacement therapy in postmenopausal women. J Pract Obstet Gynecol. 2002;18(4):225-227. Exclusion code: 11.
Wysowski DK, Governale LA. Use of menopausal hormones in the United States, 1992 through June 2003. Pharmacoepidemiol Drug Saf. 2005;14(3):171-176. Exclusion code: 5. [pmid: 15386701].
Yaffe K, Sawaya GF, Lieberburg I, Grady D. Estrogen therapy in postmenopausal women: effects on cognitive function and dementia. JAMA. 1998;279:688-695. Exclusion code: 13. [pmid: 9496988].
Yasmeen S, Romano PS, Pettinger M, et al. Incidence of cervical cytological abnormalities with aging in the Women’s Health Initiative: a randomized controlled trial. Obstet Gynecol. 2006;108(2):410-419. Exclusion code: 5. [pmid: 16880313].
Yasui T, Uemura H, Takikawa M, Irahara M. Hormone replacement therapy in postmenopausal women. J Med Invest. 2003;50(3–4):136-145. Exclusion code: 7. [pmid: 13678382].
Ylikangas S, Backstrom T, Heikkinen J. Cost-effectiveness of continuous combined hormone replacement therapy in long-term use: economic evaluation based on a 9-year study in Finland. Curr Med Res Opin. 2007;23(1):57-64. Exclusion code: 5. [pmid: 17257466].
Yoo JW, Lee CH. Drug delivery systems for hormone therapy. J Controlled Release. 2006;112(1):1-14. Exclusion code: 7.
Zandi PP, Carlson MC, Plassman BL, et al. Hormone replacement therapy and incidence of Alzheimer disease in older women: the Cache County Study. JAMA. 2002;288(17):2123-2129. Exclusion code: 6. [pmid: 12413371].
Zec RF, Trivedi MA. The effects of estrogen replacement therapy on neuropsychological functioning in postmenopausal women with and without dementia: a critical and theoretical review. Neuropsychol Rev. 2002;12(2):65-109. Exclusion code: 7. [pmid: 12371603].
Zethraeus N, Borgstrom F, Jonsson B, Kanis J. Reassessment of the cost-effectiveness of hormone replacement therapy in Sweden: results based on the Women’s Health Initiative randomized controlled trial. Int J Technol Assess Health Care. 2005;21(4):433-441. Exclusion code: 5. [pmid: 16262965].
Zhou B, Sun Q, Cong R, et al. Hormone replacement therapy and ovarian cancer risk: a meta-analysis. Gynecologic Oncology. 2008;108:641-651. Exclusion code: 7. [pmid: 18221779].
Zizic TM. Pharmacologic prevention of osteoporotic fractures. Am Fam Physician. 2004;70(7):1293-1300. Exclusion code: 7. [pmid: 15508540].