# List of Acronyms and Abbreviations

Abbreviation: Definition
3MSE: Modified Mini-Mental State Examination
AAFP: American Academy of Family Physicians
ACE: Angiotensin-converting enzyme
ACOG: American Congress of Obstetricians and Gynecologists
ACP: American College of Physicians
AD: Alzheimer’s disease
AE: Adverse events
AHRQ: Agency for Healthcare Research and Quality
BMD: Bone mineral density
BMI: Body mass index
BP: Blood pressure
BVRT: Benton Visual Retention Test
CABG: Coronary artery bypass graft
CEE: Conjugated equine estrogen
CERAD: Consortium to Establish a Registry for Alzheimer’s Disease
CES-D: Center for Epidemiologic Studies Depression Scale
CHD: Coronary heart disease
CHF: Congestive heart failure
CI: Confidence interval
CT: Computed tomography
CVD: Cardiovascular disease
CVLT: California Verbal Learning Test
DBP: Diastolic blood pressure
DSMB: Data and Safety Monitoring Board
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition
DVT: Deep venous thrombosis
E: Estrogen
E + P: Estrogen with progestin
EMS: Estrogen Memory Study
ERA: Estrogen Replacement and Atherosclerosis
ESPRIT: Oestrogen in the Prevention of Reinfarction Trial
ET: Evidence table
FDA: U.S. Food and Drug Administration
f/u: Followup
GDS: Geriatric Depression Scale
GED: General Education Development
HDL: High-density lipoprotein
HERS: Heart and Estrogen/Progestin Replacement Study
HERS II: Heart and Estrogen/Progestin Replacement Study Phase II
HIV: Human immunodeficiency virus
HR: Hazard ratio
HRT: Hormone replacement therapy
HT: Hormone therapy
HTN: Hypertension
Hx: History
ICD 9: International Classification of Diseases–9th Division
ITT: Intention-to-treat
IU: International unit
KQ: Key question
LDL: Low-density lipoprotein
MBNT: Modified Boston Naming Test
MCI: Mild cognitive impairment
MI: Myocardial infarction
MPA: Medroxyprogesterone acetate
MRC: Medical Research Council
n: Sample size
NIH: National Institutes of Health
NNT: Number needed to treat
NR: Not reported
NS: Not significant
NSAID: Nonsteroidal anti-inflammatory drug
OR: Odds ratio
P: Progestin
PANAS: Positive and Negative Affect Schedule
Pap: Papanicolau
PCI: Percutaneous coronary intervention
PD: Probable dementia
PE: Pulmonary embolism
PMA: Primary mental abilities
PO: Per os (by mouth)
PTCA: Percutaneous transluminal coronary angioplasty
RAVLT: Rey Auditory Verbal Learning Test
RCT: Randomized, controlled trial
RR: Relative risk
Rx: Prescription
SBP: Systolic blood pressure
SD: Standard deviation
SE: Standard error
SF-36: 36-Item Short-Form Health Survey
Tx: Treatment
UI: Urinary incontinence
UK: United Kingdom
ULTRA: Ultra Low-Dose Transdermal Estrogen Replacement Assessment
USPSTF: U.S. Preventive Services Task Force
VT: Venous thrombosis
VTE: Venous thromboembolism
WHI: Women’s Health Initiative
WHIMS: Women’s Health Initiative Memory Study
WHISCA: Women’s Health Initiative Study of Cognitive Aging
WISDOM: Women’s International Study of Long-Duration Oestrogen After Menopause