# Appendixes

Appendix A List of Acronyms and Abbreviations

Appendix B Detailed Methods

Appendix C Evidence and Quality Tables