# REFERENCES

1 Nelson HD, Nygren P, McInerney Y. Screening for Family and Intimate Partner Violence. Systematic Evidence Review No. 28. Rockville, MD. Agency for Healthcare Research and Quality. 2004. Accessed at http://www.ahrq.gov/downloads/pub/prevent/pdfser/famviolser.pdf. 17 April 2012.
2 Nelson HD, Nygren P, McInerney Y, et al. Screening women and elderly adults for family and intimate partner violence: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(5):387-96. [pmid: 14996681].
3 Nygren P, Nelson HD, Klein J. Screening children for family violence: a review of the evidence for the U.S. Preventive Services Task Force. Ann Fam Med. 2004;2(2):161-9. [pmid: 15083858].
4 U.S. Preventive Services Task Force. Screening for family and intimate partner violence: recommendation statement. Ann Fam Med. 2004;2(2):156-60. [pmid: 15083857].
5 US Preventive Services Task Force. Screening for Family and Intimate Partner Violence: Recommendation Statement. Rockville, MD. Agency for Healthcare Research and Quality. 2004.
6 Centers for Disease Control and Prevention. Understanding Intimate Partner Violence: Fact Sheet. Atlanta. Centers for Disease Control and Prevention. 2006. Accessed at http://www.cdc.gov/ViolencePrevention/pub/IPV_factsheet.html. 17 April 2012.
7 Saltzman LE, Fanslow JL, McMahon PM, Shelley GA. Intimate Partner Violence Surveillance: Uniform Definitions and Recommended Data Elements. Atlanta. Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 2002. Accessed at http://www.cdc.gov/ncipc/pub-res/ipv_surveillance/intimate.htm. 17 April 2012.
8 Tjaden P, Thoennes N. Stalking in America: Findings From the National Violence Against Women Survey. Washington, DC. U.S. Department of Justice. 1998. Accessed at http://www.ncjrs.gov/pdffiles/169592.pdf. 17 April 2012.
9 Florida Department of Children and Families. Adult Services Program Office, Comparison of Definitions: Florida Statutes 415 and 825. Tallahassee, FL. Florida Department of Children and Families. 2007. Accessed at www.dcf.state.fl.us/initiatives/apspanel/docs/comparisonOfDefinitions.doc. 17 April 2012.
10 National Center on Elder Abuse. Major Types of Elder Abuse. Washington, DC. Administration on Aging. 2011. Accessed at http://www.ncea.aoa.gov/ncearoot/Main_Site/FAQ/Basics/Types_Of_Abuse.aspx. 17 April 2012.
11 Daly JM, Jogerst GJ. Definitions and indicators of elder abuse: a Delphi survey of APS caseworkers. J Elder Abuse Negl. 2005;17(1):1-19. [pmid: 16611614].
12 Centers for Disease Control and Prevention. Elder Maltreatment: Definition. Atlanta. Centers for Disease Control and Prevention. 2010. Accessed at http://www.cdc.gov/ViolencePrevention/eldermaltreatment/definitions.html. 17 April 2012.
13 Kravitz JA. The SAFE ELDERS scales: identifying high risk cases of elder abuse [dissertation]. Malibu, CA. Pepperdine University. 2007.
14 Tjaden P, Thoennes N. Full Report of the Prevalence, Incidence, and Consequences of Violence Against Women: Findings From the National Violence Against Women Survey. Washington, DC. U.S. Department of Justice. 2000. Accessed at https://www.ncjrs.gov/pdffiles1/nij/183781.pdf. 17 April 2012.
15 National Center for Injury Prevention and Control. Costs of Intimate Partner Violence Against Women in the United States. Atlanta. Centers for Disease Control and Prevention. 2003. Accessed at http://www.cdc.gov/violenceprevention/pub/IPV_cost.html. 17 April 2012.
16 Black MC, Breiding MJ. Adverse health conditions and health risk behaviors associated with intimate partner violence —United States, 2005. MMWR Morb Mortal Wkly Rep. 2008;57(5):113-7. [pmid: 18256582].
17 Centers for Disease Control and Prevention. Pregnancy Risk Assessment Monitoring System (PRAMS): CPONDER. Atlanta. Centers for Disease Control and Prevention. 2008. Accessed at http://apps.nccd.cdc.gov/cPONDER/default.aspx?page=main. 17 April 2012.
18 Mouton CP, Rodabough RJ, Rovi SL, et al. Prevalence and 3-year incidence of abuse among postmenopausal women. Am J Public Health. 2004;94(4):605-12. [pmid: 15054013].
19 Thompson RS, Bonomi AE, Anderson M, et al. Intimate partner violence: prevalence, types, and chronicity in adult women. Am J Prev Med. 2006;30(6):447-57. [pmid: 16704937].
20 Moon A, Lawson K, Carpiac M, Spaziano E. Elder abuse and neglect among veterans in greater Los Angeles: prevalence, types, and intervention outcomes. J Gerontol Soc Work. 2006;46(3–4):187-204. [pmid: 16803784].
21 Catalano S. Intimate Partner Violence in the United States. Washington, DC. U.S. Department of Justice, Bureau of Justice Statistics. 2012. Accessed at http://bjs.ojp.usdoj.gov/content/intimate/ipv.cfm. 17 April 2012.
22 Corrigan JD, Wolfe M, Mysiw WJ, et al. Early identification of mild traumatic brain injury in female victims of domestic violence. Am J Obstet Gynecol. 2003;188(5 Suppl):S71-6. [pmid: 12748454].
23 Brock K. When Men Murder Women: An Analysis of 2000 Homicide Data. Washington, DC. Violence Policy Center. 2003. Accessed at http://www.ndvfri.org/wp-content/uploads/ndvfri/28839.pdf. 17 April 2012.
24 Wingood GM, DiClemente RJ, McCree DH, et al. Dating violence and the sexual health of black adolescent females. Pediatrics. 2001;107(5):1-4. [pmid: 11134427].
25 Letourneau EJ, Holmes M, Chaedunn-Roark J. Gynecologic health consequences to victims of interpersonal violence. Womens Health Issues. 1999;9(2):115-20. [pmid: 10189822].
26 Hathaway JE, Mucci LA, Silverman JG, et al. Health status and health care use of Massachusetts women reporting partner abuse. Am J Prev Med. 2000;19(4):302-7. [pmid: 11064235].
27 El Kady D, Gilbert WM, Xing G, Smith LH. Maternal and neonatal outcomes of assaults during pregnancy. Obstet Gynecol. 2005;105(2):357-63. [pmid: 15684165].
28 Huth-Bocks AC, Levendosky AA, Bogat G. The effects of domestic violence during pregnancy on maternal and infant health. Violence Vict. 2002;17(2):169-85. [pmid: 12033553].
29 El-Mohandes AA, Kiely M, Gantz MG, El-Khorazaty MN. Very preterm birth is reduced in women receiving an integrated behavioral intervention: a randomized controlled trial. Matern Child Health J. 2011;15(1):19-28. [pmid: 20082130].
30 Kiely M, El-Mohandes AA, El-Khorazaty MN, Gantz MG. An integrated intervention to reduce intimate partner violence in pregnancy: a randomized controlled trial. Obstet Gynecol. 2010;115(2 Pt 1):273-83. [pmid: 20093899].
31 Shah PS, Shah J. Knowledge Synthesis Group on Determinants of Preterm/LBW Births. Maternal exposure to domestic violence and pregnancy and birth outcomes: a systematic review and meta-analyses. J Womens Health. 2010;19(11):2017-31.
32 Campbell JC. Health consequences of intimate partner violence. Lancet. 2002;359(9314):1331-6. [pmid: 11965295].
33 Golding JM. Intimate partner violence as a risk factor for mental disorders: a meta-analysis. J Fam Violence. 1999;14(2):99-132.
34 Campbell JC, Lewandowski LA. Mental and physical effects of intimate partner violence on women and children. Psychiatr Clin North Am. 1997;20(2):353-74. [pmid: 9196919].
35 Lehmann P. Posttraumatic stress disorder (PTSD) and child witnesses to mother-assault: a summary and review. Child Youth Serv Rev. 2000;22:275-306.
36 Silverman ME, Loudon H. Antenatal reports of pre-pregnancy abuse is associated with symptoms of depression in the postpartum period. Arch Women Ment Health. 2010;13(5):411-5.
37 Coker AL, Smith PH, Bethea L, et al. Physical health consequences of physical and psychological intimate partner violence. Arch Fam Med. 2000;9:451-7. [pmid: 10810951].
38 Coker AL, Davis KE, Arias IA, et al. Physical and mental health effects of intimate partner violence for men and women. Am J Prev Med. 2002;23(4):260-8. [pmid: 12406480].
39 Trickett P, Putnam F, Noll J. Longitudinal Study on Childhood Sexual Abuse—Summary. Cincinnati. Cincinnati Children’s Hospital. 2005.
40 Sickel AE, Noll JG, Moore PJ, et al. The long-term physical health and healthcare utilization of women who were sexually abused as children. J Health Psychol. 2002;7:583-97. [pmid: 22113143].
41 National Center on Elder Abuse. Fact Sheet: Elder Abuse Prevalence and Incidence. Washington, DC. Administration on Aging. 2005. Accessed at http://www.ncea.aoa.gov/ncearoot/Main_Site/pdf/publication/FinalStatistics050331.pdf. 17 April 2012.
42 U.S. Government Accountability Office. Elder Justice: Stronger Federal Leadership Could Enhance National Response to Elder Abuse. Washington, DC. U.S. Government Accountability Office. 2011. Accessed at http://www.gao.gov/new.items/d11208.pdf. 17 April 2012.
43 Cooper C, Selwood A, Blanchard M, et al. Abuse of people with dementia by family carers: representative cross sectional survey. BMJ. 2009;338:b155. [pmid: 19164392].
44 Martin SL, Ray N, Sotres-Alvarez D, et al. Physical and sexual assault of women with disabilities. Violence Against Women. 2006;12(9):823-37. [pmid: 16905675].
45 Cooper C, Selwood A, Livingston G. The prevalence of elder abuse and neglect: a systematic review. Age Ageing. 2008;37(2):151-60. [pmid: 18349012].
46 Lachs MS, Williams CS, O’Brien S, et al. The mortality of elder mistreatment. JAMA. 1998;285(5):428-32. [pmid: 9701077].
47 Centers for Disease Control and Prevention. Intimate Partner Violence: Risk and Protective Factors. Atlanta. Centers for Disease Control and Prevention. 2010. Accessed at http://www.cdc.gov/violenceprevention/intimatepartnerviolence/riskprotectivefactors.html. 17 April 2012.
48 Bhargava R, Temkin TL, Fireman BH, et al. A predictive model to help identify intimate partner violence based on diagnoses and phone calls. Am J Prev Med. 2011;41(2):129-35. [pmid: 21767719].
49 Centers for Disease Control and Prevention. Elder Maltreatment: Risk and Protective Factors. Atlanta. Centers for Disease Control and Prevention. 2010. Accessed at http://www.cdc.gov/ViolencePrevention/eldermaltreatment/riskprotectivefactors.html. 17 April 2012.
50 Anthony EK, Lehning AJ, Austin MJ, Peck MD. Assessing elder mistreatment: instrument development and implications for adult protective services. J Gerontol Soc Work. 2009;52(8):815-36. [pmid: 19830609].
51 Svavarsdottir EK, Orlygsdottir B. Intimate partner abuse factors associated with women’s health: a general population study. J Adv Nurs. 2009;65(7):1452-62. [pmid: 19457003].
52 Martin SL, Rentz ED, Chan RL, et al. Physical and sexual violence among North Carolina women: associations with physical health, mental health, and functional impairment. Womens Health Issues. 2008;18(2):130-40. [pmid: 18319149].
53 Coker AL, Hopenhayn C, DeSimone CP, et al. Violence against women raises risk of cervical cancer. J Womens Health. 2009;18(8):1179-85.
54 Feder G, Ramsay J, Dunne D, et al. How far does screening women for domestic (partner) violence in different health-care settings meet criteria for a screening programme? Systematic reviews of nine UK National Screening Committee criteria. Health Technol Assess. 2009;13(16):1-156.
55 Chang JC, Decker M, Moracco KE, et al. What happens when health care providers ask about intimate partner violence? A description of consequences from the perspectives of female survivors. J Am Med Womens Assoc. 2003;58(2):76-81. [pmid: 12744419].
56 Gielen AC, O’Campo PJ, Campbell JC, et al. Women’s opinions about domestic violence screening and mandatory reporting. Am J Prev Med. 2000;19(4):279-85. [pmid: 11064232].
57 Moon A, Williams O. Perceptions of elder abuse and help-seeking patterns among African-American, Caucasian American, and Korean-American elderly women. Gerontologist. 1993;33(3):386-95. [pmid: 8325527].
58 Podnieks E. The lived experience of abused older women. Can Womens Stud. 1993;12(2):38-44.
59 Brownell P, Berman J, Salamone A. Mental health and criminal justice issues among perpetrators of elder abuse. J Elder Abuse Negl. 1999;11:81-94. [pmid: 21877986].
60 Moon A, Evans-Campbell T. Awareness of formal and informal sources of help for victims of elder abuse among Korean American and Caucasian elders in Los Angeles. J Elder Abuse Negl. 2000;11(3):1-23. [pmid: 21877981].
61 Phillips LR. Domestic violence and aging women. Geriatr Nurs. 2000;21(4):188-93. [pmid: 10945884].
62 Moon A, Benton D. Tolerance of elder abuse and attitudes toward third-party intervention among African American, Korean American, and white elderly. J Multicult Soc Work. 2000;8(3):283-303.
63 Sanchez Y. Elder mistreatment in Mexican American communities: the Nevada and Michigan experiences. Tatara T, editor. Understanding Elder Abuse in Minority Populations. Philadelphia. Brunner/Mazel. 1999.
64 Houry D, Sachs CJ, Feldhaus KM, Linden J. Violence-inflicted injuries: reporting laws in the fifty states. Annals Emerg Med. 2002;39:56-60.
65 Violence Against Women and Department of Justice Reauthorization Act. Pub L No. 109-162, 119 Stat 2960-3135. 2005.
66 National Center on Elder Abuse. State Directory of Helplines, Hotlines, and Elder Abuse Prevention Resources. Washington, DC. Administration on Aging. 2011. Accessed at http://www.ncea.aoa.gov/NCEAroot/Main_Site/Find_Help/State_Resources.aspx. 18 April 2012.
67 Ramsay J, Richardson J, Carter YH, et al. Should health professionals screen women for domestic violence?. BMJ. 2002;325(7359):314. [pmid: 12169509].
68 Rodriguez MA, Wallace SP, Woolf NH, Mangione CM. Mandatory reporting of elder abuse: between a rock and a hard place. Ann Fam Med. 2006;4(5):403-9. [pmid: 17003139].
69 Cooper C, Selwood A, Livingston G. Knowledge, detection, and reporting of abuse by health and social care professionals: a systematic review. Am J Geriatr Psychiatry. 2009;17(10):826-38. [pmid: 19916205].
70 Wathen CN, MacMillan HL. Canadian Task Force on Preventive Health Care. Prevention of violence against women: recommendation statement from the Canadian Task Force on Preventive Health Care. CMAJ. 2003;169:582-4. [pmid: 12975227].
71 American Medical Association. AMA Code of Medical Ethics: Opinion 2.02. Physicians’ Obligations in Preventing, Identifying, and Treating Violence and Abuse. Chicago. American Medical Association. 2007. Accessed at http://www.ama-assn.org/ama/pub/physician-resources/medical-ethics/code-medical-ethics/opinion202.shtml. 18 April 2012.
72 Institute of Medicine. Clinical Preventive Services for Women: Closing the Gaps. Washington, DC. National Academies Press. 2011.
73 American Congress of Obstetricians and Gynecologists. Screening Tools: Domestic Violence. Washington, DC. American Congress of Obstetricians and Gynecologists. 2012. Accessed at http://www.acog.org/About_ACOG/ACOG_Departments/Violence_Against_Women/Screening_Tools__Domestic_Violence. 18 April 2012.
74 Thackeray JD, Hibbard R, Dowd MD, et al. Intimate partner violence: the role of the pediatrician. Pediatrics. 2010;125(5):1094-100. [pmid: 20421260].
75 Family Violence Prevention Fund. National Consensus Guidelines on Identifying and Responding to Domestic Violence Victimization in Health Care Settings. San Francisco. Family Violence Prevention Fund. 2004. Accessed at http://www.futureswithoutviolence.org/userfiles/file/Consensus.pdf. 18 April 2012.
76 Council of International Neonatal Nurses. Position Statement on Routine Screening for Intimate Partner Violence. Boston. Council of International Neonatal Nurses. 2010. Accessed at http://www.coinnurses.org/1_documents/resources/p_statement/Position_Stat_Intimate_Partner_Violence.pdf. 18 April 2012.
77 Emergency Nurses Association. Position Statement: Intimate Partner and Family Violence, Maltreatment, and Neglect. Des Plaines, IL. Emergency Nurses Association. 2006. Accessed at http://www.ena.org/SiteCollectionDocuments/Position%20Statements/Violence_-_Intimate_Partner_and_Family_-_ENA_PS.pdf. 18 April 2012.
78 American College of Emergency Physicians. Clinical & Practice Management: Domestic Family Violence. Irving, TX. American College of Emergency Physicians. 2012. Accessed at http://www.acep.org/content.aspx?id=38378. 18 April 2012.
79 American Academy of Family Physicians. Family and Intimate Partner Violence and Abuse. Leawood, KS. American Academy of Family Physicians. 2012. Accessed at http://www.aafp.org/online/en/home/policy/policies/f/familyandintimatepartner-violenceandabuse.html. 18 April 2012.
80 American Medical Association. Diagnostic treatment guidelines on elder abuse and neglect. Arch Fam Med. 1993;2(4):371-88. [pmid: 8130916].
81 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
82 Campbell J, Jones AS, Dienemann J, et al. Intimate partner violence and physical health consequences. Arch Intern Med. 2002;162(10):1157-63. [pmid: 12020187].
83 Leeflang MM, Deeks JJ, Gatsonis C, et al. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149:889-97. [pmid: 19075208].
84 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
85 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. Institute for Health and Clinical Excellence. 2006.
86 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-8. [pmid: 1834807].
87 MacMillan HL, Wathen C, Jamieson E, et al. Screening for intimate partner violence in health care settings: a randomized trial. JAMA. 2009;302(5):493-501. [pmid: 19654384].
88 Reichenheim ME, Moraes CL. Comparison between the abuse assessment screen and the revised conflict tactics scales for measuring physical violence during pregnancy. J Epidemiol Community Health. 2004;58(6):523-7. [pmid: 15143123].
89 Houry D, Feldhaus K, Peery B, et al. A positive domestic violence screen predicts future domestic violence. J Interpers Violence. 2004;19(9):955-66. [pmid: 15296611].
90 MacMillan HL, Wathen C, Jamieson E, et al. Approaches to screening for intimate partner violence in health care settings: a randomized trial. JAMA. 2006;296(5):530-6. [pmid: 16882959].
91 Chen PH, Rovi S, Vega M, et al. Screening for domestic violence in a predominantly Hispanic clinical setting. Fam Pract. 2005;22(6):617-23. [pmid: 16055473].
92 Wathen C, Jamieson E, MacMillan HL. Who is identified by screening for intimate partner violence?. Womens Health Issues. 2008;18(6):423-32. [pmid: 19041594].
93 Sohal H, Eldridge S, Feder G. The sensitivity and specificity of four questions (HARK) to identify intimate partner violence: a diagnostic accuracy study in general practice. BMC Fam Pract. 2007;8:49. [pmid: 17727730].
94 Weiss SJ, Ernst AA, Cham E, Nick TG. Development of a screen for ongoing intimate partner violence. Violence Vict. 2003;18(2):131-41. [pmid: 12816400].
95 Ernst AA, Weiss SJ, Cham E, et al. Detecting ongoing intimate partner violence in the emergency department using a simple 4-question screen: the OVAT. Violence Vict. 2004;19(3):375-84. [pmid: 15631287].
96 Paranjape A, Liebschutz J. STaT: a three-question screen for intimate partner violence. J Womens Health. 2003;12(3):233-9.
97 Paranjape A, Rask K, Liebschutz J. Utility of STaT for the identification of recent intimate partner violence. J Natl Med Assoc. 2006;98(10):1663-9. [pmid: 17052059].
98 Thombs BD, Bernstein DP, Ziegelstein RC, et al. A brief two-item screener for detecting a history of physical or sexual abuse in childhood. Gen Hosp Psychiatry. 2007;29(1):8-13. [pmid: 17189738].
99 Fulfer JL, Tyler JJ, Choi NJ, et al. Using indirect questions to detect intimate partner violence: the SAFE-T questionnaire. J Interpers Violence. 2007;22(2):238-49. [pmid: 17202578].
100 Dubowitz H, Prescott L, Feigelman S, Lane W, Kim J. Screening for intimate partner violence in a pediatric primary care clinic. Pediatrics. 2008;121(1):e85-91. [pmid: 18166548].
101 Peralta RL, Fleming MF. Screening for intimate partner violence in a primary care setting: the validity of “feeling safe at home” and prevalence results. J Am Board Fam Pract. 2003;16(6):525-32. [pmid: 14963079].
102 Zink T, Levin L, Putnam F, Beckstrom A. Accuracy of five domestic violence screening questions with nongraphic language. Clin Pediatr. 2007;46(2):127-34.
103 Chen JQ, Chen DG. Awareness of child sexual abuse prevention education among parents of grade 3 elementary school pupils in Fuxin City, China. Health Educ Res. 2005;20(5):540-7. [pmid: 15701666].
104 Rabin RF, Jennings JM, Campbell JC. Intimate partner violence screening tools: a systematic review. Am J Prev Med. 2009;36(5):439-45. [pmid: 19362697].
105 Trabold N. Screening for intimate partner violence within a health care setting: a systematic review of the literature. Soc Work Health Care. 2007;45(1):1-18. [pmid: 17804344].
106 Basile KC, Hertz MF, Back SE. Intimate Partner Violence and Sexual Violence Victimization Assessment Instruments for Use in Healthcare Settings. Atlanta. Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 2007. Accessed at http://www.cdc.gov/ncipc/pub-res/ipv_and_sv_screening.htm. 18 April 2012.
107 Bair-Merritt MH, Jennings JM, Chen R, et al. Reducing maternal intimate partner violence after the birth of a child: a randomized controlled trial of the Hawaii Healthy Start home visitation program. Arch Pediatr Adolesc Med. 2010;164(1):16-23. [pmid: 20048237].
108 Curry MA, Durham L, Bullock L, et al. Nurse case management for pregnant women experiencing or at risk for abuse. J Obstet Gynecol Neonatal Nurs. 2006;35(2):181-92.
109 El-Mohandes AA, Kiely M, Joseph JG, et al. An integrated intervention in pregnant African-Americans reduces postpartum risk: a randomized controlled trial. Obstet Gynecol. 2008;112(3):611-20. [pmid: 18757660].
110 McFarlane JM, Groff JY, O’Brien JA, Watson K. Secondary prevention of intimate partner violence: a randomized controlled trial. Nurs Res. 2006;55(1):52-61. [pmid: 16439929].
111 Miller E, Decker MR, McCauley HL, et al. A family planning clinic partner violence intervention to reduce risk associated with reproductive coercion. Contraception. 2011;83(3):274-80. [pmid: 21310291].
112 Taft A, Small R, Hegarty K, et al. Mothers’ Advocates in the Community (MOSAIC): non-professional mentor support to reduce intimate partner violence and depression in mothers: a cluster randomised trial in primary care. BMC Public Health. 2011;11(1):178. [pmid: 21429226].
113 Ramsay C, Rivas C, Feder G. Interventions to Reduce Violence and Promote the Physical and Psychosocial Well-Being of Women Who Experience Partner Violence: A Systematic Review of Controlled Evidence. London. U.K. Department of Health. 2005. Accessed at http://www.dh.gov.uk/en/Publicationsandstatistics/Publications/PublicationsPolicyAndGuidance/DH_4126266. 18 April 2012.
114 Ramsay J, Carter Y, Davidson L, et al. Advocacy interventions to reduce or eliminate violence and promote the physical and psychosocial well-being of women who experience intimate partner abuse. Cochrane Database Syst Rev. 2009;3:CD005043. [pmid: 19588364].
115 Wathen CN, MacMillan HL. Interventions for violence against women: scientific review. JAMA. 2003;289(5):589-600. [pmid: 12578492].
116 Moskovic CS, Guiton G, Chirra A, et al. Impact of participation in a community-based intimate partner violence prevention program on medical students: a multi-center study. J Gen Intern Med. 2008;23(7):1043-7. [pmid: 18612741].
117 Fantuzzo J, Boruch R, Beriama A, et al. Domestic violence and children: prevalence and risk in five major U.S. cities. J Am Acad Child Adolesc Psychiatry. 1997;36(1):116-22. [pmid: 9000789].
118 Vest JR, Catlin TK, Chen JJ, Brownson RC. Multistate analysis of factors associated with intimate partner violence. Am J Prev Med. 2002;22(3):156-64. [pmid: 11897459].
119 Houry D, Kaslow NJ, Kemball RS, et al. Does screening in the emergency department hurt or help victims of intimate partner violence?. Ann Emerg Med. 2008;51(4):433-42. [pmid: 18313800].
120 Spangaro JM, Zwi AB, Poulos RG, Man WY. Six months after routine screening for intimate partner violence: attitude change, useful and adverse effects. Women Health. 2010;50(2):125-43. [pmid: 20437301].
121 Koziol-McLain J, Giddings L, Rameka M, Fyfe E. Intimate partner violence screening and brief intervention: experiences of women in two New Zealand health care settings. J Midwifery Womens Health. 2008;53(6):504-10. [pmid: 18984506].
122 Liebschutz J, Battaglia T, Finley E, Averbuch T. Disclosing intimate partner violence to health care clinicians—what a difference the setting makes: a qualitative study. BMC Public Health. 2008;8:229. [pmid: 18601725].
123 Renker PR, Tonkin P. Women’s views of prenatal violence screening: acceptability and confidentiality issues. Obstet Gynecol. 2006;107(2 Pt 1):348-54. [pmid: 16449123].
124 Sethi D, Watts S, Zwi A, et al. Experience of domestic violence by women attending an inner city accident and emergency department. Emerg Med J. 2004;21(2):180-4. [pmid: 14988343].
125 Weinsheimer RL, Schermer CR, Malcoe LH, et al. Severe intimate partner violence and alcohol use among female trauma patients. J Trauma. 2005;58(1):22-9. [pmid: 15674145].
126 Zeitler MS, Paine AD, Breitbart V, et al. Attitudes about intimate partner violence screening among an ethnically diverse sample of young women. J Adolesc Health. 2006;39(1):119. [pmid: 16781970].
127 Hurley KF, Brown-Maher T, Campbell SG, et al. Emergency department patients’ opinions of screening for intimate partner violence among women. Emerg Med J. 2005;22(2):97-8. [pmid: 15662056].
128 Spangaro JM, Zwi AB, Poulos RG. “Persist, persist”: a qualitative study of women’s decisions to disclose and their perceptions of the impact of routine screening for intimate partner violence. Psychol Violence”. 2011;1(2):150-62.
129 Yaffe MJ, Wolfson C, Lithwick M, Weiss D. Development and validation of a tool to improve physician identification of elder abuse: the Elder Abuse Suspicion Index (EASI). J Elder Abuse Negl. 2008;20(3):276-300. [pmid: 18928055].
130 Humphreys J, Tsoh JY, Kohn MA, Gerbert B. Increasing discussions of intimate partner violence in prenatal care using Video Doctor plus provider cueing: a randomized, controlled trial. Womens Health Issues. 2011;21(2):136-44. [pmid: 21185737].
131 Rhodes KV, Drum M, Anliker E, et al. Lowering the threshold for discussions of domestic violence: a randomized controlled trial of computer screening. Arch Intern Med. 2006;166(10):1107-14. [pmid: 16717173].
132 Ahmad F. Computer-Assisted Screening for Intimate Partner Violence in Family Practice. Toronto. University of Toronto. 2007.
133 Lewis-O’Connor A. When Push Comes to Shove: Screening Mothers for Intimate Partner Violence During a Pediatric Visit [Dissertation]. Boston. Boston College. 2008.
134 Ahmad F, Hogg-Johnson S, Stewart DE, et al. Computer-assisted screening for intimate partner violence and control: a randomized trial. Ann Intern Med. 2009;151(2):93-102. [pmid: 19487706].
135 Bair-Merritt MH, Feudtner C, Mollen CJ, et al. Screening for intimate partner violence using an audiotape questionnaire: a randomized clinical trial in a pediatric emergency department. Arch Pediatr Adolesc Med. 2006;160(3):311-6. [pmid: 16520452].
136 Schafer SD, Drach LL, Hedberg K, Kohn MA. Using diagnostic codes to screen for intimate partner violence in Oregon emergency departments and hospitals. Public Health Rep. 2008;123(5):628-35. [pmid: 18828418].
137 Cooper C, Maxmin K, Selwood A, et al. The sensitivity and specificity of the Modified Conflict Tactics Scale for detecting clinically significant elder abuse. Int Psychogeriatr. 2009;21(4):774-8. [pmid: 19493378].