# DISCUSSION

## Summary of Review Findings

### Screening for Intimate Partner Violence

Table 8 summarizes the evidence reviewed for this update. For Key Question 1 addressing the effectiveness of screening in reducing exposure to violence, physical and mental harms, and mortality, a fair-quality, cluster RCT of screening for IPV in clinical settings met inclusion criteria. This trial included 6,743 Canadian women randomized to screening or nonscreening groups.87 The primary outcomes were exposure to abuse and quality of life in the 18 months after screening, and secondary outcomes included depression, PTSD, alcohol and drug abuse, global mental and physical health, and use of health and social services. Women in both the screened and nonscreened groups had reductions over time in IPV recurrence, PTSD symptoms, and alcohol problems, as well as improvements in scores for quality of life, depression, and mental health. Outcomes for these measures were not significantly different between women in the screened compared with nonscreened groups. However, differences were significant for intermediate outcomes, such as initiating discussions about abuse with clinicians (44 percent screened vs. 8 percent nonscreened women).

Table 8 Summary of Evidence for Screening for Intimate Partner Violence

Number of studies | Design | Limitations | Consistency | Applicability | Overall quality | Findings
Key Question 1. Does screening asymptomatic women in health care settings for current, past, or increased risk for IPV reduce exposure to IPV, physical or mental harms, or mortality?
1 | RCT | High attrition rates, differential loss to followup, Hawthorne effect^*^ among control participants. | Not relevant | High | Fair | Women in both groups had reductions in IPV recurrence, PTSD symptoms, and alcohol problems, as well as improvements in scores for quality of life, depression, and mental health, but no between-group differences.
Key Question 2. How effective are screening techniques in identifying asymptomatic women with current, past, or increased risk for IPV?
15 studies of 13 instruments for identifying IPV in heath care settings | Diagnostic accuracy studies with cross-sectional and prospective data | Enrollment of dissimilar groups at baseline, high attrition rates, unclear application of the reference standard. | Consistent | High | Fair to good | 6 instruments with 1 to 8 items demonstrated sensitivity and specificity >80% in clinical populations of asymptomatic women: HARK, HITS (English and Spanish versions), modified CTQ-SF, OVAT, STaT, and WAST.
Key Question 4. For screen-detected women with current, past, or increased risk for IPV, how well do interventions reduce exposure to IPV, reduce physical or mental harms, or mortality?
6 | RCT | Enrollment of dissimilar groups at baseline, high and/or differential loss to followup, recall bias, missing data, Hawthorne effect among control participants. | Consistent | Some trials used narrowly defined populations that may limit applicability. | Fair to good | 1 trial of counseling vs. usual care during pregnancy reported decreased IVP and improved birth outcomes with counseling. 2 trials of home visitation vs. none for young mothers resulted in improved IVP outcomes with visitation. Counseling resulted in decreased pregnancy coercion and resolution of unsafe relationships vs. usual care in 1 trial. 2 trials showed improved outcomes in intervention and control groups without differences (counseling vs. referral cards, nurse management vs. usual care in pregnancy).
Key Questions 3 and 5. What are the adverse effects of screening for IPV and interventions to reduce harm from IPV?
14 | RCT, prospective cohort, cross-sectional | Descriptive data with variability of populations, measures, and analysis. | Consistent | Unclear, most data are descriptive and come from small samples. | Fair | 3 RCTs reported no adverse effects. Descriptive studies indicated that screening has minimal adverse effects, but some women experience discomfort, loss of privacy, emotional distress, and concerns about further abuse.

Abbreviations: HARK = Humiliation, Afraid, Rape, Kick; HITS = Hurt, Insult, Threaten, Scream; IPV = intimate partner violence; CTQ-SF = Childhood Trauma Questionnaire–Short Form; OVAT = Ongoing Violence Assessment Tool; PTSD = post-traumatic stress disorder; RCT = randomized, controlled trial; STaT = Slapped, Threatened, and Throw; WAST = Woman Abuse Screening Tool.

* Hawthorn effect is when subjects modify an aspect of their behavior in response to the fact that they are being studied.

Limitations of the trial limit its interpretation, however. The study had high loss to followup, and the women lost to followup had more risk and exposure to IPV than women retained in the study. Most importantly, women randomized to the nonscreening group were provided with information cards of locally available resources for women with IPV, and underwent extensive questioning about IPV over 18 months of followup that could increase their awareness, influence their behavior, and affect outcomes of the trial (i.e., Hawthorne effect).

For Key Question 2 regarding the effectiveness of screening techniques in identifying asymptomatic women with IPV, 15 studies rated fair and good quality that evaluated the diagnostic accuracy of 13 screening instruments met inclusion criteria. Screening instruments demonstrating the highest sensitivity and specificity in the included diagnostic accuracy studies include the HITS, OVAT, STaT, HARK, modified CTQ-SF, and WAST. Positive responses on the PVS significantly predicted verbal aggression and violence during the 4 months after screening. Two instruments specifically evaluated in pediatric settings had relatively low sensitivity but high specificity. Results varied between studies and across instruments.

For Key Question 4 evaluating the effectiveness of interventions in reducing exposure to violence, physical and mental harms, and mortality, one good-, four fair-, and one poor-quality RCTs met inclusion criteria. A trial of pregnant women reported decreased IPV and improved birth outcomes with a counseling intervention compared with usual care.29,30,109 Two trials of home visitation for young mothers resulted in improved IPV outcomes compared with no visitation.107,112 Compared with usual care, counseling resulted in decreased pregnancy coercion and resolution of unsafe relationships in another trial.111 Two trials of counseling showed improved outcomes in intervention and control groups, without differences between them (counseling vs. referral cards,110 nurse management vs. usual care in pregnancy108).

For Key Questions 3 and 5 relating to harms of screening and interventions, three studies included for Key Questions 1 and 4 and 11 descriptive studies identified by search strategies and systematic reviews were reviewed. Harms were actively monitored in a randomized trial of 6,743 women that evaluated screening versus no screening in Canadian primary care, acute care, and specialty care sites.87 Results of the analysis of a measure developed to monitor harms for this study indicated no differences in reported harms for screened women who were either exposed or not exposed to IPV, and no harms were associated with screening for either group. A randomized trial of a 3-year home visitation intervention for at-risk newborns and their mothers suggested nonsignificant increases in verbal abuse victimization and perpetration in the intervention group over long-term followup.107 In this study, participants also experienced less physical abuse, so it is possible that perpetrators exchanged physical abuse for verbal abuse. A randomized, two-arm trial of women receiving either a wallet-sized referral card or a 20-minute nurse management protocol to address IPV found no adverse effects as a result of the intervention.110

Descriptive studies generally indicated low levels of harm related to IPV screening and interventions, but study populations and methods varied widely. Some women indicated discomfort with screening, particularly among those with prior IPV; infringement of privacy; worries about increasing abuse by disclosing IPV; feelings of sadness and depression; and general concerns with IPV screening. These issues were voiced by a minority of respondents in the various surveys and interviews.

The results of these studies indicate that IPV screening in health care settings can provide benefits that vary depending on the population screened and the outcome measured, while potential harms of screening have minimal impact on most women. Several screening instruments designed for health care settings demonstrate high sensitivity and specificity, providing standardized approaches to screening. How well the results of these studies translate to clinical practice is not clear, although most studies were conducted in settings and populations drawn from clinical practices. The positive predictive value of screening, as well as potential effects of interventions, would be expected to be greatest in populations with high prevalence of IPV.

### Screening for Abuse and Neglect of Elderly and Vulnerable Adults

Table 9 summarizes the evidence reviewed for this update. For screening for abuse and neglect in elderly and vulnerable adults, no RCTs or controlled observational studies of screening, interventions, or harms were identified or met inclusion criteria for this review. One fair-quality study evaluating the diagnostic accuracy of the EASI, a six-item dichotomous screening instrument, met inclusion criteria for the systematic review. Compared with a comprehensive evaluation by a social worker, the sensitivity and specificity of the EASI varied from 9 to 47 percent and from 75 to 97 percent, depending on the number of positive responses to specific questions. One retrospective study described outcomes of predominantly male elderly veterans who were identified as possibly exposed to abuse or neglect, referred for detailed evaluations, and received social work services. Approximately 5 percent were identified and reported to APS over a 3-year period, and 6 percent received specific services after case management, such as nursing home placement or conservatorship arrangements.

Table 9 Summary of Evidence for Screening for Abuse and Neglect of Elderly and Vulnerable Adults

Number of studies | Design | Limitations | Consistency | Applicability | Overall quality | Findings
Key Question 1. Does screening asymptomatic elderly and vulnerable adults in health care settings for current, past, or increased risk for abuse and neglect reduce exposure to abuse and neglect, physical or mental harms, or mortality?
No studies | Not relevant | Not relevant | Not relevant | Not relevant | Not relevant | Not relevant
Key Question 2. How effective are screening techniques in identifying asymptomatic elderly and vulnerable adults with current, past, or increased risk for abuse and neglect?
1 study | Diagnostic accuracy study with cross-sectional data | Moderate attrition; reference standard may not be replicable. | Not relevant | Low; single study of a small sample of elderly patients in Canada. | Poor | The Elder Abuse Suspicion Index had sensitivity and specificity of 9–47% and 75–97%, depending on the number of positive responses to specific questions.
Key Question 4. For screen-detected elderly and vulnerable adults with current, past, or increased risk for abuse and neglect, how well do interventions reduce exposure to abuse and neglect, physical or mental harms, or mortality?
1 study | Descriptive study with retrospective data | Descriptive data with no comparisons; details of the population, detection of abuse, and interventions are unclear. | Not relevant | Low; single study of a small number of VA patients in Los Angeles. | Poor | Abused veterans were identified in primary care clinics and referred to case management; 5% were reported to Adult Protective Services and 6% required nursing home placement or conservatorship arrangements.
Key Questions 3 and 5. What are the adverse effects of screening for abuse and neglect of elderly and vulnerable adults and interventions to reduce harm from abuse and neglect?
No studies | Not relevant | Not relevant | Not relevant | Not relevant | Not relevant | Not relevant

## Limitations

Limitations of this review include using only English-language articles and studies applicable to U.S. screening populations and clinical practice. Although these inclusion criteria improve applicability to practice in the United States, they also exclude important research. Also, the inclusion criteria targeted specific study designs and health outcomes that disqualified most of the research in this field. RCTs provide the gold standard for evaluating efficacy and effectiveness, but IPV research does not readily fit this standard because of its unique methodological challenges and ethical issues.

Studies of IPV were limited by enrollment of dissimilar groups at baseline, high and/or differential loss to followup, lack of power, recall bias, missing data, and unclear application of the reference standard in diagnostic accuracy studies. Importantly, key studies provided screening and information services to women in control groups that could also be considered interventions, rather than true control conditions. Although designed this way for ethical reasons, this approach reduces measureable differences between intervention and control groups and creates a Hawthorne effect (i.e., the phenomenon that study participants change their behavior as a result of being involved in the study).

The most important limitation of studies of screening elderly and vulnerable adults for abuse and neglect were that they were generally lacking.

## Emerging Issues and Future Research

Several emerging issues are likely to influence research about IPV screening and interventions. The use of alternative screening modalities, such as audio- and computer-assisted screening instrument delivery, has gained interest.130 Computerized screening has been found to increase rates of domestic violence discussion, disclosure, and service provision.130–132 Furthermore, computerized screening has been found to be more acceptable for patients.133,134 Use of an audio questionnaire has also been perceived by patients as more private and less likely to increase risk of abuse.135 Further evaluation of the accuracy, as well as efficiency and acceptability, of these methods could improve screening processes.

Studies of the diagnostic accuracy of screening instruments are limited by the lack of accepted reference standards. Further development and/or validation of an accepted standard would allow more accurate assessment of performance measures and allow instruments to be more readily compared with each other. The broad and inconsistent definitions of abuse pose challenges for creating screening instruments, especially for detecting abuse and neglect in elderly and vulnerable populations.

Research evaluating health system approaches to screening could improve quality, standardization, and rates of screening compared with approaches that depend on implementation on an individual clinic or practitioner basis. Methods could include using diagnostic codes to guide screening in emergency department settings136 or providing screening in the context of the hospital admissions process, for example. Coupled with the systems approach to screening, systems-based protocols for further evaluation and referral for individuals with positive screening results could increase screening effectiveness. Studies that evaluate the feasibility, acceptability, and outcomes of these approaches would provide valuable guidance to health systems interested in implementing them.

Additional studies are needed to evaluate the effectiveness of interventions once IPV has been identified through screening or other processes. Few studies provide these types of evaluations currently, and they are limited by enrolling small numbers of participants from narrowly defined populations. Nonetheless, intervention studies suggest benefits despite their shortcomings and challenges in this field of research. Additional work in this area demonstrating effective interventions once women are identified with IPV through screening could potentially change practice.

All types of studies are needed to improve research for screening elderly and vulnerable adults for abuse and neglect. No RCTs of screening or interventions have been done. Studies of screening instruments are lacking, and most existing instruments remain to be validated. Screening and interventions for this population may be similar in many ways to child abuse because many elderly and vulnerable adults may not have sufficient physical, mental, or financial abilities to engage in screening or interventions. For these situations, instruments need to be framed around third party responses.45,137 Additional challenges to this research include the legal requirements related to disclosure, underlying medical conditions of patients—particularly cognitive impairments for elderly persons, and dependence on the perpetrator, among other issues.

## Conclusions

A trial of screening for IPV in 6,743 women seen in primary, acute, and specialty care clinics in Canada showed reductions in IPV recurrence and improvement in related outcomes for both screening and comparison groups, with no significant between-group differences for major outcomes after 18 months of followup. However, interpretations are limited by overall high and differential attrition and a substantial Hawthorne effect among the control group, bringing to question the feasibility of evaluating the effectiveness of IPV screening using a RCT design. Trials of IPV interventions for pregnant women and young mothers showed improved IPV outcomes for the intervention versus usual care groups, including improved birth outcomes for women provided with multiple-risk factor intervention. Several instruments have been developed for IPV screening, and their diagnostic accuracy has been evaluated in studies of different populations using various reference standards. Six instruments with 1 to 8 items demonstrated sensitivity and specificity >80 percent in clinical populations of asymptomatic women; results varied between studies and across instruments. Studies are generally lacking to address screening elderly and vulnerable adults for abuse.