# METHODS

## Key Questions and Analytic Framework

Based on evidence gaps identified from the previous review1–3 and using the methods of the USPSTF,81 the USPSTF and Agency for Healthcare Research and Quality (AHRQ) determined Key Questions for this review. Investigators created an analytic framework incorporating the Key Questions and outlining patient populations, interventions, outcomes, and harms of the screening process (Figures 1 and 2).

Figure 1 Analytic Framework and Key Questions for Screening Women for Intimate Partner Violence

* Includes reduction in the level of violence or abuse or leaving an unsafe situation.

† Includes physical trauma (e.g., fractures, dislocations, brain injury); unwanted pregnancy and sexually transmitted diseases; mental trauma and its repercussions, such as depression, anxiety, post-traumatic stress disorder; social isolation; quality of life; and chronic medical conditions, among others.

Key Questions

1. Does screening asymptomatic women in health care settings for current, past, or increased risk for intimate partner violence (IPV) reduce exposure to IPV, physical or mental harms, or mortality? (Health care settings include primary care clinics, emergency departments, and student health centers, among others.)

2. How effective are screening techniques in identifying asymptomatic women with current, past, or increased risk for IPV? (Techniques include self-administered [e.g., computer-enabled tool or patient self-report] as well as person-to-person [e.g., clinician to patient] methods.)

3. What are the adverse effects of screening for IPV?

4. For screen-detected women with current, past, or increased risk for IPV, how well do interventions reduce exposure to IPV, physical or mental harms, or mortality?

5. What are the adverse effects of interventions to reduce harm from IPV?

Figure 1 is an analytic framework for the key questions of this report that depicts the events that women without obvious signs of intimate partner violence could experience as a result of undergoing screening for intimate partner violence, with the ultimate goal of reducing mortality and morbidity related to intimate partner violence. The figure illustrates how screening can result in early detection of current, past, or increased risk for intimate partner violence, and how detection can lead to intervention. The figure also depicts the possibility of harms or adverse events occurring as a result of screening or interventions for intimate partner violence.

Figure 2 Analytic Framework and Key Questions for Abuse and Neglect of Elderly and Vulnerable Adults

* Includes reduction in the level of violence or abuse or leaving an unsafe situation.

† Includes physical trauma (e.g., fractures, dislocations, brain injury); unwanted pregnancy and sexually transmitted diseases; mental trauma and its repercussions, such as depression, anxiety, post-traumatic stress disorder; social isolation; quality of life; and chronic medical conditions, among others.

Key Questions

1. Does screening asymptomatic elderly and vulnerable adults in health care settings for current, past, or increased risk for abuse and neglect reduce exposure to abuse and neglect, physical or mental harms, or mortality? (Health care settings include primary care clinics, emergency departments, and others.)

2. How effective are screening techniques in identifying asymptomatic elderly and vulnerable adults with current, past, or increased risk for abuse and neglect? (Techniques include self-administered [e.g., computer-enabled tool or patient self-report] as well as person-to-person [e.g., clinician to patient] methods.)

3. What are the adverse effects of screening for abuse and neglect in elderly and vulnerable adults?

4. For screen-detected elderly and vulnerable adults with current, past, or increased risk for abuse and neglect, how well do interventions reduce exposure to abuse and neglect, physical or mental harms, or mortality?

5. What are the adverse effects of interventions to reduce harm from abuse and neglect?

Figure 2 is an analytic framework for the key questions of this report that depicts the events that elderly persons without obvious signs of abuse or neglect could experience as a result of undergoing screening for abuse and neglect, with the ultimate goal of reducing mortality and morbidity related to abuse and neglect. The figure illustrates how screening can result in early detection of current, past, or increased risk for abuse or neglect, and how detection can lead to intervention. The figure also depicts the possibility of harms or adverse events occurring as a result of screening or interventions for elder abuse or neglect.

Key Questions for IPV (Figure 1) include:

1. Does screening asymptomatic women in health care settings for current, past, or increased risk for IPV reduce exposure to IPV, physical or mental harms, or mortality?
2. How effective are screening techniques in identifying asymptomatic women with current, past, or increased risk for IPV?
3. What are the adverse effects of screening for IPV?
4. For screen-detected women with current, past, or increased risk for IPV, how well do interventions reduce exposure to IPV, physical or mental harms, or mortality?
5. What are the adverse effects of interventions to reduce harm from IPV?

Key Questions for elder and vulnerable adult abuse and neglect (Figure 2) include:

1. Does screening asymptomatic elderly and vulnerable adults in health care settings for current, past, or increased risk for abuse and neglect reduce exposure to abuse and neglect, physical or mental harms, or mortality?
2. How effective are screening techniques in identifying asymptomatic elderly and vulnerable adults with current, past, or increased risk for abuse and neglect?
3. What are the adverse effects of screening for abuse and neglect of elderly and vulnerable adults?
4. For screen-detected elderly and vulnerable adults with current, past, or increased risk for abuse and neglect, how well do interventions reduce exposure to abuse and neglect, physical or mental harms, or mortality?
5. What are the adverse effects of interventions to reduce harm from abuse and neglect?

The target populations for screening are individuals presenting for health care, including adult women for IPV screening and elderly and vulnerable adults for screening for abuse and neglect. Screening is defined as obtaining information about abuse from individuals in health care settings who do not have complaints relating to abuse or obvious signs of abuse, such as physical injuries. This information is obtained from surrogates for individuals who are unable to provide it themselves. Individuals with signs, symptoms, or complaints of abuse or neglect undergo evaluations outside the scope of screening recommendations.

Health care settings include primary care clinics, emergency departments, and student health centers, among others. Screening techniques include self-administered (e.g., computer-enabled tool or patient self-report) as well as person-to-person (e.g., clinician to patient) methods.

Outcomes include both reduction in exposure to IPV or abuse (e.g., decreasing levels of violence or abuse, leaving an unsafe situation), as well as reduction in mortality and physical or mental harms (e.g., physical trauma; unwanted pregnancy and sexually transmitted diseases; emotional trauma, social isolation, and its repercussions such as depression, anxiety, and nightmares; quality of life; and chronic medical conditions).

Possible screening harms include stigma, labeling, clinicians’ negative attitudes, psychological distress, escalation of abuse and family tension, loss of personal residence and financial resources, erosion of established family structure, loss of autonomy for the victim, and lost time from work, among others. Abused women and/or their children can become the target of retaliation, which can lead to homicide.82

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews through the fourth quarter of 2011, and MEDLINE and PsycINFO from 2002 to January 9, 2012, for relevant studies and systematic reviews. Search strategies and additional details are described in Appendix B1. We also reviewed reference lists of papers and citations of key studies manually and by using Scopus. Studies published in 2003 or later were eligible for inclusion in this update.

## Study Selection

We selected studies on the basis of inclusion and exclusion criteria developed for each Key Question (Appendix B2). Appendix B3 shows the results of our literature search and selection process. For all studies, we included research conducted in the United States or in other populations similar to the screening populations targeted in this review that received services and interventions applicable to U.S. medical practice.

For Key Questions 1 and 4, we included randomized, controlled trials (RCTs) of the effectiveness of screening (Key Question 1) or interventions (Key Question 4) for IPV or elder abuse in reducing exposure to abuse and health outcomes as defined by the Key Questions. Studies of screening or referral rates, attitudes about screening, plans or intentions, or reporting other types of intermediate outcomes were not included.

For Key Question 2, we included studies of the diagnostic accuracy of screening techniques in identifying asymptomatic women and elderly/vulnerable adults in health care settings with current or past violence and abuse or at high risk for violence and abuse. Screening tests were included if they were used in or were applicable to U.S. primary care settings. These included self-administered, computer-enabled, or patient self-report instruments, as well as clinician-to-patient methods. Instruments were included if they were feasible for use for screening (i.e., brief, easy to interpret, acceptable to patients and clinicians). We included studies of diagnostic accuracy reporting sensitivity, specificity, area under the curve, or other characteristics (Table 3). We excluded studies lacking a validated reference standard, examining instruments that are not feasible for screening in health care settings, or evaluating instruments in populations different than the target populations for this review. Studies of externally validated techniques, particularly if utilizing large and/or multiple samples, were preferred over studies of internally validated or nonvalidated techniques.

Table 3 Measures of Diagnostic Accuracy

Term | Definition | Interpretation
Sensitivity | The proportion of patients with a condition that test positive. | Sensitivity, specificity, PPV, and NPV are expressed as percentages; the higher the percentage, the better the accuracy of the test.
Specificity | The proportion of patients without a condition that test negative. | Sensitivity, specificity, PPV, and NPV are expressed as percentages; the higher the percentage, the better the accuracy of the test.
Positive Predictive Value (PPV) | The proportion of patients with positive tests that have the condition. | Sensitivity, specificity, PPV, and NPV are expressed as percentages; the higher the percentage, the better the accuracy of the test.
Negative Predictive Value (NPV) | The proportion of patients with negative tests that do not have the condition. | Sensitivity, specificity, PPV, and NPV are expressed as percentages; the higher the percentage, the better the accuracy of the test.
Positive Likelihood Ratio (LR+) | Likelihood ratios use sensitivity and specificity to determine if a test result usefully changes the probability that a condition exists. LR+ is the odds of having a condition when the test is positive. | - If results >1, then test results are related to the condition.; - If results <1, results are associated with absence of the condition.; - If results are close to 1, the test is not helpful for screening purposes.
Negative Likelihood Ratio (LR−) | The odds of not having a condition when the test is negative.
Area Under the Receiver Operating Characteristic Curve (AUC) | The receiver operating characteristic curve is a graphical plot of sensitivity (or true positive rate) versus 1-specificity (or false positive rate). AUC provides an estimate of the discriminatory accuracy of the test. | - If results ≤0.50, discriminatory accuracy is no better than a coin toss.; - If results range between 0.50–0.70, there is moderate accuracy.; - If results >0.70, the test may be clinically useful.

For Key Questions 3 and 5, we included studies on adverse effects of screening and interventions. Consistent with other reviews, inclusion criteria were broadened to include studies of multiple designs to describe potential adverse effects. Studies included for Key Questions 1 and 4 were reviewed for outcomes relevant to Key Questions 3 and 5.

Existing relevant systematic reviews were obtained and included if the individual studies within the review meet inclusion criteria; otherwise, we included the relevant individual studies. We excluded studies examining patient or physician education and methods of increasing screening or disclosure rates. We also excluded studies about the use of services or referral for services if they did not also include health outcomes, and the perceptions and attitudes of physicians and nurses on screening for IPV or elder abuse. Excluded studies are listed in Appendix B4.

## Data Abstraction and Quality Rating

We abstracted details about the patient population, study design, analysis, followup, and results. USPSTF quality criteria were used to determine the quality of individual studies.81 Two investigators rated the quality of studies (good, fair, poor) and resolved discrepancies by consensus (described in Appendixes B5 and B6).81,83–86 Studies with designs that lack quality criteria were qualitatively described.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each Key Question (good, fair, poor) using methods developed by the USPSTF based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence.81 No quantitative analysis, such as meta-analysis, was conducted.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners (Appendix B7).