# Evidence Tables and Quality Rating Tables

Appendix C1 Randomized, Controlled Trials of Screening for Intimate Partner Violence

Appendix C2 Quality Ratings of Randomized, Controlled Trials of Screening for Intimate Partner Violence

Appendix C3 Studies of Screening Instruments for Intimate Partner Violence

Appendix C4 Quality Ratings of Studies of Screening Instruments for Intimate Partner Violence

Appendix C5 Studies of Interventions for Intimate Partner Violence

Appendix C6 Quality Ratings of Studies of Interventions for Intimate Partner Violence

Appendix C7 Studies of Screening Instruments for Elder Abuse and Neglect

Appendix C8 Quality Ratings of Studies of Screening Instruments for Elder Abuse and Neglect

Appendix C9 Studies of Interventions for Elder Abuse and Neglect