# Detailed Methods

## Appendix B1 Search Strategies

Search strategies of various populations (children, elder/vulnerable individuals, and adult women) were combined into one library and reviewed concurrently; therefore, strategies for all of these populations are included below.

### Searches for Randomized Controlled Trials

#### Children

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. ((domestic$ or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. ((baby or babies or infan$ or toddler$ or child$ or teen$ or adolescen$) adj5 (violen$ or abus$ or batter$ or assault$)).mp.
3. from 2 keep 1–808

#### Elderly

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. ((domestic$ or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. ((baby or babies or infan$ or toddler$ or child$ or teen$ or adolescen$) adj5 (violen$ or abus$ or batter$ or assault$)).mp.
3. ((elder$ or parent$ or mother$ or father$) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
4. from 3 keep 1–396

#### Spouse

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. ((domestic$ or family or families or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. from 1 keep 1–387

### Searches for Systematic Reviews

#### Children

Database: EBM Reviews - Cochrane Database of Systematic Reviews
1. ((domestic$ or family or families or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. ((baby or babies or infan$ or toddler$ or child$ or teen$ or adolescen$) adj5 (violen$ or abus$ or batter$ or assault$)).mp.
3. from 2 keep 1–88

#### Elderly

Database: EBM Reviews - Cochrane Database of Systematic Reviews
1. ((domestic$ or family or families or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. ((baby or babies or infan$ or toddler$ or child$ or teen$ or adolescen$) adj5 (violen$ or abus$ or batter$ or assault$)).mp.
3. ((elder$ or parent$ or mother$ or father$) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
4. from 3 keep 1–56

#### Spouse

Database: EBM Reviews - Cochrane Database of Systematic Reviews
1. ((domestic$ or family or families or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. from 1 keep 1–59

### Searches for Interventions

#### Domestic

Database: Ovid MEDLINE(R)
1. exp domestic violence/
2. exp battered women/
3. 1 or 2
4. exp Family Practice/
5. exp Primary Health Care/
6. exp Physicians, Family/
7. exp Emergency Medicine/
8. exp Emergency Medical Services/
9. 4 or 5 or 6
10. 7 or 8
11. exp Preventive Health Services/
12. exp Counseling/
13. exp Mental Health Services/
14. exp “Outcome and Process Assessment (Health Care)”/
15. 3 and 9
16. 3 and 10
17. 3 and 11
18. 3 and 12
19. 3 and 13
20. 3 and 14
21. 15 or 16 or 17 or 18 or 19 or 20
22. limit 21 to (english language and yr=“2002 -Current”)
23. from 22 keep 1–1687

Database: PsycINFO
1. exp Domestic Violence/
2. exp pediatrics/
3. (pediatrician$ or paediatrician$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. exp gerontology/
5. gerontologist$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
6. exp Family Medicine/
7. exp Primary Health Care/
8. exp General Practitioners/
9. exp Family Physicians/
10. (primary care or family medicine or family practice or general practice or gp).mp. [mp=title, abstract, heading word, table of contents, key concepts]
11. exp Emergency Services/
12. (emergency or emergencies).mp. [mp=title, abstract, heading word, table of contents, key concepts]
13. 2 or 3
14. 4 or 5
15. 6 or 7 or 8 or 9 or 10
16. 11 or 12
17. 1 and 13
18. 1 and 14
19. 1 and 15
20. 1 and 16
21. 17 or 18 or 19 or 20
22. from 21 keep 1–205

#### Children

Database: Ovid MEDLINE(R)
1. exp Child Abuse/
2. exp Domestic Violence/
3. limit 2 to “all child (0 to 18 years)”
4. 1 or 3
5. exp Schools/
6. crime/ or exp crime victims/ or exp homicide/ or exp sex offenses/ or exp violence/
7. 5 and 6
8. limit 7 to “all child (0 to 18 years)”
9. 4 or 8
10. exp Family Practice/
11. exp Primary Health Care/
12. exp Physicians, Family/
13. pediatrician$.mp.
14. exp Pediatrics/
15. exp Emergency Medicine/
16. exp Emergency Medical Services/
17. 10 or 11 or 12
18. 9 and 17
19. 13 or 14
20. 9 and 19
21. 15 or 16
22. 9 and 21
23. 18 or 20 or 22
24. exp Preventive Health Services/
25. exp Counseling/
26. 9 and 24
27. 9 and 25
28. exp Mental Health Services/
29. 9 and 28
30. limit 9 to clinical trial, all
31. exp “Outcome and Process Assessment (Health Care)”/
32. 9 and 31
33. 23 or 26 or 27 or 30 or 32
34. limit 33 to english language
35. limit 34 to yr=“2002 -Current”
36. from 35 keep 1–1317

Database: PsycINFO
1. exp Child Abuse/
2. exp Child Neglect/
3. 1 or 2
4. exp Domestic Violence/
5. limit 4 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
6. exp Physical Abuse/
7. exp Emotional Abuse/
8. exp Sexual Abuse/
9. 6 or 7 or 8
10. limit 9 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
11. 3 or 5 or 10
12. exp Pediatrics/
13. (pediatrician$ or paediatrician$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
14. exp Family Medicine/
15. exp Primary Health Care/
16. exp General Practitioners/
17. exp Family Physicians/
18. (primary care or family medicine or family practice or general practice or gp).mp. [mp=title, abstract, heading word, table of contents, key concepts]
19. exp Emergency Services/
20. (emergency or emergencies).mp. [mp=title, abstract, heading word, table of contents, key concepts]
21. 12 or 13
22. 11 and 21
23. 14 or 15 or 16 or 17 or 18
24. 11 and 23
25. 19 or 20
26. 11 and 25
27. 22 or 24 or 26
28. limit 27 to yr=“2002 -Current”
29. from 28 keep 1–243

#### Elderly

Database: Ovid MEDLINE(R)
1. exp elder abuse/
2. exp Domestic Violence/
3. limit 2 to “all aged (65 and over)”
4. 1 or 3
5. exp residential facilities/
6. crime/ or exp crime victims/ or exp homicide/ or exp sex offenses/ or exp violence/
7. 5 and 6
8. limit 7 to “all aged (65 and over)”
9. 4 or 8
10. exp Family Practice/
11. exp Primary Health Care/
12. exp Physicians, Family/
13. gerontologist$.mp.
14. exp geriatrics/
15. exp Emergency Medicine/
16. exp Emergency Medical Services/
17. 10 or 11 or 12
18. 9 and 17
19. 13 or 14
20. 9 and 19
21. 15 or 16
22. 9 and 21
23. 18 or 20 or 22
24. exp Preventive Health Services/
25. exp Counseling/
26. 9 and 24
27. 9 and 25
28. exp Mental Health Services/
29. 9 and 28
30. limit 9 to clinical trial, all
31. exp “Outcome and Process Assessment (Health Care)”/
32. 9 and 31
33. 23 or 26 or 27 or 29 or 30 or 32
34. limit 33 to (english language and yr=“2002 -Current”)
35. from 34 keep 1–250

Database: PsycINFO
1. exp elder abuse/
2. exp Domestic Violence/
3. limit 2 to “380 aged <age 65 yrs and older>“
4. exp Physical Abuse/
5. exp patient abuse/
6. exp Emotional Abuse/
7. exp Sexual Abuse/
8. 4 or 5 or 6 or 7
9. limit 8 to “380 aged <age 65 yrs and older>“
10. 1 or 3 or 9
11. exp gerontology/
12. gerontologist$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
13. exp Family Medicine/
14. exp Primary Health Care/
15. exp General Practitioners/
16. exp Family Physicians/
17. (primary care or family medicine or family practice or general practice or gp).mp. [mp=title, abstract, heading word, table of contents, key concepts]
18. exp Emergency Services/
19. (emergency or emergencies).mp. [mp=title, abstract, heading word, table of contents, key concepts]
20. 11 or 12
21. 10 and 20
22. 13 or 14 or 15 or 16 or 17
23. 10 and 22
24. 18 or 19
25. 10 and 24
26. 21 or 23 or 25
27. limit 26 to yr=“2002 -Current”
28. from 27 keep 1–63

#### Spouse

Database: Ovid MEDLINE(R)
1. Spouse Abuse/
2. ((spous$ or wife or husband or boyfriend$ or girlfriend$ or married or marriage$ or intimate partner$ or common law or cohabitat$) adj5 (abus$ or violen$ or attack$ or assault$ or batter$)).mp.
3. exp Family Practice/
4. exp Primary Health Care/
5. exp Physicians, Family/
6. exp Emergency Medicine/
7. exp Emergency Medical Services/
8. 3 or 4 or 5
9. 6 or 7
10. exp Preventive Health Services/
11. exp Counseling/
12. exp Mental Health Services/
13. exp “Outcome and Process Assessment (Health Care)”/
14. 2 and 8
15. 2 and 9
16. 2 and 10
17. 2 and 11
18. 2 and 12
19. 2 and 13
20. 14 or 15 or 16 or 17 or 18 or 19
21. limit 20 to (english language and yr=“2002 -Current”)
22. from 21 keep 1–611

Database: PsycINFO
1. exp partner abuse/
2. exp battered women/
3. 1 or 2
4. exp Domestic Violence/
5. exp marriage/
6. exp marital status/
7. exp cohabitation/
8. exp spouses/
9. exp couples/
10. living arrangements/
11. 5 or 6 or 7 or 8 or 9 or 10
12. 4 and 11
13. exp Physical Abuse/
14. exp Emotional Abuse/
15. exp Sexual Abuse/
16. 13 or 14 or 15
17. 11 and 16
18. 3 or 12 or 17
19. exp Family Medicine/
20. exp Primary Health Care/
21. exp General Practitioners/
22. exp Family Physicians/
23. (primary care or family medicine or family practice or general practice or gp).mp. [mp=title, abstract, heading word, table of contents, key concepts]
24. exp Emergency Services/
25. (emergency or emergencies).mp. [mp=title, abstract, heading word, table of contents, key concepts]
26. 19 or 20 or 21 or 22 or 23
27. 18 and 26
28. 24 or 25
29. 18 and 28
30. 27 or 29
31. limit 30 to yr=“2002 -Current”
32. from 31 keep 1–148

### Searches for Screening

#### Domestic

Database: Ovid MEDLINE(R)
1. exp domestic violence/
2. exp battered women/
3. 1 or 2
4. exp Mass Screening/
5. 3 and 4
6. screen$.mp.
7. exp questionnaires/
8. exp risk assessment/
9. exp diagnosis/
10. di.fs.
11. 9 or 10
12. 7 and 11
13. 3 and 6
14. 3 and 8
15. 3 and 12
16. 13 or 14 or 15
17. limit 16 to (english language and yr=“2002 -Current”)
18. from 17 keep 1–1686

Database: PsycINFO
1. exp Domestic Violence/
2. exp Screening/
3. exp Screening Tests/
4. 2 or 3
5. 1 and 4
6. screen$.mp.
7. 1 and 6
8. exp Measurement/
9. (diagnos$ or assess$ or discover$ or recogni$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
10. 8 and 9
11. 1 and 10
12. 5 or 7 or 11
13. limit 12 to yr=“2002 -Current”
14. from 13 keep 1–327

#### Children

Database: Ovid MEDLINE(R)
1. exp Child Abuse/
2. exp Domestic Violence/
3. limit 2 to “all child (0 to 18 years)”
4. 1 or 3
5. exp Schools/
6. crime/or exp crime victims/or exp homicide/or exp sex offenses/or exp violence/
7. 5 and 6
8. limit 7 to “all child (0 to 18 years)”
9. 4 or 8
10. exp Mass Screening/
11. 9 and 10
12. screen$.mp.
13. 9 and 12
14. exp questionnaires/
15. 9 and 14
16. exp risk assessment/
17. 9 and 16
18. 11 or 13
19. exp diagnosis/
20. di.fs.
21. 19 or 20
22. 15 and 21
23. 17 or 18 or 22
24. limit 23 to yr=“2002 -Current”
25. limit 24 to english language
26. from 25 keep 1–1094

Database: PsycINFO
1. exp Child Abuse/
2. exp Child Neglect/
3. 1 or 2
4. exp Domestic Violence/
5. limit 4 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
6. exp Physical Abuse/
7. exp Emotional Abuse/
8. exp Sexual Abuse/
9. 6 or 7 or 8
10. limit 9 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
11. 3 or 5 or 10
12. exp Screening/
13. exp Screening Tests/
14. 12 or 13
15. 11 and 14
16. screen$.mp.
17. 11 and 16
18. 15 or 17
19. exp Measurement/
20. (diagnos$ or assess$ or discover$ or recogni$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
21. 19 and 20
22. 11 and 21
23. 18 or 22
24. limit 23 to yr=“2002 -Current”
25. limit 24 to english language
26. from 25 keep 1–512

#### Elderly

Database: Ovid MEDLINE(R)
1. exp elder abuse/
2. exp Domestic Violence/
3. limit 2 to “all aged (65 and over)”
4. 1 or 3
5. exp residential facilities/
6. crime/or exp crime victims/or exp homicide/or exp sex offenses/or exp violence/
7. 5 and 6
8. limit 7 to “all aged (65 and over)”
9. 4 or 8
10. exp Mass Screening/
11. 9 and 10
12. screen$.mp.
13. 9 and 12
14. exp questionnaires/
15. 9 and 14
16. exp risk assessment/
17. 9 and 16
18. 11 or 13 or 15 or 17
19. limit 18 to (english language and yr=“2002 -Current”)
20. from 19 keep 1–412

Database: PsycINFO
1. exp elder abuse/
2. exp Domestic Violence/
3. limit 2 to “380 aged <age 65 yrs and older>“
4. exp Physical Abuse/
5. exp patient abuse/
6. exp Emotional Abuse/
7. exp Sexual Abuse/
8. 4 or 5 or 6 or 7
9. limit 8 to “380 aged <age 65 yrs and older>“
10. 1 or 3 or 9
11. exp Screening/
12. exp Screening Tests/
13. 11 or 12
14. 10 and 13
15. screen$.mp.
16. 10 and 15
17. 14 or 16
18. exp Measurement/
19. (diagnos$ or assess$ or discover$ or recogni$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
20. 18 and 19
21. 10 and 20
22. 17 or 21
23. limit 22 to yr=“2002 -Current”
24. limit 23 to english language
25. from 24 keep 1–95

#### Spouse

Database: Ovid MEDLINE(R)
1. Spouse Abuse/
2. ((spous$ or wife or husband or boyfriend$ or girlfriend$ or married or marriage$ or intimate partner$ or common law or cohabitat$) adj5 (abus$ or violen$ or attack$ or assault$ or batter$)).mp.
3. exp Mass Screening/
4. 2 and 3
5. screen$.mp.
6. exp questionnaires/
7. exp risk assessment/
8. exp diagnosis/
9. di.fs.
10. 2 and 5
11. 2 and 6
12. 2 and 7
13. 8 or 9
14. 11 and 13
15. 4 or 10 or 12 or 14
16. limit 15 to (english language and yr=“2002 -Current”)
17. from 16 keep 1–664

Database: PsycINFO
1. exp partner abuse/
2. exp battered women/
3. 1 or 2
4. exp Domestic Violence/
5. exp marriage/
6. exp marital status/
7. exp cohabitation/
8. exp spouses/
9. exp couples/
10. living arrangements/
11. 5 or 6 or 7 or 8 or 9 or 10
12. 4 and 11
13. exp Physical Abuse/
14. exp Emotional Abuse/
15. exp Sexual Abuse/
16. 13 or 14 or 15
17. 11 and 16
18. 3 or 12 or 17
19. exp Screening/
20. exp Screening Tests/
21. 19 or 20
22. screen$.mp.
23. exp Measurement/
24. (diagnos$ or assess$ or discover$ or recogni$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
25. 23 and 24
26. 18 and 21
27. 18 and 22
28. 18 and 25
29. 26 or 27 or 28
30. limit 29 to yr=“2002 -Current”
31. from 30 keep 1–366

## Appendix B2 Inclusion and Exclusion Criteria

| Inclusion Criteria | Exclusion Criteria
All Key Questions
Population | Women (age ≥18 years), elderly and vulnerable adult populations, individuals presenting for primary care services. | Symptomatic individuals undergoing diagnostic evaluations for conditions related to violence and abuse (e.g., those presenting with a broken bone or signs of physical abuse in the emergency department).
Languages | Full text published in English. | Not English language.
Settings | Primary care or other settings where primary care services are offered, such as emergency departments, student health centers. Research conducted in the United States or in other populations similar to U.S. populations with services and interventions applicable to U.S. practice. | Nonclinically based settings or nonapplicable settings (e.g., prisons), populations or services/interventions not applicable to U.S. practice.
Key Question 1. Screening
Screening tests | Screening tests used in or applicable to U.S. primary care settings. These include self-administered, computer-enabled, or patient self-report instruments, as well as clinician-to-patient methods. Instruments may be designed to detect current or past violence or abuse, or risk status for violence or abuse. Instruments must be feasible for use for screening (i.e., brief, easy to interpret, acceptable to patients and clinicians). | Screening tests not used or not applicable to U.S. primary care settings.
Outcomes | Decreasing level of violence or abuse; leaving an unsafe situation; physical trauma (fractures, dislocations, brain injury); sexual trauma, unintended pregnancy, and sexually transmitted diseases; mental trauma; social isolation; mental health repercussions such as depression, anxiety, nightmares; quality of life; and chronic medical conditions, among others. | Screening or referral rates, attitudes about screening, plans or intentions, and other intermediate outcomes.
Study designs | Randomized, controlled trials. | Nonrandomized study designs.
Key Questions 2. Screening tests
Screening tests | Screening tests used in or applicable to U.S. primary care settings. These include self-administered, computer-enabled, or patient self-report instruments, as well as clinician-to-patient methods. Instruments may be designed to detect current or past violence or abuse, or risk status for violence or abuse. Instruments must be feasible for use for screening (i.e., brief, easy to interpret, acceptable to patients and clinicians). Instrument must be compared with an acceptable reference standard (verified or self-reported abuse or longer validated instrument of abuse). | Screening tests not applicable to U.S. primary care settings. Inadequate or no reference standard comparison.
Outcomes | Sensitivity, specificity, positive and negative predictive values, positive and negative likelihood ratios, diagnostic odds ratios, relative risks for future abuse. | Theory or survey development and validation without correlation to abuse outcomes, focus only on particular risk factors, or assessment of provider or participant attitudes toward the instrument.
Study designs | Studies of diagnostic accuracy. | Other study designs.
Key Question 3. Harms of screening
Outcomes | False positives, false negatives, any potential effects of screening or identification such as increased abuse. | Outcomes not directly related to the screening process.
Study designs | Any. | All designs considered.
Key Question 4. Interventions
Interventions | Services that could result from a screening assessment by a clinician; services may be implemented by nonclinicians (e.g., referral). | Public awareness campaigns without specific interventions linked to screening. Studies of other interventions that do not include a health service component (e.g., effectiveness of women’s shelters, unless referred by health clinicians).
Outcomes | Decreasing level of violence or abuse; leaving an unsafe situation; physical trauma (fractures, dislocations, brain injury); sexual trauma, unintended pregnancy, and sexually transmitted diseases; mental trauma; social isolation; mental health repercussions such as depression, anxiety, nightmares; quality of life; and chronic medical conditions, among others. | Screening or referral rates, attitudes about screening, plans or intentions, and other intermediate outcomes.
Study Designs | Randomized, controlled trials. | Nonrandomized study designs.
Key Question 5. Harms of Interventions
Interventions | Services that could result from a screening assessment by a clinician; services may be implemented by nonclinicians (e.g., referral). | Public awareness campaigns without specific interventions linked to screening. Studies of other interventions that do not include a health service component (e.g., effectiveness of women’s shelters, unless referred by health clinicians).
Outcomes | Any harms that result as an effect of interventions. | Outcomes not directly related to the screening process.
Study Designs | Any. | All designs considered.

## Appendix B3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Identified from reference lists, suggested by experts.

‡ Includes search results for child, adult, and elderly populations. Studies of children and elderly populations are included in a separate report.

§ Studies that meet inclusion criteria for Key Questions.

║ Some studies apply to more than one Key Question.

Appendix B3 is a flow chart that summarizes the search and selection of articles. There were 8,368 citations identified by searching through the Medline and Cochrane databases. Of these, 7,743 citations were excluded because they did not meet inclusion criteria. Of these, 625 full-text articles were reviewed for relevance to the key question. Of these, 590 articles were excluded for the following reasons: wrong population (116); screening test not relevant or study was limited (118); fwrong intervention (46); wrong outcome (83); wrong study design for key question (6); no primary data, editorial, or nonsystematic review (109); risk factor, association, or prevalence study only (59); not applicable to United States (25); and systematic review including noneligible studies (28). Remaining after the full-text review was 1 randomized, controlled trial for key question 1; 15 studies for key question 2; 6 randomized, controlled trials (in 8 articles) for key question 4; and 14 studies for key questions 3 and 5..

## Appendix B4 Excluded Studies

### Wrong Population

Armstrong KL, Fraser JA, Dadds MR, Morris J. A randomized, controlled trial of nurse home visiting to vulnerable families with newborns. J Paediatr Child Health. 1999;35(3):237-44. [pmid: 10404442].
Ayoub CC, Milner JS. Failure to thrive: parental indicators, types, and outcomes. Child Abuse Negl. 1985;9(4):491-9. [pmid: 4084828].
Ayranci U, Yenilmez C, Balci Y, Kaptanoglu C. Identification of violence in Turkish health care settings. J Interpers Violence. 2006;21(2):276-96. [pmid: 16368766].
Babcock JC, Green CE, Robie C. Does batterers’ treatment work? A meta-analytic review of domestic violence treatment. Clin Psychol Rev. 2004;23(8):1023-53. [pmid: 14729422].
Barlow J, Davis H, McIntosh E, et al. Role of home visiting in improving parenting and health in families at risk of abuse and neglect: results of a multicentre randomised controlled trial and economic evaluation. Arch Dis Child. 2007;92(3):229-33. [pmid: 17068074].
Barth RP. An experimental evaluation of in-home child abuse prevention services. Child Abuse Negl. 1991;15(4):363-75. [pmid: 1959070].
Barth RP, Hacking S, Ash JR. Preventing child abuse: an experimental evaluation of the child parent enrichment project. J Prim Prev. 1988;8(41):201-17.
Bowen E, Gilchrist E, Beech AR. Change in treatment has no relationship with subsequent re-offending in U.K. domestic violence sample: a preliminary study. Int J Offender Ther Comp Criminol. 2008;52(5):598-614. [pmid: 18505816].
Bradford K. Screening couples for intimate partner violence. J Fam Psychother. 2010;21(1):76-82.
Brownell P, Berman J, Salamone A. Mental health and criminal justice issues among perpetrators of elder abuse. J Elder Abuse Negl. 2000;11(4):81-94. [pmid: 21877986].
Bugental DB, Ellerson PC, Lin EK, et al. A cognitive approach to child abuse prevention. J Fam Psychol. 2002;16(3):243-58. [pmid: 12238408].
Bugental DB, Schwartz A. A cognitive approach to child mistreatment prevention among medically at-risk infants. Dev Psychol. 2009;45(1):284-8. [pmid: 19210009].
Carbone-López K, Kruttschnitt C, Macmillan R. Patterns of intimate partner violence and their associations with physical health, psychological distress, and substance use. Public Health Rep. 2006;121(4):382-92. [pmid: 16827439].
Carter-Visscher RM, Naugle AE, Bell KM, Suvak MK. Ethics of asking trauma-related questions and exposing participants to arousal-inducing stimuli. J Trauma Dissociation. 2007;8(3):27-55. [pmid: 18032343].
Chaffin M, Funderburk B, Bard D, et al. A combined motivation and parent-child interaction therapy package reduces child welfare recidivism in a randomized dismantling field trial. J Consult Clin Psychol. 2011;79(1):84-95. [pmid: 21171738].
Chaffin M, Silovsky JF, Funderburk B, et al. Parent-child interaction therapy with physically abusive parents: efficacy for reducing future abuse reports. J Consult Clin Psychol. 2004;72(3):500-10. [pmid: 15279533].
Chaffin M, Valle LA. Dynamic prediction characteristics of the Child Abuse Potential Inventory. Child Abuse Negl. 2003;27(5):463-81. [pmid: 12718957].
Chan E, Cavacuiti C. Gay Abuse Screening Protocol (GASP): screening for abuse in gay male relationships. J Homosex. 2008;54(4):423-38. [pmid: 18826169].
Chen W, Balaban R, Stanger V, et al. Suspected child abuse and neglect: assessment in a hospital setting. Isr Med Assoc J. 2002;4(8):617-23. [pmid: 12183867].
Conners NA, Whiteside-Mansell L, Deere D, et al. Measuring the potential for child maltreatment: the reliability and validity of the Adult Adolescent Parenting Inventory-2. Child Abuse Negl. 2006;30(1):39-53. [pmid: 16406026].
Cooper C, Maxmin K, Selwood A, et al. The sensitivity and specificity of the Modified Conflict Tactics Scale for detecting clinically significant elder abuse. Int Psychogeriatr. 2009;21(4):774-8. [pmid: 19493378].
Coulthard P, Yong LS, Adamson L, et al. Domestic violence screening and intervention programmes for adults with dental or facial injury. Cochrane Database Syst Rev. 2010;12:CD004486. [pmid: 21154356].
Coulthard P, Yong S, Adamson L, et al. Domestic violence screening and intervention programmes for adults with dental or facial injury. Cochrane Database Syst Rev. 2004;2:CD004486. [pmid: 15106255].
DiLillo D, Tremblay GC, et al. Linking childhood sexual abuse and abusive parenting: the mediating role of maternal anger. Child Abuse Negl. 2000;24(6):767-79. [pmid: 10888017].
Dubowitz H, Feigelman S, et al. Pediatric primary care to help prevent child maltreatment: the Safe Environment for Every Kid (SEEK) model. Pediatrics. 2009;123(3):858-64. [pmid: 19255014].
Duggan KA, McFarlane EC, Windham AM, et al. Evaluation of Hawaii’s Healthy Start Program. Future Child. 1999;9(1):66-90. [pmid: 10414011].
Duggan A, Caldera D, et al. Impact of a statewide home visiting program to prevent child abuse. Child Abuse Negl. 2007;31(8):801-27. [pmid: 17822764].
Duggan A, McFarlane E, et al. Randomized trial of a statewide home visiting program: impact in preventing child abuse and neglect. Child Abuse Negl. 2004;28(6):597-622. [pmid: 15193851].
DuMont K, Mitchell-Herzfeld S, et al. Healthy Families New York (HFNY) randomized trial: effects on early child abuse and neglect. Child Abuse Negl. 2008;32(3):295-315. [pmid: 18377991].
Easton CJ, Mandel DL, et al. A cognitive behavioral therapy for alcohol-dependent domestic violence offenders: an integrated substance abuse-domestic violence treatment approach (SADV). Am J Addict. 2007;16(1):24-31. [pmid: 17364418].
Eckenrode J, Ganzel B, et al. Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000;284(11):1385-91. [pmid: 10989400].
El-Mohandes AA, Katz KS, et al. The effect of a parenting education program on the use of preventive pediatric health care services among low-income, minority mothers: a randomized, controlled study. Pediatrics. 2003;111(6 Pt 1):1324-32. [pmid: 12777548].
El-Mohandes AA. 2006. A psycho-behavioral intervention on African American pregnant women with a history of intimate partner violence (IPV) improves birth weight distribution of their newborns [abstract]. Proceedings of the 17th Pediatric Academic Societies Annual Meeting. 2006 Apr 29–May 2. San Francisco.
Feigelman S, Dubowitz H, et al. Screening for harsh punishment in a pediatric primary care clinic. Child Abuse Negl. 2009;33(5):269-277. [pmid: 19477005].
Fergusson DM, Grant H, et al. Randomized trial of the Early Start program of home visitation. Pediatrics. 2005;116(6):e803-9. [pmid: 16322138].
Fergusson DM, Grant H, et al. Randomized trial of the Early Start program of home visitation: parent and family outcomes. Pediatrics. 2006;117(3):781-6. [pmid: 16510658].
Fraser JA, Armstrong KL, et al. Home visiting intervention for vulnerable families with newborns: follow-up results of a randomized controlled trial. Child Abuse Negl. 2000;24(11):1399-429. [pmid: 11128173].
Friedrich WN, Fisher JL, et al. Child Sexual Behavior Inventory: normative, psychiatric, and sexual abuse comparisons. Child Maltreat. 2001;6(1):37-49. [pmid: 11217169].
Gielen AC, O’Campo PJ, et al. Women’s opinions about domestic violence screening and mandatory reporting. Am J Prev Med. 2000;19(4):279-85. [pmid: 11064232].
Goldbeck L, Laib-Koehnemund A, et al. A randomized controlled trial of consensus-based child abuse case management. Child Abuse Negl. 2007;31(9):919-33. [pmid: 17870161].
Grieten H, Geeraert L, et al. A scale for home visiting nurses to identify risks of physical abuse and neglect among mothers with newborn infants. Child Abuse Negl. 2004;28(3):321-37. [pmid: 15066349].
Halpern LR. Orofacial injuries as markers for intimate partner violence. Oral Maxillofac Surg Clin North Am. 2010;22(2):239-46. [pmid: 20403555].
Halpern LR, Dodson TB. A predictive model to identify women with injuries related to intimate partner violence. J Am Dent Assoc. 2006;137(5):604-9. [pmid: 16739539].
Hardy JB, Streett R. Family support and parenting education in the home: an effective extension of clinic-based preventive health care services for poor children. J Pediatr. 1989;115(6):927-31. [pmid: 2585229].
Heckert DA, Gondolf EW. Battered women’s perceptions of risk versus risk factors and instruments in predicting repeat reassault. J Interpers Viol. 2004;19(7):778-800.
Helfritch CA, Beer DW. Use of the FirstSTEp screening tool with children exposed to domestic violence and homelessness: a group case study. Phys Occup Ther Pediatr. 2007;27(2):63-76. [pmid: 17442655].
Helmus L, Bourgon G. Taking stock of 15 years of research on the Spousal Assault Risk Assessment Guide (SARA): a critical review. Int J Forensic Mental Health. 2011;10(1):64-75.
Hsieh HF, Wang JJ, et al. Educational support group in changing caregivers’ psychological elder abuse behavior toward caring for institutionalized elders. Adv Health Science Educ Theory Pract. 2009;14(3):377-86.
PRAISE Investigators. Bhandari M, et al. Prevalence of Abuse and Intimate Partner Violence Surgical Evaluation (PRAISE): rationale and design of a multi-center cross-sectional study. BMC Musculoskelet Disord. 2010;11:77. [pmid: 20416039].
Johnson M, Stone S, et al. 2008. Assessing parent education programs for families involved with child welfare services: evidence and implications. J Evid Based Soc Work. 2008;5(1–2):191-236. [pmid: 19064449].
Johnson MA, Stone S, et al. Assessing Parent Education Programs for Families Involved With Child Welfare Services: Evidence and Implications. Berkeley, California. University of California at Berkeley. 2006.
Jouriles EN, McDonald R, et al. Improving parenting in families referred for child maltreatment: a randomized controlled trial examining effects of Project Support. J Fam Psychol. 2010;24(3):328-38. [pmid: 20545406].
Kaye DK, Mirembe FM, et al. Domestic violence during pregnancy and risk of low birthweight and maternal complications: a prospective cohort study at Mulago Hospital, Uganda. Trop Med Int Health. 2006;11(10):1576-84. [pmid: 17002732].
Kethineni S, Blimling L, et al. Youth violence: an exploratory study of a treatment program in a central Illinois county. Int J Offender Ther Comp Criminol. 2004;48(6):697-720. [pmid: 15538027].
Kimerling R, Gima K, et al. The Veterans Health Administration and military sexual trauma. Am J Pub Health. 2007;97(12):2160-6. [pmid: 17971558].
Kitzman H, Olds DL, et al. Effect of prenatal and infancy home visitation by nurses on pregnancy outcomes, childhood injuries, and repeated childbearing. JAMA. 1997;278(8):644-52. [pmid: 9272896].
Koniak-Griffin D, Verzemnieks IL, et al. Nurse visitation for adolescent mothers: two-year infant health and maternal outcomes. Nurs Res. 2003;52(2):127-36. [pmid: 12657988].
Koziol-McLain J, Garrett N, et al. A randomized controlled trial of a brief emergency department intimate partner violence screening intervention. Ann Emerg Med. 2010;56(4):413-23. [pmid: 20538369].
Kropp P, Gibas A. The Spousal Assault Risk Assessment Guide (SARA): Handbook of Violence Risk Assessment. New York. Routledge/Taylor & Francis Group. 2010.
Krysik J, LeCroy CW. The evaluation of Healthy Families Arizona: a multisite home visitation program. J Prev Interv Community. 2007;34(1–2):109-27. [pmid: 17890196].
Lane WG, Dubowitz H, et al. Screening for occult abdominal trauma in children with suspected physical abuse. Pediatrics. 2009;124(6):1595-602. [pmid: 19933726].
Larson CP. Efficacy of prenatal and postpartum home visits on child health and development. Pediatrics. 1980;66(2):191-7. [pmid: 7402804].
Lau AS, Weisz JR. Reported maltreatment among clinic-referred children: implications for presenting problems, treatment attrition, and long-term outcomes. J Am Acad Child Adolesc Psychiatry. 2003;42(11):1327-34. [pmid: 14566170].
Letarte MJ, Normandeau S, et al. Effectiveness of a parent training program: Incredible Years in a child protection service. Child Abuse Negl. 2010;34(4):253-61. [pmid: 20356626].
Lowell DI, Carter AS, et al. A randomized controlled trial of Child FIRST: a comprehensive home-based intervention translating research into early childhood practice. Child Dev. 2011;82(1):193-208. [pmid: 21291437].
MacMillan HL, Thomas BH, et al. Effectiveness of home visitation by public-health nurses in prevention of the recurrence of child physical abuse and neglect: a randomised controlled trial. Lancet. 2005;365(9473):1786-93. [pmid: 15910951].
Margolis PA, Stevens R, et al. From concept to application: the impact of a community-wide intervention to improve the delivery of preventive services to children. Pediatrics. 2001;108(3):E42. [pmid: 11533360].
Martin SL, Young SK, et al. Health care-based interventions for women who have experienced sexual violence: a review of the literature. Trauma Violence Abuse. 2007;8(1):3-18. [pmid: 17204597].
McRae RE. The Treatment of Child Neglect Through a comprehensive Service Strategy Including Home-Based Therapy, Play Therapy, Parent Education, and Parent-Child Interaction Therapy [dissertation]. San Diego, California. Alliant International University. 2003.
Miccio-Fonseca L. MEGA: an ecological risk assessment tool of risk and protective factors for assessing sexually abusive children and adolescents. J Aggress Maltreat Trauma. 2010;19(7):734-56.
Mills TJ, Avegno JL, et al. Male victims of partner violence: prevalence and accuracy of screening tools. J Emerg Med. 2006;31(4):447-52. [pmid: 17046494].
Milner JS. Medical conditions and Child Abuse Potential Inventory specificity. Psychol Assess. 1991;3(2):208-12.
Milner JS, Gold RG. Screening spouse abusers for child abuse potential. J Clin Psychol. 1986;42(1):169-72. [pmid: 3950003].
Milner JS, Gold RG, et al. Predictive validity of the Child Abuse Potential Inventory. J Consult Clin Psychol. 1984;52(5):879-84. [pmid: 6501673].
Moon A, Benton D. Tolerance of elder abuse and attitudes toward third-party intervention among African American, Korean American, and white elderly. J Multicult Soc Work. 2000;8(3):283-303.
Moon A, Evans-Campbell T. Awareness of formal and informal sources of help for victims of elder abuse among Korean American and Caucasian elders in Los Angeles. J Elder Abuse Negl. 2000;11(3):1-23. [pmid: 21877981].
Moon A, Lawson K, et al. Elder abuse and neglect among veterans in greater Los Angeles: prevalence, types, and intervention outcomes. J Gerontol Soc Work. 2006;46(3–4):187-204. [pmid: 16803784].
Moon A, Tomita SK, et al. Elder mistreatment among four Asian American groups—an exploratory study on tolerance, victim blaming and attitudes toward third-party intervention. J Gerontol Soc Work. 2002;36(1):153-69.
Moss E, Dubois-Comtois K, et al. Efficacy of a home-visiting intervention aimed at improving maternal sensitivity, child attachment, and behavioral outcomes for maltreated children: a randomized control trial. Dev Psychopathol. 2011;23(1):195-210. [pmid: 21262048].
Noether CD, Finkelstein N, et al. Design strengths and issues of SAMHSA’s women, co-occurring disorders, and violence study. Psychiatr Serv. 2005;56(10):1233-6. [pmid: 16215188].
Olds DL, Henderson CR, et al. Preventing child abuse and neglect: a randomized trial of nurse home visitation. Pediatrics. 1986;78(1):65-78. [pmid: 2425334].
Olds DL, Henderson CR, et al. Does prenatal and infancy nurse home visitation have enduring effects on qualities of parental caregiving and child health at 25 to 50 months of life?. Pediatrics. 1994;93(1):89-98. [pmid: 8265329].
Olds DL, Kitzman H, et al. Effects of nurse home-visiting on maternal life course and child development: age 6 follow-up results of a randomized trial. Pediatrics. 2004;114(6):1550-9. [pmid: 15574614].
Olds DL, Kitzman H, et al. Effects of nurse home visiting on maternal and child functioning: age 9 follow-up of a randomized trial. Pediatrics. 2007;120(4):e832-45. [pmid: 17908740].
Olds DL, Robinson J, et al. Home visiting by paraprofessionals and by nurses: a randomized, controlled trial. Pediatrics. 2002;110(3):486-96. [pmid: 12205249].
Olds DL, Robinson J, et al. Effects of home visits by paraprofessionals and by nurses: age 4 follow-up results of a randomized trial. Pediatrics. 2004;114(6):1560-8. [pmid: 15574615].
Ondersma SJ, Chaffin MJ, et al. A brief form of the child abuse potential inventory: development and validation. J Clin Child Adolesc Psychol. 2005;34(2):301-11. [pmid: 15901230].
Parish WL, Wang T, et al. Intimate partner violence in China: national prevalence, risk factors and associated health problems. Int Fam Plan Perspect. 2004;30(4):174-81. [pmid: 15590383].
Perciaccante VJ, Carey JW, et al. Markers for intimate partner violence in the emergency department setting. J Oral Maxillofac Surg. 2010;68(6):1219-24. [pmid: 20395028].
Perciaccante VJ, Susarla SM, et al. Validation of a diagnostic protocol used to identify intimate partner violence in the emergency department setting. J Oral Maxillofac Surg. 2010;68(7):1537-42. [pmid: 20561466].
Peters R, Barlow J. Systematic review of instruments designed to predict child maltreatment during the antenatal and postnatal periods. Child Abuse Rev. 2003;12(6):416-39.
Phillips LR. Domestic violence and aging women. Geriatr Nurs. 2000;21(4):188-93. [pmid: 10945884].
Phillips LR. Abuse of aging caregivers: test of a nursing intervention. Adv Nurs Sci. 2008;31(2):164-81.
Reid RJ, Bonomi AE, et al. Intimate partner violence among men: prevalence, chronicity, and health effects. Am J Prev Med. 2008;34(6):478-85. [pmid: 18471583].
Salvagni EP, Wagner MB. Development of a questionnaire for the assessment of sexual abuse in children and estimation of its discriminant validity: a case-control study. J Pediatr (Rio J). 2006;82(6):431-6. [pmid: 16951801].
Sanchez Y. Elder mistreatment in Mexican American communities: the Nevada and Michigan experiences. Tatara T, editor. Understanding Elder Abuse in Minority Populations. Philadelphia. Brunner/Mazel. 1999.
Shakil A, Donald S, et al. Validation of the HITS domestic violence screening tool with males. Fam Med. 2005;37(3):193-8. [pmid: 15739135].
Siegel E, Bauman KE, et al. Hospital and home support during infancy: impact on maternal attachment, child abuse and neglect, and health care utilization. Pediatrics. 1980;66(2):183-90. [pmid: 7402803].
Sikkema KJ, Hansen NB, et al. The clinical significance of change in trauma-related symptoms following a pilot group intervention for coping with HIV-AIDS and childhood sexual trauma. AIDS Behav. 2004;8(3):277-91. [pmid: 15475675].
Smedslund G, Dalsbo TK, et al. Cognitive behavioural therapy for men who physically abuse their female partner. Cochrane Database Syst Rev. 2011;2:CD006048.
Starn JR. Community health nursing visits for at-risk women and infants. J Community Health Nurs. 1992;9(2):103-10. [pmid: 1624977].
Stevens-Simon C, Nelligan D, et al. Adolescents at risk for mistreating their children, part II: a home- and clinic-based prevention program. Child Abuse Negl. 2001;25(6):753-69. [pmid: 11525524].
Stover CS, Poole G, et al. The domestic violence home-visit intervention: impact on police-reported incidents of repeat violence over 12 months. Violence Vict. 2009;24(5):591-606. [pmid: 19852401].
Swan SC. A review of research on women’s use of violence with male intimate partners. Violence Vict. 2008;23(3):301-14. [pmid: 18624096].
Swenson CC, Schaeffer CM, et al. Multisystemic therapy for child abuse and neglect: a randomized effectiveness trial. J Fam Psychol. 2010;24(4):497-507. [pmid: 20731496].
Thackeray J, Stelzner S, et al. Screening for intimate partner violence: the impact of screener and screening environment on victim comfort. J Interpers Violence. 2007;22(6):659-70. [pmid: 17515428].
Thomas NJ, Shaffer ML, et al. Temporal factors and the incidence of physical abuse in young children: decreased nonaccidental trauma during child abuse prevention month. J Pediatr Surg. 2007;42(10):1735-9. [pmid: 17923205].
Waxman HC, Houston WR, et al. The long-term effects of the Houston Child Advocates, Inc., program on children and family outcomes. Child Welfare. 2009;88(6):23-46. [pmid: 20695290].
Wherry JN, Graves LE, et al. The convergent validity of the trauma symptom checklist for young children for a sample of sexually abused outpatients. J Child Sex Abuse. 2008;17(1):38-50.
Williams KR, Grant SR. Empirically examining the risk of intimate partner violence: the revised Domestic Violence Screening Instrument (DVSI-R). Pub Health Rep. 2006;121(4):400-8. [pmid: 16827441].
Williams TL. The Development and Validation of a Multi-Dimensional Assessment Instrument of Child Sexual Abuse Experiences [dissertation]. College Station, TX. Texas A&M University. 2002.
Woodman J, Pitt M, et al. Performance of screening tests for child physical abuse in accident and emergency departments. Health Technol Assess. 2008;12(33):1-95.
Wu V, Huff H, et al. Pattern of physical injury associated with intimate partner violence in women presenting to the emergency department: a systematic review and meta-analysis. Trauma Violence Abuse. 2010;11(2):71-82. [pmid: 20430799].
Yaffe MJ, Wolfson C, et al. Development and validation of a tool to improve physician identification of elder abuse: the Elder Abuse Suspicion Index (EASI). J Elder Abuse Negl. 2008;20(3):276-300. [pmid: 18928055].
Zink T, Klesges LM, et al. Abuse behavior inventory: cutpoint, validity, and characterization of discrepancies. J Interpers Violence. 2007;22(7):921-931. [pmid: 17575069].
Zun LS, Downey L, et al. The effectiveness of an ED-based violence prevention program. Am J Emerg Med. 2006;24(1):8-13. [pmid: 16338502].

### Issue With Screening Test

Ahmad F. Computer-Assisted Screening for Intimate Partner Violence in Family Practice. Toronto. University of Toronto. 2007.
Ahmad F, Hogg-Johnson S, Stewart DE, et al. Computer-assisted screening for intimate partner violence and control: a randomized trial. Ann Intern Med. 2009;151(2):93-102. [pmid: 19487706].
Anderson BA, Marshak HH, et al. Identifying intimate partner violence at entry to prenatal care: clustering routine clinical information. J Midwifery Womens Health. 2002;47(5):353-359. [pmid: 12361347].
Ast E. The Development and Validation of the Ast Physical Discipline Inventory–2006 (ADPI). Fresno, California. Alliant International University. 2007.
Bair-Merritt MH, Jennings JM, et al. Screening for domestic violence and childhood exposure in families seeking care at an urban pediatric clinic. J Pediatr. 2008;152(5):734-736. [pmid: 18410785].
Begun AL, Brondino MJ, et al. The revised Safe At Home instrument for assessing readiness to change intimate partner violence. Murphy CM, Maiuro RD, editors. Motivational Interviewing and Stages of Change in Intimate Partner Violence. New York. Springer. 2009.
Begun AL, Murphy C, et al. Characteristics of the Safe at Home instrument for assessing readiness to change intimate partner violence. Res Soc Work Pract. 2003;13(1):80-107.
Berk RA, He Y, et al. Developing a practical forecasting screener for domestic violence incidents. Eval Rev. 2005;29(4):358-83. [pmid: 15985524].
Bifulco A, Bernazzani O, et al. The childhood experience of care and abuse questionnaire (CECA.Q): validation in a community series. Br J Clin Psychol. 2005;44(Pt 4):563-581. [pmid: 16368034].
Bonomi AE, Thompson RS, et al. Ascertainment of intimate partner violence using two abuse measurement frameworks. Injury Prev. 2006;12(2):121-124.
Bremner J, Bolus R, et al. Psychometric properties of the Early Trauma Inventory-Self-Report. J Nerv Ment Dis. 2007;195(3):211-218. [pmid: 17468680].
Campbell JC, Webster D, et al. The danger assessment: validation of a lethality risk assessment instrument for intimate partner femicide. J Interpers Violence. 2009;24(4):653-74. [pmid: 18667689].
Carr GD, Moretti MM, et al. Evaluating parenting capacity: validity problems with the MMPI-2, PAI, CAPI, and ratings of child adjustment. Prof Psychol Res Pract. 2005;36(2):188-196.
Carroll JC, Reid AJ, et al. Effectiveness of the Antenatal Psychosocial Health Assessment (ALPHA) form in detecting psychosocial concerns: a randomized controlled trial. Can Med Assoc J. 2005;173(3):253-259. [pmid: 16076821].
Cerezo MA, Pons-Salvador G. Improving child maltreatment detection systems: a large-scale case study involving health, social services, and school professionals. Child Abuse Negl. 2004;28(11):1153-1169. [pmid: 15567021].
Chang DC, Knight VM, et al. The multi-institutional validation of the new screening index for physical child abuse. J Pediatr Surg. 2005;40(1):114-119. [pmid: 15868569].
Colarossi LG, Breitbart V, et al. Screening for intimate partner violence in reproductive health centers: an evaluation study. Women Health. 2010;50(4):313-326. [pmid: 20711946].
Conrad KJ, Iris M, et al. Self-report measure of financial exploitation of older adults. Gerontologist. 2010;50(6):758-773. [pmid: 20667945].
Cooper C, Manela M, et al. Screening for elder abuse in dementia in the LASER-AD study: prevalence, correlates and validation of instruments. Int J Geriatr Psychiatr. 2008;23(3):283-8.
Curry MA, Powers LE, et al. Development of an abuse screening tool for women with disabilities. J Aggress Maltreat Trauma. 2003;8(4):123-41.
Curry M, Renker P, et al. Development of measures of abuse among women with disabilities and the characteristics of their perpetrators. Violence Against Women. 2009;15(9):1001-25. [pmid: 19622789].
Datner EM, Wiebe DJ, et al. Identifying pregnant women experiencing domestic violence in an urban emergency department. J Interpers Violence. 2007;22(1):124-135. [pmid: 17151383].
Davis RC, Taylor BG. A proactive response to family violence: the results of a randomized experiment. Criminology. 1997;35(2):307-333.
Dienemann J, Glass N, et al. The Domestic Violence Survivor Assessment (DVSA): a tool for individual counseling with women experiencing intimate partner violence. Issues Mental Health Nurs. 2007;28(8):913-925.
DiLillo D, Hayes-Skeltona SA, et al. Development and initial psychometric properties of the Computer Assisted Maltreatment Inventory (CAMI): a comprehensive self-report measure of child maltreatment history. Child Abuse Negl. 2010;34(5):305-314. [pmid: 20347148].
Elzevier HW, Voorham-van der Zalm PJ, et al. How reliable is a self-administered questionnaire in detecting sexual abuse: a retrospective study in patients with pelvic-floor complaints and a review of literature. J Sex Med. 2007;4(4 Pt 1):956-963. [pmid: 17627742].
Erlingsson CL, Carlson SL, et al. Elder abuse risk indicators and screening questions: results from a literature search and a panel of experts from developed and developing countries. J Elder Abuse Negl. 2003;15(3–4):185-203.
Falk DR, Shepard MF, et al. Evaluation of a domestic violence assessment protocol used by employee assistance counselors. Employee Assistance Quarterly. 2002;17(3):1-15.
Fogarty CT, Brown JB. Screening for abuse in Spanish-speaking women. J Am Board Fam Pract. 2002;15(2):101-111. [pmid: 12002193].
Fricker AE, Smith DW, et al. Effects of context and question type on endorsement of childhood sexual abuse. J Trauma Stress. 2003;16(3):265-268. [pmid: 12816339].
Fulmer T, Paveza G, et al. Neglect assessment in urban emergency departments and confirmation by an expert clinical team. J Gerontol Biol Sci Med Sci. 2005;60(8):102-1006.
Gagnon AJ, Tuck J, et al. A systematic review of questionnaires measuring the health of resettling refugee women. Health Care Women Int. 2004;25(2):111-149. [pmid: 14766429].
Goetz AT, Shackelford TK, et al. Adding insult to injury: development and initial validation of the partner-directed insults scale. Violence Vict. 2006;21(6):691-706. [pmid: 17220014].
Gully KJ. Expectations test: trauma scales for sexual abuse, physical abuse, exposure to family violence, and posttraumatic stress. Child Maltreat. 2003;8(3):218-229. [pmid: 12934639].
Halpern LR, Parry BA, et al. A comparison of 2 protocols to detect intimate partner violence. J Oral Maxillofac Surg. 2009;67(7):1453-1459. [pmid: 19531417].
Halpern LR, Perciaccante VJ, et al. A protocol to diagnose intimate partner violence in the emergency department. J Trauma Injury Infect Crit Care. 2006;60(5):1101-1105.
Halpern LR, Susarla SM, et al. Injury location and screening questionnaires as markers for intimate partner violence. J Oral Maxillofac Surg. 2005;63(9):1255-1261. [pmid: 16122587].
Hamby S, Sugarman DB, et al. Does questionnaire format impact reported partner violence rates? An experimental study. Violence Vict. 2006;21(4):507-518. [pmid: 16897917].
Harrington D, Zuravin S, et al. The Neglect Scale: confirmatory factor analyses in a low-income sample. Child Maltreat. 2002;7(4):359-368. [pmid: 12408247].
Hegarty K, Bush R, et al. The Composite Abuse Scale: further development and assessment of reliability and validity of a multidimensional partner abuse measure in clinical settings. Violence Vict. 2005;20(5):529-547. [pmid: 16248489].
Heinzer MM, Krimm JR. Barriers to screening for domestic violence in an emergency department. Holist Nurs Pract. 2002;16(3):24-33. [pmid: 11913225].
Heron SL, Thompson MP, et al. Do responses to an intimate partner violence screen predict scores on a comprehensive measure of intimate partner violence in low-income black women?. Ann Emerg Med. 2003;42(4):483-491. [pmid: 14520319].
Hewitt LN, Bhavsar P, et al. The secrets women keep: intimate partner violence screening in the female trauma patient. J Trauma Injury Infect Crit Care. 2011;70(2):320-323.
Holtrop TG, Fischer H, et al. Screening for domestic violence in a general pediatric clinic: be prepared!. Pediatrics. 2004;114(5):1253-1257. [pmid: 15520104].
Houry D, Kemball RS, et al. Development of a brief mental health screen for intimate partner violence victims in the emergency department. Acad Emerg Med. 2007;14(3):202-209. [pmid: 17242384].
Hymel KP, Stoiko MA, et al. Head injury depth as an indicator of causes and mechanisms. Pediatrics. 2010;125(4):712-720. [pmid: 20351004].
Irizarry-Irizarry A. Development and validation of a questionnaire about the attitude and exposure of aged-Puerto Ricans to abuse and neglect. P R Health Sci J. 2008;27:129-33. [pmid: 18616040].
Jones C, Bonner M. Screening for domestic violence in an antenatal clinic. Aust J Midwifery. 2002;15(1):14-20. [pmid: 12017039].
Jones S, Davidson WS 2nd, et al. Validation of the subtle and overt psychological abuse scale: an examination of construct validity. Violence Vict. 2005;20(4):407-416. [pmid: 16250408].
Jory B. The Intimate Justice Scale: an instrument to screen for psychological abuse and physical violence in clinical practice. J Marital Fam Ther. 2004;30(1):29-44. [pmid: 14763207].
Kantor GK, Holt MK, et al. Development and preliminary psychometric properties of the Multidimensional Neglectful Behavior Scale-Child Report. Child Maltreat. 2004;9:409-28. [pmid: 15538039].
Kataoka Y, Yaju Y, et al. Self-administered questionnaire versus interview as a screening method for intimate partner violence in the prenatal setting in Japan: a randomised controlled trial. BMC Pregnancy Childbirth. 2010;10:84. [pmid: 21182802].
Kearney MH, Haggerty LA, et al. Birth outcomes and maternal morbidity in abused pregnant women with public versus private health insurance. J Nurs Scholarsh. 2003;35(4):345-9. [pmid: 14735677].
Kilpatrick KL. The parental empathy measure: a new approach to assessing child maltreatment risk. Am J Orthopsychiatr. 2005;75(4):608-620.
Koenig LJ, Whitaker DJ, et al. Violence during pregnancy among women with or at risk for HIV infection. Am J Pub Health. 2002;92(3):367-370. [pmid: 11867312].
Kropp P. Development of the Spousal Assault Risk Assessment Guide (SARA) and the Brief Spousal Assault Form for the Evaluation of Risk (B-SAFER). Baldry AC, Winkel FW, editors. Intimate Partner Violence Prevention and Intervention: The Risk Assessment and Management Approach. Hauppauge, NY. Nova Science Publishers. 2008.
Lam WK, Fals-Stewart W, et al. The timeline followback interview to assess children’s exposure to partner violence: reliability and validity. J Fam Violence. 2009;24(2):133-143.
Lewis-O’Connor A. When push comes to shove: screening mothers for intimate partner violence during a pediatric visit. Boston. Boston College. 2008.
Lounds JJ, Borkowski JG, et al. Reliability and validity of the Mother-Child Neglect Scale. Child Maltreat. 2004;9(4):371-381. [pmid: 15538036].
Lutz KF. Living two lives: a grounded theory of abuse during pregnancy. Comm Nurs Res. 2004;37:101-109.
McClennen JC, Summers AB, et al. The Lesbian Partner Abuse Scale. Res Social Work Pract. 2002;12(2):277-292.
McFarlane J, Greenberg L, et al. Identification of abuse in emergency departments: effectiveness of a two-question screening tool. J Emerg Nurs. 1995;21(5):391-394. [pmid: 7500563].
McFarlane J, Hughes R, et al. Abuse Assessment Screen–Disability (AAS-D): measuring frequency, type, and perpetrator of abuse toward women with physical disabilities. J Womens Health Gender Based Med. 2001;10:861-866.
McWhinney-Dehaney L. The Development and Psychometric Testing of the Risk for Abuse Assessment Scale and the Abuse Assessment Tool for Use in Jamaican Women. Atlanta. Emory University. 2007.
Melchert TP, Kalemeera A. A brief version of the Family Background Questionnaire. Meas Eval Couns Dev. 2009;41(4):210-222.
Midmer D, Bryanton J, et al. Assessing antenatal psychosocial health: randomized controlled trial of two versions of the ALPHA form. Can Fam Physician. 2004;50:80-87. [pmid: 14761108].
Moran PM, Bifulco A, et al. Exploring psychological abuse in childhood, I: developing a new interview scale. Bull Menninger Clin. 2002;66(3):213-240. [pmid: 12448628].
Murphy S, Orkow B, et al. Prenatal prediction of child abuse and neglect: a prospective study. Child Abuse Negl. 1985;9(2):225-235. [pmid: 4005663].
Naik AD, Teal CR, et al. Conceptual challenges and practical approaches to screening capacity for self-care and protection in vulnerable older adults. J Am Geriatr Soc. 2008;56(Suppl 2):S266-70. [pmid: 19016970].
Nilsson D, Wadsby M, et al. The psychometric properties of the Trauma Symptom Checklist for Children (TSCC) in a sample of Swedish children. Child Abuse Negl. 2008;32(6):627-36. [pmid: 18584867].
Nusbaum N, Cheung V, et al. Role of first responders in detecting and evaluating elders at risk. Arch Gerontol Geriatr. 2006;43(3):361-367. [pmid: 16513192].
Paivio SC, Cramer KM. Factor structure and reliability of the Childhood Trauma Questionnaire in a Canadian undergraduate student sample. Child Abuse Negl. 2004;28(8):889-904. [pmid: 15350772].
Paranjape A, Rodriguez M, et al. Psychometric properties of a new scale to assess family violence in older African American women: the Family Violence Against Older Women (FVOW) Scale. Violence Against Women. 2009;15(10):1213-1226. [pmid: 19710297].
Parkinson GW, Adams RC, et al. Maternal domestic violence screening in an office-based pediatric practice. Pediatrics. 2001;108(3):1-9. [pmid: 11433046].
Peterson L, Tremblay G, et al. The parental daily diary: a sensitive measure of the process of change in a child maltreatment prevention program. Behav Modifi. 2002;26(5):627-47.
Pierce MC, Kaczor K, et al. Bruising characteristics discriminating physical child abuse from accidental trauma. Pediatrics. 2010;125(1):67-74. [pmid: 19969620].
Plazaola-Castano J, Ruiz-Perez I, et al. Validation of the Spanish version of the Index of Spouse Abuse. J Womens Health. 2009;18(4):499-506.
Pless IB, Sibald AD, et al. A reappraisal of the frequency of child abuse seen in pediatric emergency rooms. Child Abuse Negl. 1987;11(2):193-200. [pmid: 3496143].
Powers LE, Renker P, et al. Interpersonal violence and women with disabilities: analysis of safety promoting behaviors. Violence Against Women. 2009;15(9):1040-1069. [pmid: 19608856].
Prosser LA, Corso PS. Measuring health-related quality of life for child maltreatment: a systematic literature review. Health Qual Life Outcomes. 2007;5:42. [pmid: 17634122].
Ramirez IL, Straus MA. The effect of question order on disclosure of intimate partner violence: an experimental test using the Conflict Tactics Scales. J Fam Violence. 2006;21(1):1-9.
Regan KV, Bartholomew K, et al. Measuring physical violence in male same-sex relationships: an item response theory analysis of the Conflict Tactics Scales. J Interpers Violence. 2002;17(3):235-252.
Reichenheim ME, Klein R, et al. Assessing the physical violence component of the Revised Conflict Tactics Scales when used in heterosexual couples: an item response theory analysis. Cad Saude Publica. 2007;23(1):53-62. [pmid: 17187104].
Reichenheim ME, Moraes CL. Psychometric properties of the Portuguese version of the Conflict Tactics Scales Parent-Child Version (CTSPC) used to identify child abuse. Cad Saude Publica. 2006;22(3):503-515. [pmid: 16583094].
Renker PR, Tonkin P. Postpartum women’s evaluations of an audio/video computer-assisted perinatal violence screen. Comput Inform Nurs. 2007;25(3):139-47. [pmid: 17496478].
Rickert VI, Davison LL, et al. A randomized trial of screening for relationship violence in young women. J Adolesc Health. 2009;45(2):163-170. [pmid: 19628143].
Robertson KR, Milner JS. Construct validity of the Child Abuse Potential Inventory. J Clin Psychol. 1983;39(3):426-429. [pmid: 6874976].
Russell BS. Revisiting the measurement of shaken baby syndrome awareness. Child Abuse Negl. 2010;34(9):671-676. [pmid: 20638721].
Scafidi EC. Understanding partner psychological abuse and depressive symptoms: a new measure and a new theoretical model. New Brunswick, NJ. Rutgers, The State University of New Jersey. 2007.
Schafer SD, Drach LL, et al. Using diagnostic codes to screen for intimate partner violence in Oregon emergency departments and hospitals. Pub Health Rep. 2008;123(5):628-635. [pmid: 18828418].
Schofield MJ, Mishra GD. Validity of self-report screening scale for elder abuse: Women’s Health Australia Study. Gerontologist. 2003;43(1):110-120. [pmid: 12604752].
Schofield MJ, Reynolds R, et al. Screening for vulnerability to abuse among older women: Women’s Heath Australia Study. J Appl Gerontol. 2002;21(1):24-39.
Schwartz L, Jensen MP, et al. The development and psychometric evaluation of an instrument to assess spouse responses to pain and well behavior in patients with chronic pain: the Spouse Response Inventory. J Pain. 2005;6(4):243-252. [pmid: 15820912].
Shackelford TK, Goetz AT. Men’s sexual coercion in intimate relationships: development and initial validation of the Sexual Coercion in Intimate Relationships Scale. Violence Vict. 2004;19(5):541-556. [pmid: 15844724].
Shaffer A, Huston L, et al. Identification of child maltreatment using prospective and self-report methodologies: a comparison of maltreatment incidence and relation to later psychopathology. Child Abuse Negl. 2008;32(7):682-692. [pmid: 18638626].
Short LM, Rodriguez R. Testing an intimate partner violence assessment icon form with battered migrant and seasonal farmworker women. Women Health. 2002;35(2–3):181-192. [pmid: 12201507].
Slep AM, Heyman RE. Severity of partner and child maltreatment: reliability of scales used in America’s largest child and family protection agency. J Fam Violence. 2004;19:95-106.
Sprecher AG, Muelleman RL, et al. A neural network model analysis to identify victims of intimate partner violence. Am J Emerg Med. 2004;22(2):87-89. [pmid: 15011219].
Stappenbeck CA, Fals-Stewart W. Measuring intimate partner violence: a comparison of the Conflict Tactics Scale and the Timeline Followback Spousal Violence Interview. Morgan JP, editor. Focus on Aggression Research. Hauppauge, NY. Nova Science. 2004.
Straus MA, Douglas EM. A short form of the Revised Conflict Tactics Scales, and typologies for severity and mutuality. Violence Vict. 2004;19(5):507-520. [pmid: 15844722].
Svavarsdottir EK. Detecting intimate partner abuse within clinical settings: self-report or an interview. Scand J Caring Sci. 2010;24(2):224-232. [pmid: 20230520].
Thombs BD. Measurement Invariance of the Childhood Trauma Questionnaire Across Gender and Race/Ethnicity: Applications of Structural Equation Modeling and Item Response Theory (TEXAS). New York. Fordham University. 2005.
Thombs BD, Bernstein DP, et al. A validation study of the Dutch Childhood Trauma Questionnaire-Short Form: factor structure, reliability, and known-groups validity. Child Abuse Negl. 2009;33(8):518-523. [pmid: 19758699].
Thombs BD, Bernstein DP, et al. An evaluation of screening questions for childhood abuse in 2 community samples: implications for clinical practice. Arch Intern Med. 2006;166(18):2020-2026. [pmid: 17030837].
Tilden VP, Shepherd P. Increasing the rate of identification of battered women in an emergency department: use of a nursing protocol. Res Nurs Health. 1987;10(4):209-224. [pmid: 3503315].
Torres A, Navarro P, et al. Detecting domestic violence: Spanish external validation of the Index of Spouse Abuse. J Fam Violence. 2010;25(3):275-286.
Trautman DE, McCarthy ML, et al. Intimate partner violence and emergency department screening: computerized screening versus usual care. Ann Emerg Med. 2007;49:526-34. [pmid: 17276547].
Uchison TJ. Using the CBCL to Screen for Maltreatment in Young Children. Keene, NH. Antioch University New England. 2007.
Vega EM, O’Leary KD. Reaction time and item presentation factors in the self-report of partner aggression. Violence Vict. 2006;96(4):519-532. [pmid: 16897918].
Veltman MW, Browne KD. Identifying abused children using assessments and observations in the classroom: a preliminary study. Child Abuse Rev. 2003;12(5):315-334.
Vivilaki VG, Dafermos V, et al. Identifying intimate partner violence during the postpartum period in a Greek sample. Arch Womens Mental Health. 2010;13(6):467-476.
Wahl RA, Sisk DJ, et al. Clinic-based screening for domestic violence: use of a child safety questionnaire. BMC Med. 2004;2:25. [pmid: 15228622].
Waller A, Hohenhaus S, et al. Development and validation of an emergency department screening and referral protocol for victims of domestic violence. Ann Emerg Med. 1996;27(6):754-760. [pmid: 8644964].
Walsh CA, MacMillan HL, et al. Measurement of victimization in adolescence: development and validation of the Childhood Experiences of Violence Questionnaire. Child Abuse Negl. 2008;32(11):1037-1057. [pmid: 18992940].
Webster J, Holt V. Screening for partner violence: direct questioning or self-report?. Obstet Gynecol. 2004;103(2):299-303. [pmid: 14754699].
Wrangle J, Fisher JW, et al. Ha sentido sola? Culturally competent screening for intimate partner violence in Latina women. J Womens Health. 2008;17(2):261-268.

### Wrong Intervention

Acierno R, Resnick H, et al. Assessing elder victimization—demonstration of a methodology. Soc Psychiatry Psychiatr Epidemiol. 2003;38(11):644-653. [pmid: 14614553].
Backos AK. Indicators of PTSD in the Draw-a-Person and Kinetic Family Drawing With Mothers and Children Exposed to Domestic Violence. San Francisco. Alliant International University. 2010.
Baird S, Jenkins SR. Vicarious traumatization, secondary traumatic stress, and burnout in sexual assault and domestic violence agency staff. Violence Vict. 2003;18(1):71-86. [pmid: 12733620].
Barlow J, Smailagic N, et al. Individual and group based parenting programmes for improving psychosocial outcomes for teenage parents and their children. Cochrane Database Syst Rev. 2011;5:CD002964. [pmid: 21412881].
Bennett L, Riger S, et al. Effectiveness of hotline, advocacy, counseling, and shelter services for victims of domestic violence: a statewide evaluation. J Interpers Violence. 2004;19:815-29. [pmid: 15186538].
Berk RA, Campbell A, et al. The deterrent effect of arrest in incidents of domestic violence: a Bayesian analysis of four field experiments. Am Sociol Rev. 1992;57(5):698-708.
Berzin SC, Cohen E, et al. Does family group decision making affect child welfare outcomes? Findings from a randomized control study. Child Welfare. 2008;87(4):35-54. [pmid: 19391466].
Brown SD. An Investigation of Trauma Symptom Reduction in a Clinical Sample of Sexually Abused Children Using the Trauma Symptom Checklist for Children. Atlanta. Georgia State University. 2008.
Calderon SH, Gilbert P, et al. Cueing prenatal providers effects on discussions of intimate partner violence. Am J Prev Med. 2008;34(2):134-137. [pmid: 18201643].
Campbell JC, Coben JH, et al. An evaluation of a system-change training model to improve emergency department response to battered women. Acad Emerg Med. 2001;8(2):131-8. [pmid: 11157288].
Cohen JA, Mannarino AP, et al. Treating sexually abused children: 1 year follow-up of a randomized controlled trial. Child Abuse Negl. 2005;29(2):135-145. [pmid: 15734179].
Conley A, Berrick JD. Community-based child abuse prevention: outcomes associated with a differential response program in California. Child Maltreat. 2010;15(4):282-292. [pmid: 20647255].
Fanslow JL, Norton RN, et al. Outcome evaluation of an emergency department protocol of care on partner abuse. Aust N Z J Pub Health. 1998;22(5):598-603. [pmid: 9744216].
Finkelhor D. Prevention of sexual abuse through educational programs directed toward children. Pediatrics. 2007;120(3):640-645. [pmid: 17766537].
Gomez-Beloz A, Williams MA, et al. Intimate partner violence and risk for depression among postpartum women in Lima, Peru. Violence Vict. 2009;24(3):380-398. [pmid: 19634363].
Lefever JB, Howard KS, et al. Cell phones and the measurement of child neglect: the validity of the Parent-Child Activities Interview. Child Maltreat. 2008;13(4):320-333. [pmid: 18612039].
Lobbestael J, Arntz A, et al. Development and psychometric evaluation of a new assessment method for childhood maltreatment experiences: the Interview for Traumatic Events in Childhood (ITEC). Child Abuse Negl. 2009;33(8):505-517. [pmid: 19758701].
Madera SR, Toro-Alfonso J. Description of a domestic violence measure for Puerto Rican gay males. J Homosex. 2005;50(1):155-173. [pmid: 16368669].
McColgan MD, Cruz M, et al. Results of a multifaceted intimate partner violence training program for pediatric residents. Child Abuse Negl. 2010;34(4):275-283. [pmid: 20303591].
McFarlane J, Malecha A, et al. Protection orders and intimate partner violence: an 18-month study of 150 black, Hispanic, and white women. Am J Pub Health. 2004;94(4):613-618. [pmid: 15054014].
McFarlane JM, Groff JY, et al. Behaviors of children exposed to intimate partner violence before and 1 year after a treatment program for their mother. Appl Nurs Res. 2005;18(1):7-12. [pmid: 15812730].
McFarlane JM, Groff JY, et al. Behaviors of children following a randomized controlled treatment program for their abused mothers. Issues Compr Pediatr Nurs. 2005;28(4):195-211. [pmid: 16356894].
McWhirter PT. Differential therapeutic outcomes of community-based group interventions for women and children exposed to intimate partner violence. J Interpers Violence. 2011;26(12):2457-2482. [pmid: 20889533].
Nagle GA. Maternal Participation, Depression and Partner Violence in a State Run Child Abuse Prevention Program: Louisiana Nurse Home Visitation 1999–2002. New Orleans. Tulane University. 2002.
Nucero P, O’Connor P. Identification of domestic violence in the emergency department. N J Nurse. 2002;32(7):15. [pmid: 12400198].
Padala P, Madison J, et al. Risperidone monotherapy for post-traumatic stress disorder related to sexual assault and domestic abuse in women. Int Clin Psychopharmacol. 2006;21:275-80. [pmid: 16877898].
Palmer S, Stalker CA, et al. Balancing positive outcomes with vicarious traumatization: participants’ experiences with group treatment for long-term effects of childhood abuse. Soc Work Groups. 2007;30(4):59-77.
Reich DB, Winternitz S, et al. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. J Clin Psychiatry. 2004;65(12):1601-1606. [pmid: 15641864].
Resick PA, Nishith P, et al. How well does cognitive-behavioral therapy treat symptoms of complex PTSD? An examination of child sexual abuse survivors within a clinical trial. CNS Spectr. 2003;8(5):340-355. [pmid: 12766690].
Ruch LO, Wang CH. Validation of the Sexual Assault Symptom Scale II (SASS II) using a panel research design. J Interpers Violence. 2006;21(11):1440-1461. [pmid: 17057161].
Schultz PN, Remick-Barlow GA, et al. Equine-assisted psychotherapy: a mental health promotion/intervention modality for children who have experienced intra-family violence. Health Soc Care Community. 2007;15(3):265-271. [pmid: 17444990].
Short LM, Alpert E, et al. A tool for measuring physician readiness to manage intimate partner violence. Am J Prev Med. 2006;30(2):173-180. [pmid: 16459217].
Short LM, Hadley SM, et al. Assessing the success of the WomanKind program: an integrated model of 24-hour health care response to domestic violence. Women Health. 2002;35(2–3):101-119. [pmid: 12201502].
Sikkema KJ, Hansen NB, et al. Outcomes from a group intervention for coping with HIV/AIDS and childhood sexual abuse: reductions in traumatic stress. AIDS Behav. 2007;11(1):49-60. [pmid: 16858634].
Simpson LE, Atkins DC, et al. Low-level relationship aggression and couple therapy outcomes. J Fam Psychol. 2008;22(1):102-111. [pmid: 18266537].
Smith N, Lam D, et al. Childhood experience of care and abuse questionnaire (CECA.Q): validation of a screening instrument for childhood adversity in clinical populations. Soc Psychiatry Psychiatr Epidemiol. 2002;37(12):572-579. [pmid: 12545234].
Stader SR, Holmes GR, et al. Comparison of scores for abused and nonabused young adults on the Psychological Trauma and Resources Scale. Psychol Rep. 2004;94(2):687-693. [pmid: 15154203].
Thomas R, Zimmer-Gembeck MJ. Accumulating evidence for parent-child interaction therapy in the prevention of child maltreatment. Child Dev. 2011;82(1):177-192. [pmid: 21291436].
Timmer SG, Urquiza AJ, et al. Parent-child interaction therapy: application to maltreating parent-child dyads. Child Abuse Negl. 2005;29(7):825-842. [pmid: 16051355].
Tourigny M, Hebert M, et al. Efficacy of a group therapy for sexually abused adolescent girls. J Child Sex Abuse. 2005;14(4):71-93.
Vreeman RC, Carroll AE. A systematic review of school-based interventions to prevent bullying. Arch Pediatr Adolesc Med. 2007;161(1):78-88. [pmid: 17199071].
Wallis DA. Reduction of trauma symptoms following group therapy. Aust N Z J Psychiatry. 2002;36(1):67-74. [pmid: 11929440].
Wolfe DA, Crooks C, et al. A school-based program to prevent adolescent dating violence: a cluster randomized trial. Arch Pediatr Adolesc Med. 2009;163(8):692-699. [pmid: 19652099].
Wright DC, Woo WL, et al. An investigation of trauma-centered inpatient treatment for adult survivors of abuse. Child Abuse Negl. 2003;27(4):393-406. [pmid: 12686324].
Yoshihama M, Clum K, et al. Measuring the lifetime experience of domestic violence: application of the life history calendar method. Violence Vict. 2002;17(3):297-317. [pmid: 12102055].
Young CA, Douglass JP. Use of, and outputs from, an assault patient questionnaire within accident and emergency departments on Merseyside. Emerg Med J. 2003;20(3):232-237. [pmid: 12748137].

### Wrong Outcome

Bair-Merritt MH, Feudtner C, et al. Screening for intimate partner violence using an audiotape questionnaire: a randomized clinical trial in a pediatric emergency department. Arch Pediatr Adolesc Med. 2006;160(3):311-316. [pmid: 16520452].
Barr R, Barr M, et al. Do educational materials change knowledge and behavior about crying and shaken baby syndrome? A randomized controlled trial. Can Med Assoc J. 2009;180:727-733. [pmid: 19255065].
Blackmore ER, Carroll J, et al. The use of the Antenatal Psychosocial Health Assessment (ALPHA) tool in the detection of psychosocial risk factors for postpartum depression: a randomized controlled trial. J Obstet Gynaecol Can. 2006;28(10):873-878. [pmid: 17140502].
Bonds DE, Ellis SD, et al. Patient attitudes toward screening. N C Med J. 2007;68(1):23-29. [pmid: 17500428].
Bullock LF, Browning C, et al. Telephone social support for low-income pregnant women. J Obstet Gynecol Neonat Nurs. 2002;31(6):658-664.
Cattaneo LB, Bell ME, et al. Intimate partner violence victims’ accuracy in assessing their risk of re-abuse. J Fam Violence. 2007;22(6):429-440.
Chen PH, Rovi S, et al. Randomized comparison of 3 methods to screen for domestic violence in family practice. Ann Fam Med. 2007;5(5):430-435. [pmid: 17893385].
Conners NA, Whiteside-Mansell L, et al. Measuring the potential for child maltreatment: the reliability and validity of the Adult Adolescent Parenting Inventory–2. Child Abuse Negl. 2006;30(1):39-53. [pmid: 16406026].
Crouch JL, Skowronski JJ, et al. Parental responses to infant crying: the influence of child physical abuse risk and hostile priming. Child Abuse Negl. 2008;32:702-710. [pmid: 18606450].
Daly JM, Jogerst GJ. Readability and content of elder abuse instruments. J Elder Abuse Negl. 2005;17(4):31-52. [pmid: 17050491].
Datner EM, O’Malley M, et al. Universal screening for interpersonal violence: inability to prove universal screening improves provision of services. Eur J Emerg Med. 2004;11(1):35-38. [pmid: 15167191].
Daugherty JD, Houry DE. Intimate partner violence screening in the emergency department. J Postgrad Med. 2008;54(4):301-305. [pmid: 18953150].
DePanfilis D, Zuravin SJ. The effect of services on the recurrence of child maltreatment. Child Abuse Negl. 2002;26(2):187-205. [pmid: 11933989].
DiLillo D, DeGue S, et al. Participant responses to retrospective surveys of child maltreatment: does mode of assessment matter?. Violence Vict. 2006;21(4):410-424. [pmid: 16897910].
Duggan A, Fuddy L, et al. Randomized trial of a statewide home visiting program to prevent child abuse: impact in reducing parental risk factors. Child Abuse Negl. 2004;28:625-45.
Duggan A, Fuddy L, et al. Evaluating a statewide home visiting program to prevent child abuse in at-risk families of newborns: fathers’ participation and outcomes. Child Maltreat. 2004;9(1):3-17. [pmid: 14870994].
Eckenrode J, Campa M, et al. Long-term effects of prenatal and infancy nurse home visitation on the life course of youths: 19-year follow-up of a randomized trial. JAMA. 2010;164:9-15.
Edelen MO, McCaffrey DF, et al. Measurement of teen dating violence attitudes: an item response theory evaluation of differential item functioning according to gender. J Interpers Violence. 2009;24(8):1243-1263. [pmid: 18701746].
Enriquez M, Cheng AL, et al. Development and feasibility of an HIV and IPV prevention intervention among low-income mothers receiving services in a Missouri day care center. Violence Against Women. 2010;16(5):560-578. [pmid: 20388931].
Fernandez-Fuertes AA, Fuertes A, et al. Assessment of violence in adolescent couples: validation of the Conflict in Adolescent Dating Relationships Inventory (CADRI)- Spanish version. Int J Clin Health Psychol. 2006;6(2):339-358.
Fleegler EW, Lieu TA, et al. Families’ health-related social problems and missed referral opportunities. Pediatrics. 2007;119(6):e1332-1341. [pmid: 17545363].
Furniss K, McCaffrey M, et al. Nurses and barriers to screening for intimate partner violence. MCN Am J Matern Child Nurs. 2007;32(4):238-243. [pmid: 17667289].
Gillum TL, Sun CJ, et al. Can a health clinic-based intervention increase safety in abused women? Results from a pilot study. J Womens Health. 2009;18(8):1259-1264.
Glowa PT, Frasier PY, et al. Increasing physician comfort level in screening and counseling patients for intimate partner violence: hands-on practice. Patient Educ Couns. 2002;46(3):213-220. [pmid: 11932119].
Glowa PT, Frazier PY, et al. What happens after we identify intimate partner violence? The family physician’s perspective. Fam Med. 2003;35(10):730-736. [pmid: 14603406].
Goff HW, Shelton A, et al. Preparedness of health care practitioners to screen women for domestic violence in a border community. Health Care Women Int. 2003;24(2):135-148. [pmid: 12746023].
Grafton D, Wright BL, et al. Successful implementation of universal woman abuse inquiry. Pub Health Nurs. 2006;23(6):535-540. [pmid: 17096779].
Graham-Bermann SA, Lynch S, et al. Community-based intervention for children exposed to intimate partner violence: an efficacy trial. J Consult Clin Psychol. 2007;75(2):199-209. [pmid: 17469878].
Green CE Jr. Intimate partner violence and health care utilization: a randomized controlled trial. Houston, TX. University of Houston. 2005.
Gutmanis I, Beynon C, et al. Factors influencing identification of and response to intimate partner violence: a survey of physicians and nurses. BMC Pub Health. 2007;7:12. [pmid: 17250771].
Heckert D, Gondolf EW. Battered women’s perceptions of risk versus risk factors and instruments in predicting repeat reassault. J Interpers Violence. 2004;19(7):778-800. [pmid: 15186536].
Higgins LP, Hawkins JW. Screening for abuse during pregnancy: implementing a multisite program. MCN Am J Matern Child Nurs. 2005;30(2):109-114. [pmid: 15775806].
Hiscock H, Bayer JK, et al. Universal parenting programme to prevent early childhood behavioural problems: cluster randomised trial. Br Med J. 2008;336(7639):318-321. [pmid: 18244958].
Humphreys J, Tsoh JY, et al. Increasing discussions of intimate partner violence in prenatal care using Video Doctor plus provider cueing: a randomized, controlled trial. Womens Health Issues. 2011;21(2):136-144. [pmid: 21185737].
Jack SM, Jamieson E, et al. The feasibility of screening for intimate partner violence during postpartum home visits. Can J Nurs Res. 2008;40(2):150-170. [pmid: 18714904].
Jonassen J, Mazor K. Identification of physician and patient attributes that influence the likelihood of screening for intimate partner violence. Acad Med. 2003;78(10 Suppl):S20-3. [pmid: 14557085].
Joseph JG, El-Mohandes AA, et al. Reducing psychosocial and behavioral pregnancy risk factors: results of a randomized clinical trial among high-risk pregnant African American women. Am J Pub Health. 2009;99(6):1053-1061. [pmid: 19372532].
Katz C, Hershkowitz I. The effects of drawing on children’s accounts of sexual abuse. Child Maltreat. 2010;15(2):171-179. [pmid: 19926626].
Katz KS, Blake SM, et al. The design, implementation and acceptability of an integrated intervention to address multiple behavioral and psychosocial risk factors among pregnant African American women. BMC Pregnancy Childbirth. 2008;8(1):22. [pmid: 18578875].
Kim J, Dubowitz H, et al. Comparison of 3 data collection methods for gathering sensitive and less sensitive information. Ambul Pediatr. 2008;8(4):255-260. [pmid: 18644548].
Kitzman H, Olds DL, et al. Enduring effects of prenatal and infancy home visiting by nurses on children: follow-up of a randomized trial among children at age 12 years. Arch Pediatr Adolesc Med. 2010;164(5):412-418.
Kosterman R, Hawkins JD, et al. Preparing for the drug free years: session-specific effects of a universal parent-training intervention with rural families. J Drug Educ. 2001;31(1):47-68. [pmid: 11338965].
Krugman SD, Witting MD, et al. Perceptions of help resources for victims of intimate partner violence. J Interpers Violence. 2004;19(7):766-777. [pmid: 15186535].
Lane WG, Dubowitz H. Primary care pediatricians’ experience, comfort and competence in the evaluation and management of child maltreatment: do we need child abuse experts?. Child Abuse Negl. 2009;33(2):76-83. [pmid: 19278726].
Leppakoski T, Astedt-Kurki P, et al. Identification of women exposed to acute physical intimate partner violence in an emergency department setting in Finland. Scand J Caring Sci. 2010;24(4):638-647. [pmid: 20487409].
McCord-Duncan EC, Floyd M, et al. Detecting potential intimate partner violence: which approach do women want?. Fam Med. 2006;38(6):416-422. [pmid: 16741840].
McCurdy K. Risk assessment in child abuse prevention programs. Soc Work Res. 1995;19:77-87.
McFarlane J, Malecha A, et al. Increasing the safety-promoting behaviors of abused women. Am J Nurs. 2004;104(3):40-50. [pmid: 15108570].
McGuigan WM, Katzev AR, et al. Multi-level determinants of retention in a home-visiting child abuse prevention program. Child Abuse Negl. 2003;27(4):363-380. [pmid: 12686322].
Melendez RM, Hoffman S, et al. Intimate partner violence and safer sex negotiation: effects of a gender-specific intervention. Arch Sex Behav. 2003;32(6):499-511. [pmid: 14574094].
Miller E, Decker MR, et al. Pregnancy coercion, intimate partner violence and unintended pregnancy. Contraception. 2010;81(4):316-322. [pmid: 20227548].
Neale AV, Hwalek MA, et al. Validation of the Hwalek-Sengstock elder abuse screening test. J Appl Gerontol. 1991;10(4):406-418.
Nelson CS, Higman SM, et al. Medical homes for at-risk children: parental reports of clinician-parent relationships, anticipatory guidance, and behavior changes. Pediatrics. 2005;115(1):48-56. [pmid: 15629981].
Norton I, Schauer J. A hospital-based domestic violence group. Psychiatr Serv. 1997;48:1186-90. [pmid: 9285981].
Ondersma SJ, Svikis DS, et al. Computer-based brief intervention: a randomized trial with postpartum women. Am J Prev Med. 2007;32(3):231-238. [pmid: 17236741].
Oschwald M, Renker P, et al. Development of an accessible Audio Computer-Assisted Self-Interview (A-CASI) to screen for abuse and provide safety strategies for women with disabilities. J Interpers Violence. 2009;24(5):795-818. [pmid: 18515785].
Owen-Smith A, Hathaway J, et al. Screening for domestic violence in an oncology clinic: barriers and potential solutions. Oncol Nurs Forum. 2008;35(4):625-633. [pmid: 18591166].
Post LA, Klevens J, et al. An examination of whether coordinated community responses affect intimate partner violence. J Interpers Violence. 2010;25(1):75-93. [pmid: 19196879].
Pruitt DL, Erickson MT. The Child Abuse Potential Inventory: a study of concurrent validity. J Clin Psychol. 1985;41(1):104-111. [pmid: 3973031].
Ramsay J, Richardson J, et al. Should health professionals screen women for domestic violence? Systematic review. BMJ. 2002;325(7359):314. [pmid: 12169509].
Reynolds AJ, Temple JA, et al. Effects of a school-based, early childhood intervention on adult health and well-being: a 19-year follow-up of low-income families. Arch Pediatr Adolesc Med. 2007;161(8):730-739. [pmid: 17679653].
Rhodes KV, Frankel RM, et al. You’re not a victim of domestic violence, are you? Provider patient communication about domestic violence. Ann Intern Med. 2007;147(9):620-627. [pmid: 17975184].
Richard L, Gauvin L, et al. Integrating the ecological approach in health promotion for older adults: a survey of programs aimed at elder abuse prevention, falls prevention, and appropriate medication use. Int J Pub Health. 2008;53(1):46-56. [pmid: 18522369].
Robinson-Whelen S, Hughes RB, et al. Efficacy of a computerized abuse and safety assessment intervention for women with disabilities: a randomized controlled trial. Rehab Psychol. 2010;55(2):97-107.
Rodriguez ML, Dumont K, et al. Effects of Healthy Families New York on the promotion of maternal parenting competencies and the prevention of harsh parenting. Child Abuse Negl. 2010;34(10):711-723. [pmid: 20850872].
Russa MB, Rodriguez CM. Physical discipline, escalation, and child abuse potential: psychometric evidence for the Analog Parenting Task. Aggress Behav. 2010;36:251-60. [pmid: 20540158].
Savell JK, Kinder BN, et al. Effects of administering sexually explicit questionnaires on anger, anxiety, and depression in sexually abused and nonabused females: implications for risk assessment. J Sex Marital Ther. 2006;32(2):161-172. [pmid: 16418106].
Schofield MJ, Mishra GD. Three year health outcomes among older women at risk of elder abuse: Women’s Health Australia. Qual Life Res. 2004;13(6):1043-1052. [pmid: 15287271].
Scholle SH, Buranosky R, et al. Routine screening for intimate partner violence in an obstetrics and gynecology clinic. Am J Pub Health. 2003;93(7):1070-1072. [pmid: 12835182].
Siemieniuk RA, Krentz HB, et al. Domestic violence screening: prevalence and outcomes in a Canadian HIV population. AIDS Patient Care STDS. 2010;24(12):763-770. [pmid: 21138382].
Smith CO, Thompson MP, et al. Service utilization patterns of maltreated and nonmaltreated children from low-income, African-American families. Psychiatr Serv. 2009;60:1386-9. [pmid: 19797382].
Spangaro JM, Zwi AB, et al. Who tells and what happens: disclosure and health service responses to screening for intimate partner violence. Health Soc Care Community. 2010;18(6):671-680. [pmid: 20637041].
Stayton CD, Duncan MM. Mutable influences on intimate partner abuse screening in health care settings: a synthesis of the literature. Trauma Violence Abuse. 2005;6(4):271-285. [pmid: 16217117].
Straus H, Cerulli C, et al. Intimate partner violence and functional health status: associations with severity, danger, and self-advocacy behaviors. J Womens Health. 2009;18:625-31.
Thombs BD, Bennett W, et al. Cultural sensitivity in screening adults for a history of childhood abuse: evidence from a community sample. J Gen Intern Med. 2007;22(3):368-373. [pmid: 17356970].
Tyrka AR, Price LH, et al. Childhood maltreatment and telomere shortening: preliminary support for an effect of early stress on cellular aging. Biol Psychiatr. 2010;67(6):531-534.
Wathen CN, Jamieson E, et al. 2007. Risk indicators to identify intimate partner violence in the emergency department. Open Med. 2007;1(2):113-122.
Zelenko MA, Huffman LC, et al. The Child Abuse Potential Inventory and pregnancy outcome in expectant adolescent mothers. Child Abuse Negl. 2001;25:1481-1495. [pmid: 11766012].
Zielinski DS, Eckenrode J, et al. Nurse home visitation and the prevention of child maltreatment: impact on the timing of official reports. Dev Psychopathol. 2009;21(2):441-453. [pmid: 19338692].
Zink T, Fisher BS. Family violence quality assessment tool for primary care offices. Qual Manag Health Care. 2007;16(3):265-279. [pmid: 17627222].
Zink T, Siegel R, et al. Physician knowledge and management of children exposed to domestic violence in Ohio: a comparison of pediatricians and family physicians. Clin Pediatr. 2005;44(3):211-219.
Zun L. Violence prevention in the ED. Am J Emerg Med. 2003;21(6):454-457. [pmid: 14574650].
Zun LS, Downey LV, et al. Violence prevention in the ED: linkage of the ED to a social service agency. Am J Emerg Med. 2003;21(6):454-457. [pmid: 14574650].

### Wrong Study Design for Key Question

Bradshaw JM. Preventing Shaken Baby Syndrome: A Comparison of Two Parent Education Programs. Storrs, CT. University of Connecticut. 2011.
Dias MS, Smith K, et al. Preventing abusive head trauma among infants and young children: a hospital-based, parent education program. Pediatrics. 2005;115(4):e470-477. [pmid: 15805350].
Eckenrode J, Powers J, et al. Long-term effects of early home visitation on rates of state-verified cases of child abuse and neglect [abstract]. Pediatr Res. 1996;39:104.
El-Mohandes A, Kiely M, et al. Reduction of intimate partner violence in pregnancy: the effect of an integrated intervention in an African-American low income population [abstract]. Proceedings of the 16th Pediatric Academic Societies Annual Meeting. 2005 May 14–17. Washington, DC.
Grant TM, Ernst CC, et al. An intervention with high-risk mothers who abuse alcohol and drugs: the Seattle advocacy model. Am J Pub Health. 1996;86(12):1816-1817. [pmid: 9003147].
Mercier CE, Barry SE, et al. Improving newborn preventive services at the birth hospitalization: a collaborative, hospital-based quality-improvement project. Pediatrics. 2007;120(3):481-8. [pmid: 17766519].

### No Primary Data, Editorial, Non-Systematic Review

Telephone intervention works to stop intimate partner violence. J Psychosoc Nurs Mental Health Serv. 2004;42(6):12-13.
Anderson CL. The Parenting Profile Assessment: screening for child abuse. Appl Nurs Res. 1996;6(1):31-38. [pmid: 8439176].
Aneja S, Gottlieb AS, et al. Physician intervention for intimate partner violence. Med Health R I. 2009;92(9):307-309. [pmid: 19842528].
Annan S. Sexual violence in rural areas: a review of the literature. Fam Community Health. 2006;29(3):164-168. [pmid: 16775466].
Anthony EK, Lehning AJ, et al. Assessing elder mistreatment: instrument development and implications for adult protective services. J Gerontol Soc Work. 2009;52(8):815-836. [pmid: 19830609].
American Medical Association. National Advisory Council on Violence and Abuse. Policy Compendium. Washington, DC. American Medical Association. 2008. Accessed at http://www.ama-assn.org/ama1/pub/upload/mm/386/vio_policy_comp.pdf. 25 April 2012.
Auchter B. Interventing with domestic violence offenders: introduction. Violence Against Women. 2008;14(2):131-135. [pmid: 18335639].
Baldry AC, Winkel FW. Intimate Partner Violence Prevention and Intervention: The Risk Assessment and Management Approach. Hauppauge, NY. Nova Science. 2008.
Barr RG, Runyan D. Inflicted childhood neurotrauma: the problem set and challenges to measuring incidence. Am J Prev Med. 2008;34(4 Suppl 1):S106-11. [pmid: 18374258].
Barth RP. Preventing child abuse and neglect with parent training: evidence and opportunities. Future Child. 2009;19(2):95-118. [pmid: 19719024].
Bomba PA. Use of a single page elder abuse assessment and management tool: a practical clinician’s approach to identifying elder mistreatment. J Gerontol Soc Work. 2006;46(3–4):103-122. [pmid: 16803779].
Brown K, Streubert GE, et al. Effectively detect and manage elder abuse. Nurs Pract. 2004;29(8):22-27.
Burgess AW, Roberts AR, et al. The stress-crisis continuum: its application to domestic violence. Roberts AR, editor. Battered Women and Their Families: Intervention Strategies and Treatment Programs. 3rd ed. New York. Springer. 2007.
Campbell J, Glass N. Safety planning, danger, and lethality assessment. Mitchell C, Anglin D, editors. Intimate Partner Violence: A Health-Based Perspective. New York. Oxford University Press. 2009.
Campbell JC. Health consequences of intimate partner violence. Lancet. 2002;359(9314):1331-6. [pmid: 11965295].
Carney DM, McKibbin L. Screening for domestic violence. J Nurs Manag. 2003;34(9):35-36.
Chapin MG, Mackie CF. Research evidence to update practice guidelines for domestic violence screening in military settings. Mil Med. 2007;172(7):ii-iv. [pmid: 17691676].
Cole TB. Is domestic violence screening helpful?. JAMA. 2000;284(5):551-553. [pmid: 10918685].
Colombini M, Mayhew S, et al. Health-sector responses to intimate partner violence in low- and middle-income settings: a review of current models, challenges and opportunities. Bull World Health Organ. 2008;86(8):635-642. [pmid: 18797623].
Donelan-McCall N, Eckenrode J, et al. Home visiting for the prevention of child maltreatment: lessons learned during the past 20 years. Pediatr Clin North Am. 2009;56(2):389-403. [pmid: 19358923].
Dubowitz H. Tackling child neglect: a role for pediatricians. Pediatr Clin North Am. 2009;56(2):363-378. [pmid: 19358921].
Edleson JL, Ellerton AL, et al. Assessing child exposure to adult domestic violence. Child Youth Serv Rev. 2007;29(7):961-971.
Edwards A, Lutzker JR. Iterations of the SafeCare model: an evidence-based child maltreatment prevention program. Behav Modif. 2008;32(5):736-756. [pmid: 18441332].
Escriba-Aguir V, Ruiz-Perez I, et al. Screening for domestic violence during pregnancy. J Psychosom Obstet Gynaecol. 2007;28(3):133-134. [pmid: 17577754].
Feindler EL, Rathus JH, et al. Assessment of Family Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2003.
Feindler EL, Rathus JH, et al. Interview methods. Assessment of Family Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2003.
Feindler EL, Rathus JH, et al. Self-report inventories. Assessment of Family Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2003.
Feindler EL, Rathus JH, et al. Self-report inventories for the assessment of children. Assessment of Family Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2003.
Finn J, Atkinson T. Promoting the safe and strategic use of technology for victims of intimate partner violence: evaluation of the Technology Safety Project. Violence Against Women. 2009;15(11):1402-1414. [pmid: 19809100].
Ford-Gilboe M, Wuest J, et al. Developing an evidence-based health advocacy intervention for women who have left an abusive partner. Can J Nurs Res. 2006;38(1):147-167. [pmid: 16671285].
Fulmer T. Screening for mistreatment of older adults. Am J Nurs. 2008;108(12):52-59. [pmid: 19033914].
Fulmer T, Guadagno L, et al. Progress in elder abuse screening and assessment instruments. J Am Geriatr Soc. 2004;52(2):297-304. [pmid: 14728644].
Family Violence Prevention Fund. National Consensus Guidelines on Identifying and Responding to Domestic Violence Victimization in Health Care Settings. Washington, DC. Family Violence Prevention Fund. 2004. Accessed at http://www.futureswithoutviolence.org/userfiles/file/Consensus.pdf. 25 April 2012.
Gillum TL. The benefits of a culturally specific intimate partner violence intervention for African American survivors. Violence Against Women. 2008;14(8):917-943. [pmid: 18667406].
Gillum TL. Improving services to African American survivors of IPV: from the voices of recipients of culturally specific services. Violence Against Women. 2009;15(1):57-80. [pmid: 19015390].
Goodyear-Smith F. National screening policies in general practice: a case study of routine screening for partner abuse. Appl Health Econ Health Policy. 2002;1(4):197-209. [pmid: 14619249].
Gupton S. Always believe. Ann Emerg Med. 2002;40(1):122-123. [pmid: 12085085].
Harris MH, Weber M. Providing crisis counselors on-site to victims of domestic violence in the emergency department: a report of a local pilot project. S D J Med. 2002;55(4):147-149. [pmid: 11977868].
Hawkins JW, Pearce CW, et al. Using technology to expedite screening and intervention for domestic abuse and neglect. Pub Health Nurs. 2009;26(1):58-69. [pmid: 19154193].
Hayward S. Nurse home visits reduced child abuse and neglect over a 15 year period. Evid Based Nurs. 1998;1(3):77.
Hegarty K. The health consequences of child sexual abuse and partner abuse for women attending general practice. Aust Fam Physician. 2003;32(9):760. [pmid: 14524222].
Hegarty KL, Gunn JM, et al. Women’s evaluation of abuse and violence care in general practice: a cluster randomised controlled trial (WEAVE). BMC Pub Health. 2010;10:2. [pmid: 20044929].
Houry D, Bay L, et al. Arrests for intimate partner violence in female detention patients. Am J Emerg Med. 2005;23(1):96-97. [pmid: 15672349].
Howard KS, Brooks-Gunn J. The role of home-visiting programs in preventing child abuse and neglect. Future Child. 2009;19(2):119-146. [pmid: 19719025].
Hulme PA. Retrospective measurement of childhood sexual abuse: a review of instruments. Child Maltreat. 2004;9(2):201-217. [pmid: 15104889].
Hulme PA. Psychometric evaluation and comparison of three retrospective, multi-item measures of childhood sexual abuse. Child Abuse Negl. 2007;31(8):853-869. [pmid: 17825410].
Janssen P, Dascal-Weichhendler H, et al. Assessment for intimate partner violence: where do we stand?. J Am Board Fam Med. 2006;19(4):413-415. [pmid: 16809657].
Kaye LW, Kay D, et al. Intervention with abused older males: conceptual and clinical perspectives. J Elder Abuse Negl. 2007;19(1–2):153-172. [pmid: 18077275].
Klevens J, Saltzman LE. The controversy on screening for intimate partner violence: a question of semantics?. J Womens Health. 2009;18(2):143-145.
Klevens J, Whitaker DJ. Primary prevention of child physical abuse and neglect: gaps and promising directions. Child Maltreat. 2007;12(4):364-377. [pmid: 17954942].
Korfmacher J. The Kempe Family Stress Inventory: a review. Child Abuse Negl. 2000;24(1):129-140. [pmid: 10660015].
Kottwitz D, Bowling S. A pilot study of the Elder Abuse Questionnaire. Kans Nurse. 2003;78(7):4-6. [pmid: 14528596].
Koziol-Mclain J, Campbell JC. Universal screening and mandatory reporting: an update on two important issues for victims/survivors of intimate partner violence. J Emerg Nurs. 2001;27(6):602-606. [pmid: 11712019].
Kravitz JA. The SAFE ELDERS Scales: Identifying High Risk Cases of Elder Abuse. Malibu, CA. Pepperdine University. 2007.
Kropp PR. Intimate partner violence risk assessment and management. Violence Vict. 2008;23(2):202-220. [pmid: 18624090].
Krugman SD, Lane WG, et al. Update on child abuse prevention. Curr Opin Pediatr. 2007;19(6):711-718. [pmid: 18025942].
Laughon K, Renker P, et al. Revision of the Abuse Assessment Screen to address nonlethal strangulation. J Obstet Gynecol Neonat Nurs. 2008;37(4):502-507.
LeCroy CW, Krysik J. Measurement issues in home visitation: a research note. Child Youth Serv Rev. 2010;32(10):1483-1486.
Lock TG, Levis DJ, et al. The Sexual Abuse Questionnaire: a preliminary examination of a time and cost efficient method in evaluating the presence of childhood sexual abuse in adult patients. J Child Sex Abuse. 2005;14(1):1-26.
Mackay K. To screen or not to screen: identification of domestic violence in Canadian emergency departments. CJEM. 2008;10(4):329-332. [pmid: 18652723].
MacMillan HL, Wathen C. Violence against women: integrating the evidence into clinical practice. Can Med Assoc J. 2003;169(6):570-571. [pmid: 12975225].
MacMillan HL, Wathen CN, et al. Interventions to prevent child maltreatment and associated impairment. Lancet. 2009;373:250-266. [pmid: 19056113].
Marcellus L. The ethics of relation: public health nurses and child protection clients. J Adv Nurs. 2005;51(4):414-420. [pmid: 16086810].
McCaw B, Bauer HM, et al. Women referred for on-site domestic violence services in a managed care organization. Women Health. 2002;35(2–3):23-40. [pmid: 12201508].
McNutt LA, Waltermaurer E, et al. Rationale for and development of the computerized intimate partner violence screen for primary care. Fam Violence Prev Health Pract. 2005;3:1-12.
Meeks-Sjostrom D. A comparison of three measures of elder abuse. J Nurs Scholarsh. 2004;36(3):247-250. [pmid: 15495494].
Midmer D, Carroll J, et al. From research to application: the development of an antenatal psychosocial health assessment tool. Can J Pub Health. 2002;93(4):291-296. [pmid: 12154533].
Mowat A. Toolkit will help GPs detect children at risk of abuse. Practitioner. 2008;252(1706):5. [pmid: 18575383].
Naumann P, Langford D, et al. Women battering in primary care practice. Fam Pract. 1999;16(4):343-352. [pmid: 10493703].
Nelson HD. Screening for domestic violence—bridging the evidence gaps. Lancet. 2004;364(Suppl 1):S22-23. [pmid: 15967139].
Newton AW, Vandeven AM. Child abuse and neglect: a worldwide concern. Curr Opin Pediatr. 2010;22:226-233. [pmid: 20164772].
Olds DL. Prenatal and infancy home visiting by nurses: from randomized trials to community replication. Pediatrics. 2002;3(3):153-172.
Olds DL, Sadler L, et al. Programs for parents of infants and toddlers: recent evidence from randomized trials. J Child Psychol Psychiatry. 2007;48(3–4):355-391. [pmid: 17355402].
Ondersma SJ, Chaffin MJ, et al. A brief form of the Child Abuse Potential Inventory: development and validation: Erratum. J Clin Child Adolesc Psychol. 2006;35(4):598.
Petrucci CJ, Mills LG. Domestic violence assessment: current practices and new models for improved child welfare interventions. Brief Treat Crisis Interv. 2002;2(2):153-172.
Phelan MB. Screening for intimate partner violence in medical settings. Trauma Violence Abuse. 2007;8(2):199-213. [pmid: 17545574].
Plichta SB. Intimate partner violence and physical health consequences: policy and practice implications. J Interpers Violence. 2004;19(11):1296-1323. [pmid: 15534333].
Prinz RJ, Sanders MR, et al. Population-based prevention of child maltreatment: the U.S. Triple P System Population Trial. Prev Sci. 2009;10(1):1-12. [pmid: 19160053].
Proeve M. Issues in the application of Bayes’ theorem to child abuse decision making. Child Maltreat. 2009;14(1):114-120. [pmid: 18495947].
Pullen RL. Screening for abuse and neglect. Nursing. 2007;37(2):69. [pmid: 17273093].
Punukollu M. Domestic violence: screening made practical. J Fam Pract. 2003;52(7):537-543. [pmid: 12841970].
Rathus JH, Feindler EL. Self-report measures specific to the assessment of partner abuse. Assessment of Partner Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2004.
Reeves S, Wysong J. Strategies to address financial abuse. J Elder Abuse Negl. 2010;22(3–4):328-334. [pmid: 20711918].
Reynolds AJ, Mathieson LC, et al. Do early childhood interventions prevent child maltreatment? A review of research. Child Maltreat. 2009;14(2):182-206. [pmid: 19240245].
Rhodes KV, Lauderdale DS, et al. Between me and the computer: increased detection of intimate partner violence using a computer questionnaire. Ann Emerg Med. 2002;40(5):476-484. [pmid: 12399790].
Rhodes KV, Levinson W. Interventions for intimate partner violence against women: clinical applications. JAMA. 2003;289(5):601-605. [pmid: 12578493].
Russell BS, Britner PA, et al. The promise of primary prevention home visiting programs: a review of potential outcomes. J Prev Interv Community. 2007;34(1–2):129-147. [pmid: 17890197].
Scribano PV. Prevention strategies in child maltreatment. Curr Opin Pediatr. 2010;22(5):616-20. [pmid: 20829692].
Senseman RL. Screening for intimate partner violence among gay and lesbian patients in primary care. Clin Excell Nurse Pract. 2002;6(4):27-32.
Shapiro CJ, Prinz RJ, et al. Population-based provider engagement in delivery of evidence-based parenting interventions: challenges and solutions. J Prim Prev. 2010;31(4):223-234. [pmid: 20195773].
Sormanti M, Shibusawa T. Intimate partner violence among midlife and older women: a descriptive analysis of women seeking medical services. Health Soc Work. 2008;33(1):33-41. [pmid: 18326448].
Spangaro J, Zwi AB, et al. The elusive search for definitive evidence on routine screening for intimate partner violence. Trauma Violence Abuse. 2009;10(1):55-68. [pmid: 19056688].
Spangaro JM. The NSW Health routine screening for domestic violence program. N S W Pub Health Bull. 2007;18(5–6):86-89. [pmid: 17651662].
Strand VC, Sarmiento TL, et al. Assessment and screening tools for trauma in children and adolescents: a review. Trauma Violence Abuse. 2005;6(1):55-78. [pmid: 15574673].
Strecher V, Wang C, et al. Tailored interventions for multiple risk behaviors. Health Educ Res. 2002;17(5):619-626. [pmid: 12408206].
Sugg N. What do medical providers need to successfully intervene with intimate partner violence?. J Aggress Maltreat Trauma. 2006;13(3–4):101-120.
Taft A, Hegarty K, et al. Screening women for intimate partner violence in health care settings: protocol. Cochrane Database Syst Rev. 2009.
Taft AJ, Hegarty KL. Intimate partner violence against women: what outcomes are meaningful?. JAMA. 2010;304(5):577-579. [pmid: 20682943].
Taft AJ, Small R, et al. MOSAIC (Mothers’ Advocates in the Community): protocol and sample description of a cluster randomised trial of mentor mother support to reduce intimate partner violence among pregnant or recent mothers. BMC Pub Health. 2009;9:159. [pmid: 19473534].
Taket A, Wathen CN, et al. Should health professionals screen all women for domestic violence?. PLoS Med. 2004;1(1):e4. [pmid: 15526052].
Thackeray JD, Hibbard R, et al. Intimate partner violence: the role of the pediatrician. Pediatrics. 2010;125(5):1094-1100. [pmid: 20421260].
Walker CA, Davies J. A critical review of the psychometric evidence base of the Child Abuse Potential Inventory. J Fam Violence. 2010;25(2):215-227.
Walsh C, Jamieson E, et al. Measuring child sexual abuse in children and youth. J Child Sex Abuse. 2004;13(1):39-68.
Wathen C, MacMillan HL, et al. Screening for intimate partner violence. Am J Prev Med. 2006;31(5):453. [pmid: 17046419].
Webster J. Screening for domestic violence: the ‘evidence’ dilemma. Contemp Nurse. 2006;21(2):163-164. [pmid: 16696598].
Wetmore M, Fairbairn CD. A regional California program to screen adolescent patients for intimate partner violence. J Emerg Nurs. 2003;29(4):373-376. [pmid: 12874565].
Yaffe MJ. Detection and reporting of elder abuse. Fam Med. 2010;42(2):83. [pmid: 20135557].
Zink T, Lloyd K, et al. Applying the planned care model to intimate partner violence. Manag Care. 2007;16(3):54-61. [pmid: 17432168].

### Risk Factor, Association, or Prevalence Study Only

Acierno R, Lawyer SR, et al. Current psychopathology in previously assaulted older adults. J Interpers Violence. 2007;22(2):250-258. [pmid: 17202579].
Adams BL. Assessment of child abuse risk factors by advanced practice nurses. Pediatr Nurs. 2005;31(6):498-502. [pmid: 16411545].
Anderst J, Hill TD, et al. A comparison of domestic violence screening methods in a pediatric office. Clin Pediatr. 2004;43(1):103-105.
Blackburn JF. Reading Skills in Children Exposed to Domestic Violence. Bloominton, IN. Indiana University. 2006.
Bullock L, Bloom T, et al. Abuse disclosure in privately and Medicaid-funded pregnant women. J Midwifery Womens Health. 2006;51(5):361-369. [pmid: 16945784].
Buri HM, Daly JM, et al. Elder abuse telephone screen reliability and validity. J Elder Abuse Negl. 2009;21(1):58-73. [pmid: 19197621].
Castelda BA, Levis DJ, et al. Extension of the sexual abuse questionnaire to other abuse categories: the initial psychometric validation of the Binghamton Childhood Abuse Screen. J Child Sex Abuse. 2007;16(1):107-125.
Chang DC, Knight V, et al. The tip of the iceberg for child abuse: the critical roles of the pediatric trauma service and its registry. J Trauma. 2004;57(6):1189-1198. [pmid: 15625449].
Cleary BS, Keniston A, et al. Intimate partner violence in women hospitalized on an internal medicine service: prevalence and relationship to responses to the review of systems. J Hosp Med. 2008;3(4):299-307. [pmid: 18698603].
Cohen M, Halevi-Levin S, et al. Development of a screening tool for identifying elderly people at risk of abuse by their caregivers. J Aging Health. 2006;18(5):660-685. [pmid: 16980634].
Cohen M, Levin SH, et al. Elder abuse: disparities between older people’s disclosure of abuse, evident signs of abuse, and high risk of abuse. J Am Geriatr Soc. 2007;55(8):1224-1230. [pmid: 17661961].
Coker AL, Flerx VC, et al. Intimate partner violence incidence and continuation in a primary care screening program. Am J Epidemiol. 2007;165(7):821-827. [pmid: 17255117].
Coker AL, Flerx VC, et al. Partner violence screening in rural health care clinics. Am J Pub Health. 2007;97(7):1319-1325. [pmid: 17538065].
Cooper C, Katona C, et al. Indicators of elder abuse: a cross-national comparison of psychiatric morbidity and other determinants in the Ad-HOC study. Am J Geriatr Psychiatry. 2006;14(6):489-497. [pmid: 16731717].
Dichter ME, Rhodes KV. Reports of police calls for service as a risk indicator for intimate partner violence. Acad Emerg Med. 2009;16(1):83-86. [pmid: 19007347].
Dong X, Simon MA. Is greater social support a protective factor against elder mistreatment?. Gerontology. 2008;54(6):381-388. [pmid: 18600021].
Dubowitz H, Kim J, et al. Identifying children at high risk for a child maltreatment report. Child Abuse Negl. 2011;35(2):96-104. [pmid: 21376396].
Ekeus C, Christensson K, et al. Unintentional and violent injuries among pre-school children of teenage mothers in Sweden: a national cohort study. J Epidemiol Community Health. 2004;58:680-685. [pmid: 15252071].
Ergonen AT, Ozdemir MH, et al. Domestic violence on pregnant women in Turkey. J Forens Legal Med. 2009;16(3):125-129.
Foran HM, O’Leary D. Alcohol and intimate partner violence: a meta-analytic review. Clin Psychol Rev. 2008;28:1222-1234. [pmid: 18550239].
Goodman L, Dutton MA, et al. Women’s resources and use of strategies as risk and protective factors for reabuse over time. Violence Against Women. 2005;11(3):311-336. [pmid: 16043552].
Grubaugh AL, Frueh B. Intimate partner violence victimization among adults with severe mental illness: results of a cross-sectional study. J Clin Psychiatry. 2006;67(9):1472-1473. [pmid: 17017840].
Hegarty K, Gunn J, et al. Physical and social predictors of partner abuse in women attending general practice: a cross-sectional study. Br J Gen Pract. 2008;58(552):484-487. [pmid: 18611314].
Hegarty KL, Bush R. Prevalence and associations of partner abuse in women attending general practice: a cross-sectional survey. Aust N Z J Pub Health. 2002;26(5):437-442. [pmid: 12413288].
Herzig K, Danley D, et al. Seizing the 9-month moment: addressing behavioral risks in prenatal patients. Patient Educ Couns. 2006;61(2):228-235. [pmid: 16256291].
Huth-Bocks AC, Levendosky AA, et al. The effects of domestic violence during pregnancy on maternal and infant health. Violence Vict. 2002;17(2):169-185. [pmid: 12033553].
Johnson JK, Haider F, et al. The prevalence of domestic violence in pregnant women. BJOG. 2003;110(3):272-275. [pmid: 12628266].
Koziol-McLain J, Rameka M, et al. Partner violence prevalence among women attending a Maori health provider clinic. Aust N Z J Pub Health. 2007;31(2):143-148. [pmid: 17461005].
Kumar S, Jeyaseelan L, et al. Domestic violence and its mental health correlates in Indian women. Br J Psychiatry. 2005;187:62-67. [pmid: 15994573].
Lee LC, Kotch J, et al. Child maltreatment in families experiencing domestic violence. Violence Vict. 2004;19(5):573-591. [pmid: 15844726].
Loxton D, Schofield M, et al. History of domestic violence and health service use among mid-aged Australian women. Aust N Z J Pub Health. 2004;28(4):383-388. [pmid: 15704705].
McDonald R, Jouriles EN, et al. Children’s adjustment problems in families characterized by men’s severe violence toward women: does other family violence matter?. Child Abuse Negl. 2009;33(2):94-101. [pmid: 19303141].
McFarlane J, Malecha A, et al. Intimate partner physical and sexual assault and child behavior problems. MCN Am J Matern Child Nurs. 2007;32(2):74-80. [pmid: 17356411].
McFarlane JM, Groff JY, et al. Behaviors of children who are exposed and not exposed to intimate partner violence: an analysis of 330 black, white, and Hispanic children. Pediatrics. 2003;112(3 Pt 1):e202-207. [pmid: 12949313].
Miller E, Decker MR, et al. Intimate partner violence and health care-seeking patterns among female users of urban adolescent clinics. Matern Child Health J. 2010;14(6):910-917. [pmid: 19760162].
Neggers Y, Goldenberg R, et al. Effects of domestic violence on preterm birth and low birth weight. Acta Obstet Gynecol Scand. 2004;83(5):455-460. [pmid: 15059158].
Palazzi S, de Girolamo G, et al. Observational study of suspected maltreatment in Italian paediatric emergency departments. Arch Dis Child. 2005;90(4):406-410. [pmid: 15781934].
Papadakaki M, Tzamalouka GS, et al. Seeking for risk factors of intimate partner violence in a Greek national sample: the role of self-esteem. J Interpers Violence. 2009;24(5):732-750. [pmid: 18463309].
Pulido ML, Gupta D. Protecting the child and the family: integrating domestic violence screening into a child advocacy center. Violence Against Women. 2002;8(8):917-933.
Ramsden C, Bonner M. A realistic view of domestic violence screening in an emergency department. Accid Emerg Nurs. 2002;10(1):31-39. [pmid: 11998582].
Reijneveld SA, de Meer G, et al. Detection of child abuse by Dutch preventive child-healthcare doctors and nurses: has it changed?. Child Abuse Negl. 2008;32(9):831-837. [pmid: 18945489].
Resick PA, Galovski TE, et al. A randomized clinical trial to dismantle components of cognitive processing therapy for posttraumatic stress disorder in female victims of interpersonal violence. J Consult Clin Psychol. 2008;76(2):243-258. [pmid: 18377121].
Reynolds AJ, Robertson DL. School-based early intervention and later child maltreatment in the Chicago Longitudinal Study. Child Dev. 2003;74(1):3-26. [pmid: 12625433].
Reynolds AJ, Temple JA, et al. School-based early intervention and child well-being in the Chicago Longitudinal Study. Child Welfare. 2003;82(5):633-656. [pmid: 14524429].
Rhodes KV, Drum M, et al. Lowering the threshold for discussions of domestic violence: a randomized controlled trial of computer screening. Arch Intern Med. 2006;166(10):1107-1114. [pmid: 16717173].
Ross J, Walther V, et al. Screening risks for intimate partner violence and primary care settings: implications for future abuse. Soc Work Health Care. 2004;38(4):1-23. [pmid: 15149903].
Roy CA, Perry JC. Instruments for the assessment of childhood trauma in adults. J Nerv Mental Dis. 2004;192(5):343-351.
Schonfeld L, Larsen RG, et al. Behavioral health services utilization among older adults identified within a state abuse hotline database. Gerontologist. 2006;46(2):193-199. [pmid: 16581883].
Silverstein MN. Factors Associated With Intimate Partner Violence During Pregnancy: An Evolutionary Feminist Approach. Denver. University of Colorado at Denver. 2003.
Storer E. Identifying Mothers at Risk for Child Abuse Through the Development of a Maternal Prenatal Assessment Instrument. San Francisco. Alliant International University. 2003.
Strathearn L, Mamun AA, et al. Does breastfeeding protect against substantiated child abuse and neglect? A 15-year cohort study. Pediatrics. 2009;123(2):483-493. [pmid: 19171613].
Suellentrop K, Morrow B, et al. Monitoring progress toward achieving Maternal and Infant Healthy People 2010 objectives—19 states, Pregnancy Risk Assessment Monitoring System (PRAMS), 2000–2003. MMWR Surveill Summ. 2006;55(9):1-11. [pmid: 17021594].
Theodore A, Chang JJ, et al. Measuring the risk of physical neglect in a population-based sample. Child Maltreat. 2007;12(1):96-105. [pmid: 17218651].
Vest JR, Catlin TK, et al. Multistate analysis of factors associated with intimate partner violence. Am J Prev Med. 2002;22(3):156-164. [pmid: 11897459].
Waltermaurer E, McNutt LA, et al. Examining the effect of residential change on intimate partner violence risk. J Epidemiol Community Health. 2006;60(11):923-927. [pmid: 17053280].
Weberling LC, Forgays DK, et al. Prenatal child abuse risk assessment: a preliminary validation study. Child Welfare. 2003;82(3):319-334. [pmid: 12769394].
Wenzel JD, Monson CL, et al. Domestic violence: prevalence and detection in a family medicine residency clinic. J Am Osteopath Assoc. 2004;104(6):233-239. [pmid: 15233329].
Whitaker DJ, Haileyesus T, et al. Differences in frequency of violence and reported injury between relationships with reciprocal and nonreciprocal intimate partner violence. Am J Pub Health. 2007;97(5):941-947. [pmid: 17395835].
Whitfield CL, Anda RF, et al. Violent childhood experiences and the risk of intimate partner violence in adults: assessment in a large health maintenance organization. J Interpers Violence. 2003;18(2):166-185.

### Not Applicable to United States

Ameh N, Shittu SO, et al. Risk scoring for domestic violence in pregnancy. Niger J Clin Pract. 2008;11(1):18-21. [pmid: 18689133].
Ayub M, Irfan M, et al. Psychiatric morbidity and domestic violence: a survey of married women in Lahore. Soc Psychiatry Psychiatr Epidemiol. 2009;44(11):953-960. [pmid: 19277437].
Connelly CD, Newton RR, et al. A psychometric examination of English and Spanish versions of the Revised Conflict Tactics Scales. J Interpers Violence. 2005;20(12):1560-1579. [pmid: 16246917].
Constantino R, Kim Y, et al. Effects of a social support intervention on health outcomes in residents of a domestic violence shelter: a pilot study. Issues Mental Health Nurs. 2005;26(6):575-590.
Dietz TL, Jasinski JL. The effect of item order on partner violence reporting: an examination of four versions of the revised Conflict Tactics Scales. Soc Sci Res. 2007;36(1):353-373.
Dong X, Simon MA. Is impairment in physical function associated with increased risk of elder mistreatment? Findings from a community-dwelling Chinese population. Pub Health Rep. 2010;125(5):743-753. [pmid: 20873291].
Hokoda A, Ramos-Lira L, et al. Reliability of translated measures assessing dating violence among Mexican adolescents. Violence Vict. 2006;21(1):117-127. [pmid: 16494137].
Ishii T, Asukai N, et al. Development of the Domestic Violence Screening Inventory (DVSI) and its reliability and validity [Japanese]. Seishin Igaku. 2003;45(8):817-823.
Moonesinghe L, Rajapaksa L, et al. Development of a screening instrument to detect physical abuse and its use in a cohort of pregnant women in Sri Lanka. Asia Pac J Pub Health. 2004;16(2):138-144. [pmid: 15624793].
Munoz-Rivas MJ, Rodriguez JM, et al. Validation of the modified version of the Conflict Tactics Scale (M-CTS) in a Spanish population of youths [Spanish]. Psicothema. 2007;19:693-8. [pmid: 17959128].
Ogioni L, Liperoti R, et al. Cross-sectional association between behavioral symptoms and potential elder abuse among subjects in home care in Italy: results from the Silvernet Study. Am J Geriatr Psychiatry. 2007;15(1):70-78. [pmid: 17194817].
Perez-Carceles MD, Rubio L, et al. Suspicion of elder abuse in south eastern Spain: the extent and risk factors. Arch Gerontol Geriatr. 2009;49(1):132-137. [pmid: 18676036].
Perez-Rojo G, Castiello MT, et al. Spanish contribution to international advances in the linguistic and cultural adaptation of a screening tool for elder abuse [Spanish]. Rev Esp Geriatr Gerontol. 2008;43(3):180-188. [pmid: 18682135].
Phua DH, Ng TW, et al. Epidemiology of suspected elderly mistreatment in Singapore. Singapore Med J. 2008;49(10):765-773. [pmid: 18946608].
Reis M, Nahmiash D. Validation of the Indicators of Abuse (IOA) screen. Gerontologist. 1998;38(4):471-480. [pmid: 9726134].
Rinfret-Raynor M, Turgeon J, et al. A systematic screening protocol of domestic violence: measurement of efficiency. Can J Community Mental Health. 2002;21(1):85-99.
Runyan DK, Cox CE, et al. Describing maltreatment: do child protective service reports and research definitions agree?. Child Abuse Negl. 2005;29(5):461-477. [pmid: 15970320].
Tiwari A, Fong DY, et al. Effect of an advocacy intervention on mental health in Chinese women survivors of intimate partner violence: a randomized controlled trial. JAMA. 2010;304(5):536-543. [pmid: 20682933].
Tiwari A, Leung WC, et al. A randomised controlled trial of empowerment training for Chinese abused pregnant women in Hong Kong. BJOG. 2005;112(9):1249-1256. [pmid: 16101604].
Wang JJ. Psychological abuse behavior exhibited by caregivers in the care of the elderly and correlated factors in long-term care facilities in Taiwan. J Nurs Res. 2005;13(4):271-280. [pmid: 16372238].
Wang JJ, Lin JN, et al. Psychologically abusive behavior by those caring for the elderly in a domestic context. Geriatr Nurs. 2006;27(5):284-291. [pmid: 17045127].
Wang JJ, Lin MF, et al. Caregiver factors contributing to psychological elder abuse behavior in long-term care facilities: a structural equation model approach. Int Psychogeriatr. 2009;21(2):314-320. [pmid: 19138458].
Wang JJ, Tseng HF, et al. Development and testing of screening indicators for psychological abuse of older people. Arch Psychiatr Nurs. 2007;21(1):40-47. [pmid: 17258108].
Widom CS, Button MA, et al. Development and validation of a new instrument to assess lifetime trauma and victimization history. J Trauma Stress. 2005;18(5):519-531. [pmid: 16281250].
Wiglesworth A, Mosqueda L, et al. Screening for abuse and neglect of people with dementia. J Am Geriatr Soc. 2010;58(3):493-500. [pmid: 20398118].

### Systematic Review, Checked Individual Studies

Allin H, Wathen CN, et al. Treatment of child neglect: a systematic review. Can J Psychiatry. 2005;50(8):497-504. [pmid: 16127968].
Bair-Merritt MH, Blackstone M, et al. Physical health outcomes of childhood exposure to intimate partner violence: a systematic review. Pediatrics. 2006;117(2):e278-e290. [pmid: 16452335].
Barlow J, Johnston I, et al. Individual and group-based parenting programmes for the treatment of physical child abuse and neglect. Cochrane Database Syst Rev. 2006;3:CD005463. [pmid: 16856097].
Basile KC, Hertz MF, et al. Intimate Partner Violence and Sexual Violence Victimization Assessment Instruments for Use in Healthcare Settings. Atlanta. Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 2007.
Bennett C, Macdonald G, et al. Home-based support for disadvantaged adult mothers. Cochrane Database Syst Rev. 2009;1:CD003759. [pmid: 18254033].
Bilukha O, Hahn RA, et al. The effectiveness of early childhood home visitation in preventing violence: a systematic review. Am J Prev Med. 2005;28(2 Suppl 1):11-39. [pmid: 15698746].
Feder G, Ramsay J, et al. How far does screening women for domestic (partner) violence in different health-care settings meet criteria for a screening programme? Systematic reviews of nine UK National Screening Committee criteria. Health Technol Assess. 2009;13:16.
Geeraert L, Van den Noortgate W, et al. The effects of early prevention programs for families with young children at risk for physical child abuse and neglect: a meta-analysis. Child Maltreat. 2004;9(3):277-291. [pmid: 15245680].
Hahn RA, Bilukha OO, et al. First reports evaluating the effectiveness of strategies for preventing violence: early childhood home visitation. Findings from the Task Force on Community Preventive Services. MMWR Recomm Rep. 2003;52(RR-14):1-9. [pmid: 14566220].
Harding K, Galano J, et al. Healthy Families America effectiveness: a comprehensive review of outcomes. J Prev Interv Community. 2007;34(1–2):149-179. [pmid: 17890198].
Hodnett ED, Roberts I. Home-based social support for socially disadvantaged mothers. Cochrane Database Syst Rev. 2000;2:CD000107. [pmid: 10796694].
Louwers EC, Affourtit MJ, et al. Screening for child abuse at emergency departments: a systematic review. Arch Dis Child. 2010;95(3):214-218. [pmid: 19773222].
Lundahl BW, Nimer J, et al. Preventing child abuse: a meta-analysis of parent training programs. Res Soc Work Pract. 2006;16(3):251-262.
Macdonald G, Bennett C, et al. Home-based support for disadvantaged teenage mothers. Cochrane Database Syst Rev. 2007;3:CD006723. [pmid: 17636849].
O’Campo P, Kirst M, et al. Implementing successful intimate partner violence screening programs in health care settings: evidence generated from a realist-informed systematic review. Soc Sci Med. 2011;72(6):855-866. [pmid: 21330026].
O’Reilly R, Beale B, et al. Screening and intervention for domestic violence during pregnancy care: a systematic review. Trauma Violence Abuse. 2010;11(4):190-201. [pmid: 20688785].
Plichta SB. Interactions between victims of intimate partner violence against women and the health care system: policy and practice implications. Trauma Violence Abuse. 2007;8(2):226-239. [pmid: 17545576].
Rabin RF, Jennings JM, et al. Intimate partner violence screening tools: a systematic review. Am J Prev Med. 2009;36(5):439-445. [pmid: 19362697].
Ramchandani P, Jones DP. Treating psychological symptoms in sexually abused children: from research findings to service provision. Br J Psychiatry. 2003;183:484-490. [pmid: 14645018].
Ramsay C, Rivas C, et al. 2005. Interventions to Reduce Violence and Promote the Physical and Psychosocial Well-Being of Women Who Experience Partner Violence: A Systematic Review of Controlled Evidence. London. U.K. Department of Health. 2005.
Ramsay J, Carter Y, et al. Advocacy interventions to reduce or eliminate violence and promote the physical and psychosocial well-being of women who experience intimate partner abuse. Cochrane Database Syst Rev. 2009;3:CD005043. [pmid: 19588364].
Sadowski L, Casteel C. Intimate partner violence towards women. Clin Evid (Online). 2010. Feb. 24. pii:1013.
Shah PS, Shah J, et al. Maternal exposure to domestic violence and pregnancy and birth outcomes: a systematic review and meta-analyses. J Womens Health. 2010;19:2017-31.
Sharps PW, Campbell J, et al. Current evidence on perinatal home visiting and intimate partner violence. J Obstet Gynecol Neonat Nurs. 2008;37(4):480-490.
Spinks A, Turner C, et al. The ‘WHO Safe Communities’ model for the prevention of injury in whole populations. Cochrane Database Syst Rev. 2009;(3):CD004445. [pmid: 19588359].
Sweet MA, Appelbaum MI. Is home visiting an effective strategy? A meta-analytic review of home visiting programs for families with young children. Child Dev. 2004;75:1435-56. [pmid: 15369524].
Trabold N. Screening for intimate partner violence within a health care setting: a systematic review of the literature. Soc Work Health Care. 2007;45(1):1-18. [pmid: 17804344].
Wathen C, MacMillan HL. Interventions for violence against women: scientific review. JAMA. 2003;289(5):589-600. [pmid: 12578492].

## Appendix B5 USPSTF Quality Rating Criteria for Diagnostic Accuracy Studies, Randomized Controlled Trials, and Observational Studies

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate results in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test
- Random or consecutive selection of patients
- Screening cutoff predetermined
- All patients undergo the reference standard

#### Definition of ratings based on above criteria

Good: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number of (more than 100) broad-spectrum patients with and without disease; study attempts to enroll a random or consecutive sample of patients who meet prestated inclusion criteria screening cutoffs.
Fair: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients (i.e., applicable to most screening settings).
Poor: | Has important limitation, such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

### Randomized Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups. Randomized controlled trials (RCTs): adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis, consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of ratings based on above criteria

Good: | Meets all criteria: comparable groups are assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Any or all of the following problems occur, without the important limitations noted in the “poor” category below: generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Any of the following major limitations exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Sources: Harris, 2001^81^; Leeflang, 2008^83^; Whiting, 2003.^84^

## Appendix B6 Quality Rating Criteria for Systematic Reviews

Overall quality rating for each systematic review is based on the below questions. Ratings are summarized as good, fair, or poor.

- Search dates reported? Yes or No
- Search methods reported? Yes or No
- Comprehensive search? Yes or No
- Inclusion criteria reported? Yes or No
- Selection bias avoided? Yes or No
- Validity criteria reported? Yes or No
- Validity assessed appropriately? Yes or No
- Methods used to combine studies reported? Yes or No
- Findings combined appropriately? Yes or No
- Conclusions supported by data? Yes or No

### Definitions of ratings based on above criteria

Good: | Meets all criteria: reports comprehensive and reproducible search methods and results; reports predefined criteria to select studies and reports reasons for excluding potentially relevant studies; adequately evaluates quality of included studies and incorporates assessments of quality when synthesizing data; reports methods for synthesizing data and uses appropriate methods to combine data qualitatively or quantitatively; conclusions supported by the evidence reviewed.
Fair: | Fails to meet one or more of the above criteria, but the limitations are not judged as being major.
Poor: | Has a major limitation in one or more of the above criteria.

Developed from the following publications: Harris, 2001^81^; National Institute for Health and Clinical Excellence, 2006^85^; Oxman, 1991.^86^

## Appendix B7 Reviewers of the Draft Report

Joseph Chin, M.D., M.S.

Medical Officer, Centers for Medicare & Medicaid Services, Office of Clinical Standards and Quality, Coverage and Analysis Group

Claudia Cooper, B.M., M.R.C.Psych., M.Sc., Ph.D.

Senior Lecturer and Honorary Consultant, Department of Mental Health Sciences, University College London, United Kingdom

Megan Gerber, M.D., M.P.H.

Medical Director of Women’s Health, Boston Veterans Affairs Medical Center

Linda S. Kinsinger, M.D., M.P.H.

Chief Consultant for Preventive Medicine, Veterans Health Administration

Christina Nicolaidis, M.D., M.P.H.

Associate Professor of Medicine and Public Health, Oregon Health & Science University

Marcel E. Salive, M.D., M.P.H.

Medical Officer, National Institute on Aging, National Institutes of Health

Julie Weitlauf, Ph.D.

Clinical Associate Professor, Stanford University School of Medicine