# Abbreviations

Abbreviation: Meaning
AAS: Abuse Assessment Screen
AHRQ: Agency for Healthcare Research and Quality
APS: Adult Protective Services
AUC: Area under the curve
CAS: Composite Abuse Scale
CDC: Centers for Disease Control and Prevention
CI: Confidence interval
COST: Consequences of Screening Tool
CTQ-SF: Childhood Trauma Questionnaire–Short Form
CTS: Conflict Tactics Scale
CTS2: Conflict Tactics Scale 2
DAST: Drug Abuse Severity Test
EASI: Elder Abuse Suspicion Index
EPC: Evidence-based Practice Center
EPDS: Edinburgh Postnatal Depression Scale
GRECC: Geriatric Research, Education, and Clinical Center
HARK: Humiliation, Afraid, Rape, Kick
HITS: Hurt, Insult, Threaten, Scream
IPV: Intimate partner violence
IRR: Incidence rate ratio
ISA: Index of Spouse Abuse
MOS-SF: Medical Outcome Study–Short Form
NIH-DC: National Institutes of Health–District of Columbia
NR: Not reported
OAS/OVAT: Ongoing Abuse Screen/Ongoing Violence Assessment Tool
OR: Odds ratio
PSI-SF: Parenting Stress Index–Short Form
PSQ: Parent Screening Questionnaire
PTSD: Post-traumatic stress disorder
PVS: Partner Violence Screen
RCT: Randomized, controlled trial
RR: Relative risk
SAFE-T: Secure, Accepted, Family, Even, Talk
SAVAWS: Safety Behavior Checklist, Community Resources Checklist, Severity of Violence Against Women Scale
SF-36: 36-Item Short-Form Health Survey
SPAN: Startle, Physiological Arousal, Anger, and Numbness
STaT: Slapped, Threatened, and Throw
USPSTF: U.S. Preventive Services Task Force
WAST: Women Abuse Screening Tool
WHO: World Health Organization
WHOQOL: World Health Organization Quality of Life
WIC: Women, Infants, and Children
VA: Veterans Affairs