# Results

We identified 11 studies (two RCTs34–41 and nine cohort studies10,42–49) on benefits of prostate cancer treatments and 16 studies (two RCTs31–33,50 and 14 cohort studies51–66) on harms (Table 4, Appendix C1, and Appendix C2). Sample sizes ranged from 72 to 44,630 and duration of followup from 1 to 23 years. Four studies were rated as good quality,35,50,60,64,66 one as poor quality,41 and the remainder as fair quality (Appendix C3 and Appendix C4). Frequent methodological shortcomings were failure to describe loss to followup (six cohort studies and all three RCTs met this criterion) and inadequate blinding of outcome assessors (no cohort studies and one RCT met this criterion). Only two studies33,45 clearly described the control group intervention (Table 4). Baseline characteristics differed for patients who received active treatments compared with watchful waiting. For example, men who received ADT had higher baseline PSA levels compared with those who underwent watchful waiting.51,55,60,63,64

Table 4 Study Characteristics of Randomized, Controlled Trials and Cohort Studies of Treatments for Prostate Cancer

Author, Yr | Interventions | Definition of watchful waiting | Mean duration of followup | Mean age | Stage at diagnosis | Adjusted variables in analysis | Outcomes | Quality rating
Randomized, controlled trials
Bill-Axelson et al, 2011^35^ Other publications: Johansson et al, 2009^31^ Bill-Axelson et al, 2008^34^ Holmberg et al, 2006^39^ Bill-Axelson et al, 2005^36^ Steineck et al, 2002^50^ Holmberg et al, 2002^40^ | Watchful waiting (n=348) Radical prostatectomy (n=347) | No immediate treatment | 13 yrs (range, 3 wks to 20.2 yrs); 15-yr estimates reported | 65 yrs | 12% (83/695) T1b 12% (81/695) T1c 76% (529/695) T2 <1% (2/695) unknown Mean PSA, 12.9 ng/mL | Not applicable (RCT) | Prostate cancer mortality All-cause mortality | Good
Fransson et al, 2001^32^ Other publications: Fransson et al, 2009^33^ | Watchful waiting (n=27) Radiotherapy (n=27) | Regular monitoring and deferred treatment until time of progression | 10 yrs | 78 yrs | 25% (14/57) T1 75% (43/57) T2 | Not applicable (RCT) | Disease-specific quality of life Generic quality of life | Fair
Iversen et al, 1995^41^ Other publications: Byar et al, 1981^37^ Graversen et al, 1990^38^ | Watchful waiting (n=68) Radical prostatectomy (n=74) | Oral placebo, no other treatment | 23 yrs (range, 19–27 yrs) | 64 yrs | 54% (76/142) WHO Stage I 46% (66/142) WHO Stage II | Not applicable (RCT) | All-cause mortality | Poor
Cohort studies
Albertsen et al, 2007^42^ | No initial therapy (n=114) Surgery (n=802) Radiation (n=702) | Observation only (not defined) | Varied according to treatment group (median, 13.1–13.6 yrs) | 68 yrs | 4% Gleason score 2–4 6% Gleason score 5 47% Gleason score 6 26% Gleason score 7 17% Gleason score 8–10 | Gleason score, PSA, clinical stage, age at diagnosis, and Charlson comorbidity score | Prostate cancer mortality | Fair
Bacon et al, 2001^51^ | Watchful waiting (n=31) Prostatectomy (n=421) EBRT (n=221) Brachytherapy (n=69) Hormone (n=33) Other^*^ (n=67) *Definition unclear; results not abstracted | Not defined | 5 yrs | 71 yrs | 3% (23/842) T1 86% (726/842) T2 11% (93/842) other | Age, marital status, waist circumference, metabolic equivalent hours of physical activity per week, smoking status, alcohol intake, comorbidities, Gleason score | Disease-specific quality of life Generic quality of life | Fair
Choo et al, 2010^52^ | Watchful waiting (n=9) Radiotherapy (n=52; EBRT=22, brachytherapy=30) | Not defined | 2 yrs | 64 yrs | 4% (3/75) Tx 55% (41/75) T1 37% (28/75) T2 4% (3/75) T3 | No adjustment for variables; adjustment made for repeat measures | Disease-specific quality of life | Fair
Galbraith et al, 2001^54^ | Watchful waiting (n=30) Surgery (n=59) Conventional radiation (n=25) Proton-beam radiation (n=24) Mixed-beam radiation (n=47) | Not defined | 2 yrs | 68 yrs | Stage NR (mean PSA values ranged from 9.8 to 17.6 at baseline depending on treatment group) | No adjustment for variables | Disease-specific quality of life Generic quality of life | Fair
Hoffman et al, 2003^55^ | No treatment (n=230) Androgen deprivation (n=179) Radiation (n=583) Radical prostatectomy (n=1373) | No active treatment | 2 yrs | 66 yrs | Stage NR (all were T1 or T2) | Demographic, socioeconomic and clinical variables (not further defined) | Disease-specific quality of life | Fair
Ladjevardi et al, 2010^43^ | Conservative management^*^ (watchful waiting [n=9,435] and palliative treatment, including androgen deprivation, [n=3210]) Radical prostatectomy (n=12,950) Radiotherapy (n=6308; EBRT n=4443, brachytherapy n=1865) | Not defined | Median, 4 yrs (range, 0–12 yrs) | 65 yrs | <1% T0 49% T1 35% T2 15% T3 <1% TX | Age, Gleason score, PSA | All-cause mortality | Fair
Litwin et al, 1995a56 Litwin et al, 1995b57 | Observation (n=60) Prostatectomy (n=98) Radiation (n=56) | Not defined | 6 yrs | 73 yrs | Tumor stage NR (all were clinically localized) | Age; comorbidities (diabetes, CV disease, respiratory disease, GI disease, renal disease, depression, alcohol or drug problems, smoking) | Disease-specific quality of life Generic quality of life | Fair
Litwin et al, 2002^58^ | Watchful waiting (n=66) Radical prostatectomy (n=282) Radiation (n=104) | Not defined | 2 yrs | 66 yrs | 30% (136/452) T1 66% (298/452) T2 4% (18/452) T3/4 or N+ or M+ | Comorbidities, PSA, Gleason score, age | Generic quality of life | Fair
Lu-Yao et al, 2008^44^ | Conservative management (n=11,404) Primary androgen deprivation therapy (n=7867) | No use of surgery, radiation or androgen deprivation | Median, 7 yrs | 78 yrs | 58% T1 42% T2 | Instrumental variable analysis (covariates in analysis included age, race, comorbidity status, cancer stage, cancer grade, income status, urban resident, marital status, and year of diagnosis) | Prostate cancer mortality All-cause mortality | Fair
Lubeck et al, 1999^59^ | Observation (n=87) Prostatectomy (n=351) Radiotherapy (n=75) Results from the hormone therapy group were not abstracted; 32% (57/179) were stage T3 or higher at baseline | No surgery, radiation or medical therapy in first year following diagnosis | 2 yrs | 66 yrs | 25% (174/692) T1 62% (427/692) T2 5% (33/179) T3/T4 8% (52/692) other | Time (mixed model used to evaluate rate of quality of life change); age | Disease-specific quality of life Generic quality of life | Fair
Merglen et al, 2007^45^ | Watchful waiting (n=378) Prostatectomy (n=158) Any EBRT (n=205; EBRT alone [n=152] or EBRT + ADT [n=53]) ADT (n=72) Other treatment (n=31; not described) | Active followup with treatment for disease progression | 7 yrs | 71 yrs | 29% stage 1 40% stage 2 31% stage 3 22% PSA <10 28% PSA 11–29 23% PSA >30 27% PSA unknown | Age, period of diagnosis, method of detection, lymph node status, clinical tumor stage, differentiation, PSA level | Prostate cancer mortality All-cause mortality | Fair
Potosky et al, 2002^60^ | Observation (n=416) ADT (n=245) | No therapy | 1 yr | Mean age NR 4% (27/661) 40–59 yrs 22% (145/661) 60–69 yrs 53% (350/661) 70–79 yrs 21% (139/661) 80+ yrs | 33% (221/661) T1 51% (338/661) T2 15% (101/661) unknown | Socio- demographic and clinical characteristics, presence of sexual partner, impotence, comorbidities, prostate cancer symptoms | Disease-specific quality of life Generic quality of life | Good
Schapira et al, 2001^61^ | Expectant management (n=29) Radical prostatectomy (n=42) Radiation therapy (n=51) | Not defined | 1 yr | Median age, 69 yrs | 50% (61/122) T1 50% (61/122) T2 | Comorbidities, stage, age, yrs of education, race, marital status, employment status | Disease-specific quality of life Generic quality of life | Fair
Schymura et al, 2010^46^ | Watchful waiting (n=614) Radical prostatectomy (n=1310) Radiation therapy (EBRT or brachytherapy; n=1037) ADT (n=339) | No therapy within 6 mo of diagnosis | 5 yrs | Mean age NR: 18% <60 yrs 17% 60–64 yrs 22% 65–69 yrs 21% 70–74 yrs 14% 75–79 yrs 8% ≥80 yrs | 57% PSA <10 26% PSA 10–20 11% PSA >20 13% PSA unknown | Age at diagnosis, race/ethnicity, marital status, state, PSA value, Gleason score, comorbidity score, time since diagnosis | Disease-specific quality of life Generic quality of life | Fair
Siegel et al, 2001^62^ | Watchful waiting (n=64) Radical prostatectomy (n=419) EBRT (n=319) | Followup every 3–4 mo for 1 yr, every 6 mo after | 4 yrs | 66 yrs | 7% (58/802) grade A 89% (713/802) grade B 4% (31/802) unknown | No adjustment for variables | Disease-specific quality of life | Fair
Smith et al, 2000^63^ | Observation (n=120) Radical prostatectomy (n=1247) Radiotherapy (n=189) Hormonal therapy (n=67) Cryotherapy (n=28) | Not defined | 4 yrs | 67 yrs | 98% (2194/2234) T1/T2 <1% (9/2234) T3 1% (29/2234) T4 | Age, current comorbidities, education, time since diagnosis | Disease-specific quality of life Generic quality of life | Fair
Smith et al, 2009^64^ | Active surveillance (n=200) Radical prostatectomy (n=981) EBRT (n=123) ADT (n=61) Combined EBRT/ADT (n=166) Low-dose brachytherapy (n=58) High-dose brachytherapy (n=47) | Active surveillance (not further defined) | 3 yrs | 61 yrs | 54% (889/1636) T1 46% (747/1636) T2 | Age, insurance status, comorbidity score, stage, Gleason score, PSA | Disease-specific quality of life Generic quality of life | Good
Stattin et al, 2010^10^ | Surveillance (n=2021) Radical prostatectomy (n=3399) Radiation (n=1429) | Combined active surveillance and watchful waiting (no further definition) | Median, 8.2 yrs | 63 yrs | 59% T1 41% T2 Mean PSA, 8.2 ng/mL | Prostate cancer risk category, Charlson co- morbidity index, socioeconomic status | Prostate cancer mortality All-cause mortality | Fair
Talcott et al, 2003^65^ Other publications: Clark et al, 2001^53^ | Observation (n=19) Radical prostatectomy (n=129) EBRT (n=182) Brachytherapy (n=80) | Not defined | 2 yrs | 65 yrs | Exact proportion of patients with T1 and T2 unclear due to reporting method; most (>70%) were T1 | Age, D’Amico risk category, marital status, education, other variables (not defined) | Disease-specific quality of life | Fair
Tewari et al, 2007^47^ | Conservative management (n=197) Radiotherapy (n=137) Radical prostatectomy (n=119) | Not defined | 5 yrs | 63 yrs | 100% stage 3 | Propensity analysis (propensity score based on age at diagnosis, race, socioeconomic status, Charlson comorbidity index, and yr of diagnosis) | Prostate cancer mortality All-cause mortality | Fair
Thong et al, 2009^66^ | Active surveillance (n=71) EBRT (n=71) | Stage and tumor grade ≤2 at time of diagnosis who received no active treatment | 5–10 yrs | 76 yrs | 80% (114/142) T1 20% (28/142) T2 | Demographic and clinical characteristics | Disease-specific quality of life Generic quality of life | Good
Wong et al, 2006^48^ | Observation (n=12,608) Active treament (n=32,022; includes radical prostatectomy [n=13,292] and EBRT or brachytherapy [n=18,249], alone or in combination) | No Medicare data for prostatectomy, radiation or hormonal therapy | 12 yrs | 72 yrs | 55% stage ≤T2a 45% stage T2b-T2c | Propensity- adjusted (propensity score based on age at diagnosis, SEER site, yr of diagnosis, tumor size, tumor grade, marital status, residence in urban setting, race, income, educational achievement, comorbidities) | All-cause mortality | Fair
Zhou et al, 2009^49^ | No treatment ( n=1716) Monotherapy: Radical prostatectomy (n=889) EBRT (n=783) Brachytherapy (n=595) ADT (n=2049) Combination therapy: Radical prostatectomy + EBRT, ADT, or both (n=181) EBRT + ADT (n=1286) Brachytherapy + EBRT or ADT (n=756) | No definitive therapy within 6 mo of diagnosis | 7 yrs | Mean age NR; for total cohort (including 1924 patients with distant or unknown stage): 21% 65–69 yrs 32% 70–74 yrs 46% ≥75 yrs | 66% Gleason score <7 | Age, race, tumor stage, Gleason score, pretreatment comorbidity | Prostate cancer mortality | Fair

* Conservatively managed patients included those who received ADT.

Abbreviations: ADT = androgen deprivation therapy; CV = cardiovascular; EBRT = external beam radiation therapy; GI = gastrointestinal; mo = month; NR = not reported; PSA = prostate-specific antigen; RCT = randomized, controlled trial; SEER = Surveillance, Epidemiology, and End Results; wk = week; WHO = World Health Organization; yr = year.

We also included six observational studies67–72 of surgical complications following prostatectomy, and five uncontrolled studies of harms associated with HIFU (Appendix C5).73–77

Studies generally provided limited information about the interventions studied. For example, one study reported harms stratified by type of prostatectomy (nerve sparing vs. non-nerve sparing),64 while other studies reporting harms provided few details on the type of prostatectomy evaluated. For studies of harms associated with radiation therapy, four reported harms results separately for EBRT and brachytherapy.51,52,64,65 Of the remaining 10 studies, study participants received EBRT in three studies,58,62,66 a mixture of EBRT and brachytherapy in one study,63 and six studies did not describe what type of radiation therapy was given (presumably EBRT for most studies, which covered earlier time periods). One study stratified results by use of conventional radiation, proton-beam radiation, or mixed-beam radiation.54

Methods for reporting harms varied among included studies. Studies reported dichotomous outcomes, continuous scales, or both. The studies used a variety of continuous scales (Table 5) to assess generic quality of life changes following prostate cancer treatments, most commonly the Short-Form 36-Item Health Survey (SF-36). SF-36 scores range from 0–100, with higher scores representing better functioning or quality of life in eight areas (subscales): physical function, social function, bodily pain, emotional well-being, energy, general health perceptions, role limitations due to physical problems, and role limitations due to emotional problems. Mental and physical component summary scores are derived from combining subscale scores relevant to these broader domains. The most commonly used continuous scale for measuring disease-specific quality of life was the University of California, Los Angeles Prostate Cancer Index (PCI). Like the SF-36, PCI scores also range from 0 to 100, in five areas: urinary bother, urinary function, sexual bother, sexual function, and bowel bother; higher scores indicate less bother or better function.57 For both the SF-36 and the PCI, differences of 5 to 10 points are generally thought to indicate clinically meaningful changes.78 Methods for categorizing patients as having or not having urinary incontinence and erectile dysfunction varied. Definitions for urinary incontinence included “at least daily urinary leakage,” “no urinary control or frequent dribbling,” “incontinence,” “use of a pad for urinary leakage,” and “regular reliance on diaper.” Definitions for erectile dysfunction included “no erections at all,” “impotence,” “erectile dysfunction,” “poor or very poor sexual function,” “erection insufficient for intercourse,” and “problems getting an erection nearly all the time.” Gastrointestinal effects (e.g., diarrhea, leakage, urgency) were primarily reported in studies of radiation therapy, and hormonal side effects (e.g., hot flashes, gynecomastia) were reported in studies of ADT. Uncommonly reported harms included anxiety or depression and weight gain.

Table 5 Quality of Life Measures

Abbreviation | Full title | Scales | Scoring | Description
General quality of life measures
SF-36 | Short-form 36-item Health Survey (also known as Medical Outcomes Study General Health Survey; RAND 36-item Health Survey; UCLA 36- item Health Survey) | 5-point Likert scales | 0–100 | 36-item self-administered general quality of life measure used to evaluate physical function, social function, bodily pain, emotional well- being, energy/fatigue, general health perceptions, role limitations due to physical problems, and role limitations due to emotional problems.
Cancer-specific quality of life measures (impotence and incontinence)
CARES-SF | Cancer Rehabilitation Evaluation System–Short Form | 5-point Likert scales | 0–4 | 59-item self-administered cancer-specific quality of life measure; one global score and five higher-order factors representing physical, psychosocial, medical interaction, marital, and sexual quality of life.
BSFI | Brief Sexual Function Inventory | 5-point Likert scales | 0–4 | 11-item self-administered sexual function measure, divided into five domains: sexual drive (2 questions, pooled scores 0–8); erectile function (3 questions, pooled scores 0–12); ejaculation (2 questions, pooled scores 0–8); problem assessment (3 questions, pooled scores 0–12); and overall satisfaction (1 question, score 0–4).
EPIC | Expanded Prostate Cancer Index Composite | 5-point Likert scales | 0–100 | 32-item self-administered prostate cancer treatment-related quality of life measure assessing urinary, bowel, sexual, and hormone function, as well as overall satisfaction.
FACT-G | Functional Assessment of Cancer Therapy–General | 5-point Likert scales | 0–108 | 27-item self-administered general quality of life measure with physical, social/family, emotional, and functional well-being subscales.
PCSS | Prostate Cancer Symptom Scale | 0- (no problems/very good function) to 10-point linear analogue scale | 0–10 | 18-item self-administered quality of life measure specific to prostate cancer.
PTSS | Southwest Oncology Group Prostate Treatment-Specific Symptoms Measure | 5-point Likert scale | 1–5 | 19-item quality of life measure of bowel, bladder, and sexual function specific to prostate cancer.
QLQ-C30 | European Organization for Research and Treatment of Cancer (EORTC) Quality of Life Questionnaire for Cancer | 4- and 7-point Likert scales | 1–100 | 30-item self-administered quality of life measure for cancer patients, with disease-specific modules available.
QUF94W | QUF94W | 0- (no problems/very good function) to 10-point linear analogue scale | 0–10 | 43-item self-administered quality of life measure for prostate cancer patients, designed to evaluate side effects after pelvic radiotherapy.
UCLA-PCI | University of California, Los Angeles Prostate Cancer Index | Various-point Likert scales | 0–100 | Self-administered measure of treatment-related sexual (8 items), urinary (5 items), and bowel symptoms (4 items) and bother.

## Key Question 1 What Are the Benefits of Treatment of Early-Stage or Screen-Detected Prostate Cancer?

### Summary

One good-quality RCT compared treatment for localized prostate cancer with watchful waiting in men with localized prostate cancer. It found that prostatectomy was associated with decreased risk of prostate cancer-specific mortality (15% vs. 21%; relative risk [RR], 0.62 [95% CI, 0.44 to 0.87]; absolute difference, 6.1 percentage points [95% CI, 0.2 to 12]) and all-cause mortality (RR, 0.75 [95% CI, 0.61 to 0.92]; absolute difference, 6.6 percentage points [95% CI, −1.3 to 14]), though benefits appeared to be restricted to men younger than age 65 years, based on subgroup analyses. Applicability of the trial to men with screen-detected prostate cancer is uncertain, as it did not enroll men specifically with screen-detected prostate cancer, and the proportion of men with stage T2 tumors (75%) was substantially higher than observed in recent screening trials. Cohort studies consistently found that prostatectomy and radiation therapy were associated with decreased risk for all-cause mortality (6 studies; median adjusted hazard ratio [HR], 0.46 [range, 0.32 to 0.67] and 5 studies; median adjusted HR, 0.68 [range, 0.62 to 0.81], respectively) and prostate cancer-specific mortality (5 studies; median adjusted HR, 0.32 [range, 0.25 to 0.50] and 5 studies; median adjusted HR, 0.66 [range, 0.63 to 0.70], respectively), but estimates are susceptible to confounding by indication. Two cohort studies found that ADT for localized prostate cancer was associated with increased risk of prostate cancer-specific mortality compared with watchful waiting. No studies evaluated effects of cryotherapy or HIFU compared with watchful waiting on all-cause or prostate cancer-specific mortality.

### Evidence

#### Prostatectomy

Prostatectomy was compared with watchful waiting in one good-quality RCT (n=695) of men with localized (stages T1b, T1c, or T2) prostate cancer (Table 6, Appendix C1).34–36,40 It did not specifically enroll men with screen-detected prostate cancer, and about 75% of cases were palpable (stage T2). The 2002 USPSTF review included results from this trial through 6 years of followup.40 Data now available through 15 years show a sustained decrease in risk for prostate cancer-specific mortality (15% vs. 21%; RR, 0.62 [95% CI, 0.44 to 0.87]; absolute difference, 6.1 percentage points [95% CI, 0.2 to 12]) and all-cause mortality (RR, 0.75 [95% CI, 0.61 to 0.92]; absolute difference, 6.6 percentage points [95% CI, −1.3 to 14]).35 In subgroup analyses, benefits were restricted to men younger than age 65 years (RR, 0.49 [95% CI, 0.31 to 0.79] for prostate cancer-specific mortality; RR, 0.52 [95% CI, 0.37 to 0.73] for all-cause mortality). One other small (n=142), poor-quality RCT found no difference between prostatectomy for localized prostate cancer and no prostatectomy on overall survival through 23 years.41 It did not report prostate cancer-specific mortality.

Table 6 Prostate Cancer-Specific and All-Cause Mortality

Author, year, followup | Prostate cancer-specific mortality | All-cause mortality
Prostatectomy vs. watchful waiting
Randomized, controlled trials
Bill-Axelson et al, 2011^35^ Other publications: Bill-Axelson et al, 2008^34^ Holmberg et al, 2006^39^ Bill-Axelson et al, 2005^36^ Steineck et al, 2002^50^ Holmberg et al, 2002^40^ Duration: 13 yrs | 15% (CI, 11 to 19) vs. 21% (CI, 17 to 26); HR, 0.62 (CI, 0.44 to 0.87) [underlined: Subgroups: Risk] 6.5% (CI, 3.5 to 14) vs. 11% (CI, 6.8 to 18); HR, 0.53 (CI, 0.24 to 1.1) [underlined: Subgroups: Age] Age <65 yrs: 16% (CI, 11 to 24) vs. 26% (CI, 20 to 34); HR, 0.49 (CI, 0.31 to 0.79) Age ≥65 yrs: 13% (CI, 8.9 to 19) vs. 16% (CI, 11 to 23); HR, 0.83 (CI, 0.50 to 1.3) [underlined: Subgroups: Risk + Age] Age <65 yrs and low risk: 7.1% (CI, 2.7 to 19) vs. 12 (CI, 6.0 to 23); HR, 0.41 (CI, 0.14 to 1.2) Age ≥65 yrs and low risk: 6.6% (CI, 2.5 to 17) vs. 10% (CI, 5.1 to 21); HR, 0.76 (CI, 0.35 to 2.3) | 46% (CI, 41 to 52) vs. 53% (CI, 47 to 59); HR, 0.75 (CI, 0.61 to 0.92) [underlined: Subgroups: Risk] Low risk: 31% (CI, 24 to 41) vs. 45% (CI, 37 to 54); HR, 0.62 (CI, 0.42 to 0.92) [underlined: Subgroups: Age] Age <65 yrs: 34% (CI, 27 to 43) vs. 47% (CI, 40 to 56); HR, 0.52 (CI, 0.37 to 0.73) Age ≥65 yrs: 57% (CI, 50 to 65) vs. 57% (CI, 50 to 66); HR, 0.98 (CI, 0.75 to 1.3) [underlined: Subgroups: Risk + Age] Age <65 yrs and low risk: 17% (CI, 9.5 to 30) vs. 36% (CI, 26 to 50); HR, 0.36 (CI, 0.18 to 0.7) Age ≥65 yrs and low risk: 47% (CI, 35 to 62) vs. 53% (CI, 41 to 68); HR, 0.92 (CI, 0.57 to 1.5)
Iversen et al, 1995^41^ Other publications: Byar et al, 1981^37^ Graversen et al, 1990^38^ Duration: 23 yrs | NR | Median duration of survival: 8 yrs vs. 11 yrs; p>0.05
Cohort studies
Albertsen et al, 2007^42^ Duration: 13 yrs | 14% vs. 4%; RR, 3.4 (CI, 1.9 to 5.9) | NR
Ladjevardi et al, 2009^43^ Duration: 4 yrs | NR | HR, 0.41 (CI, 0.36 to 0.48) [underlined: Subgroups: Risk] Gleason score 7: HR, 0.78 (CI, 0.63 to 0.97) Gleason score 8–10: HR, 0.65 (CI, 0.47 to 0.90)
Merglen et al, 2007^45^ Duration: 7 yrs | 5-yr mortality: 8/158 (5%) vs. 43/378 (11%); HR, 0.56 (CI, 0.24 to 1.3) 10-yr mortality: 15/158 (9%) vs. 70/378 (11%); HR, 0.59 (CI, 0.26 to 0.91) [underlined: Subgroups: Risk] 10-yr mortality, Gleason score <7: 9/112 (8%) vs. 31/225 (14%); HR, 0.5 (CI, 0.22 to 1.1) 10-yr mortality, Gleason score ≥7: 4/31 (13%) vs. 28/76 (37%); HR, 0.23 (CI, 0.06 to 0.91) [underlined: Subgroups: Age] 10-yr mortality, age <70 yrs: 5/118 (4%) vs. 13/104 (13%); HR, 0.12 (CI, 0.04 to 0.42) 10-yr mortality, age ≥70 yrs: 10/40 (25%) vs. 57/274 (21%); HR, 1.25 (CI, 0.59 to 2.5) | 5-yr mortality: 21/158 (13%) vs. 147/378 (39%); HR, 0.71 (CI, 0.4 to 1.4) 10-yr mortality: 34/158 (22%) vs. 223/378 (60%); HR, 0.67 (CI, 0.4 to 1.1)
Schymura et al, 2010^46^ Duration: 5 yrs | NR | 6% vs. 25%; HR, 0.44 (CI, 0.33 to 0.59)
Stattin et al, 2010^10^ Duration: 8 yrs | 2.4% (CI, 1.8 to 3.3) vs. 3.6% (CI, 2.7 to 4.8); HR, 0.49 (CI, 0.34 to 0.71) [underlined: Subgroups: Risk] Low risk: 0.4% (CI, 0.13 to 0.97) vs. 2.4% (CI, 1.2 to 4.1); HR, 0.29 (CI, 0.09 to 0.87) Intermediate risk: 3.4% (CI, 2.5 to 4.7) vs. 5.2% (CI, 3.7 to 6.9); HR, 0.53 (CI, 0.35 to 0.80) | 11% (CI, 10 to 13) vs. 23% (CI, 21 to 26); HR, 0.49 (CI, 0.41 to 0.57)
Tewari et al, 2007^47^ Duration: 4–6 yrs^*^ | 18/119 (15%) vs. 85/197 (43%); HR, 0.31 (CI, 0.17 to 1.2) | 27/119 (23%) vs. 139/197 (71%); HR, 0.32 (CI, 0.20 to 0.51)
Wong et al, 2006^48^ Duration: 12 yrs | NR | HR, 0.50 (CI, 0.47 to 0.53)
Zhou et al, 2008^49^ Duration: 7 yrs | HR, 0.25 (CI, 0.13 to 0.48) | NR
Radiation therapy vs. watchful waiting
Cohort studies
Albertsen et al, 2007^42^ Duration: 13 yrs | 9% vs. 14%; rate ratio, 1.5 (CI, 0.9 to 2.6) | NR
Ladjevardi et al, 2009^43^ Duration: 4 yrs | NR | HR, 0.62 (CI, 0.54 to 0.71) [underlined: Subgroups: Risk] Gleason score 7: HR, 0.81 (CI, 0.66 to 0.99) Gleason score 8–10: HR, 0.71 (CI, 0.55 to 0.92)
Stattin et al, 2010^10^ Duration: 8 yrs | 3.3% (CI, 2.5 to 5.7) vs. 3.6% (CI, 2.7 to 4.8); HR, 0.70 (CI, 0.45 to 1.1) [underlined: Subgroups: Risk] Low risk: 1.8% (CI, 0.65 to 4.0) vs. 2.4% (CI, 1.2 to 4.1); HR, 0.94 (CI, 0.31 to 2.85) Intermediate risk: 3.8% (CI, 2.6 to 5.4) vs. 5.2% (CI, 3.7 to 6.9); HR, 0.66 (CI, 0.42 to 1.1) | 18% (CI, 16 to 21) vs. 23% (CI, 21 to 26); HR, 0.68 (CI, 0.57 to 0.82)
Tewari et al, 2007^47^ Duration: 4–6 yrs^*^ | 23/137 (17%) vs. 85/197 (43%); HR, 0.63 (CI, 0.38 to 1.1) | 58/137 (42%) vs. 139/197 (71%); HR, 0.70 (CI, 0.50 to 0.99)
Wong et al, 2006^48^ Duration: 12 yrs | NR | HR, 0.81 (CI, 0.78 to 0.85)
Zhou et al, 2008^49^ Duration: 7 yrs | EBRT: HR, 0.66 (CI, 0.41 to 1.0) Brachytherapy: HR, 0.45 (CI, 0.23 to 0.87) EBRT + ADT: HR, 0.97 (CI, 0.70 to 1.33) Brachytherapy + EBRT or ADT: HR, 0.46 (CI, 0.27 to 0.8) | EBRT: HR, 0.63 (CI, 0.53 to 0.75) Brachytherapy: HR, 0.4 (CI, 0.32 to 0.52) EBRT + ADT: HR, 0.57 (CI, 0.49 to 0.66) Brachytherapy + EBRT or ADT: HR, 0.32 (CI, 0.26 to 0.41)
Androgen deprivation therapy vs. watchful waiting
Cohort studies
Lu-Yao et al, 2008^44^ Duration: 7 yrs | 867/32,744 events per person-yr (rate 2.6/100) vs. 693/55,424 events per person-yr (rate 1.3/100); HR, 1.8 (CI, 1.6 to 1.9) [underlined: Subgroups: Risk] Moderately differentiated tumors: HR, 1.8 (CI, 1.6 to 2.1) Poorly differentiated tumors: HR, 1.1 (CI, 1.0 to 1.3) | 4729/39,767 events per person-yr (rate 11.9/100) vs. 6316/66,567 events per person-yr (rate 9.5/100); HR, 1.2 (CI, 1.1 to 1.2) [underlined: Subgroups: Risk] Moderately differentiated tumors: HR, 1.2 (CI, 1.1 to 1.2) Poorly differentiated tumors: HR, 1.0 (CI, 1.0 to 1.1)
Zhou et al, 2008^49^ Duration: 7 yrs | HR, 1.3 (CI, 1.0 to 1.7) | HR, 0.91 (CI, 0.83 to 1.0)

* Duration of followup varied by treatment group.

Abbreviations: ADT = androgen deprivation therapy; CI = confidence interval; EBRT = external beam radiotherapy; HR = hazard ratio; NR = not reported; RR = relative risk.

Eight cohort studies (median n=2,264 [range, 316 to 25,900]) with duration of followup ranging from 4 to 13 years consistently found prostatectomy for localized prostate cancer to be associated with decreased risk for all-cause mortality (6 studies; median adjusted HR, 0.46 [range, 0.32 to 0.67])10,43,45–48 and prostate cancer-specific mortality (5 studies; median adjusted HR, 0.32 [range, 0.25 to 0.50])10,42,45,47,49 compared with watchful waiting (Table 6, Appendix C1). The largest was a fair-quality, propensity-adjusted analysis of data from the U.S. Surveillance, Epidemiology, and End Results (SEER) program (n=25,900) of men ages 65 to 80 years that found decreased risk for all-cause mortality after 12 years (adjusted HR, 0.50 [95% CI, 0.66 to 0.72]).48 Another large (n=22,385), fair-quality Swedish cohort study also found prostatectomy to be associated with decreased risk for all-cause mortality after 4 years of followup, after adjustment for age, Gleason score, and PSA level (adjusted HR, 0.41 [95% CI, 0.36 to 0.48]).43

#### Radiation therapy

No RCTs compared radiation therapy with watchful waiting. Five cohort studies (median n=3,441 [range, 334 to 30,857]) with followup ranging from 4 to 13 years consistently found that radiation therapy (EBRT or unspecified modality) for localized prostate cancer was associated with decreased risk for all-cause mortality (5 studies; median adjusted HR, 0.68 [range, 0.62 to 0.81])10,43,47–49 and prostate cancer-specific mortality (5 studies; median adjusted HR, 0.66 [range, 0.63 to 0.70])10,42,47–49 compared with watchful waiting (Table 6, Appendix C1). The largest study, a previously described analysis of SEER data, found radiation therapy to be associated with decreased propensity-adjusted risk for all-cause mortality (adjusted HR, 0.81 [95% CI, 0.78 to 0.85]).48 A large Swedish cohort study (also described earlier) found radiation therapy to be associated with decreased risk for all-cause mortality (adjusted HR, 0.62 [95% CI, 0.54 to 0.71]).43

#### Androgen deprivation therapy

No RCTs compared ADT with watchful waiting. Two fair-quality cohort studies evaluated risk of all-cause and prostate cancer-specific mortality following ADT versus watchful waiting after 7 years (Table 6, Appendix C1).44,49 One study (n=19,271) found that ADT was associated with increased risk of all-cause mortality (adjusted HR, 1.2 [95% CI, 1.1 to 1.2]) and prostate cancer-specific mortality (adjusted HR, 1.8 [95% CI, 1.6 to 2.0]).44 Stratification of men into groups with moderately or poorly differentiated tumors did not affect conclusions. A smaller cohort study (n=3,765) also found that ADT was associated with increased risk of prostate cancer-specific mortality (adjusted HR, 1.3 [95% CI, 1.0 to 1.7]), but slightly decreased risk of all-cause mortality (HR, 0.89 [95% CI, 0.80 to 0.98]) after 7 years of followup.49

#### Cryotherapy and high-intensity focused ultrasonography

No RCTs or cohort studies evaluated risk of all-cause or prostate cancer-specific mortality following cryotherapy or HIFU.

## Key Question 2 What Are the Harms of Treatment of Early-Stage or Screen-Detected Prostate Cancer?

### Summary

Prostatectomy is associated with an increased risk of urinary incontinence (5 studies; RR, 3.1 [95% CI, 2.0 to 4.8]; I^2^=55%; risk difference, 20 percentage points [95% CI, 10 to 30]) and erectile dysfunction (6 studies; RR, 1.6 [95% CI, 1.4 to 1.8]; I^2^=58%; risk difference, 28 percentage points [95% CI, 24 to 32]) compared with watchful waiting. Based on large databases and surgical series, prostatectomy is also associated with a risk of perioperative (30-day) mortality (about 0.5%) and cardiovascular events (0.6% to 3%).

Radiation therapy is also associated with an increased risk of erectile dysfunction compared with watchful waiting (6 studies; RR, 1.3 [95% CI, 1.2 to 1.5]; I^2^=0%; risk difference, 15 percentage points [95% CI, 10 to 20]), but the difference in risk of urinary incontinence did not reach statistical significance (5 studies; RR, 1.4 [95% CI, 0.78 to 2.4]; I^2^=20%). Radiation therapy is also associated with an increased risk of bowel dysfunction, which may improve over time. Data from one study suggest that low-dose brachytherapy may be associated with fewer harms compared with high-dose brachytherapy or EBRT.

There were no clear adverse effects related to general health-related quality of life following either prostatectomy or radiation therapy compared with watchful waiting.

Evidence on harms associated with ADT for localized prostate cancer is relatively limited, but suggests increased risk of erectile dysfunction (3 studies; RR, 2.3 [95% CI, 1.5 to 3.6]; I^2^=90%; risk difference, 43% [95% CI, 30 to 56]), as well as other systemic effects related to androgen deprivation, such as gynecomastia and hot flashes. Evidence on harms associated with cryotherapy and HIFU is very limited and consists primarily of uncontrolled studies.

### Evidence

#### Prostatectomy

Urinary incontinence and erectile dysfunction. Prostatectomy was associated with increased risk of urinary incontinence compared with watchful waiting in one RCT (RR, 2.3 [95% CI, 1.6 to 3.2])31 and four cohort studies (median RR, 4.0 [range, 2.0 to 11]) (Table 7, Appendix C2).55,57,61,64 In the RCT, the absolute increase in risk of urinary incontinence with surgery was 28% (49% vs. 21%).31 In the cohort studies, the median rate of urinary incontinence with watchful waiting was 6% (range, 3% to 10%), with prostatectomy associated with a median increase in absolute risk of 18 percentage points (range, 8 to 40).55,57,61,64 In pooled analyses, prostatectomy was associated with a relative risk for urinary incontinence of 3.1 (95% CI, 2.0 to 4.8) (Figure 2) and risk difference of 22 percentage points (95% CI, 8.9 to 34) compared with watchful waiting.31,55,57,61,64 Although statistical heterogeneity was present (I^2^=55%), all studies found that prostatectomy was associated with increased risk. Stratification by study type reduced statistical heterogeneity among the cohort studies (I^2^=22%), but the confidence intervals for the estimates overlapped.

Table 7 Urinary Incontinence and Erectile Dysfunction

Author, year, followup | Urinary incontinence | Erectile dysfunction
Prostatectomy vs. watchful waiting
Randomized, controlled trials
Johansson et al, 2009^31^ Steineck et al, 2002^50^ 2–8 years | [underlined: Urinary incontinence] 49% (79/162) vs. 21% (33/155); RR, 2.3 (CI, 1.6 to 3.2) | [underlined: Erectile dysfunction] 81% (128/159) vs. 45% (71/158); RR, 1.8 (CI, 1.5 to 2.2)
Cohort studies
Hoffman et al, 2003^55^ 2 years | [underlined: Urinary leakage, daily or more often] 35% (484/1373) vs. 8% (19/230); RR, 4.3 (CI, 2.8 to 6.6) | [underlined: No erections] 55% (757/1373) vs. 26% (60/230); RR, 2.1 (CI, 1.7 to 2.6)
Litwin et al, 1995b57 6 years | [underlined: No urinary control or frequent dribbling] 19% (19/98) vs. 10% (6/60); RR, 1.9 (CI, 0.82 to 4.6) | [underlined: Poor or very poor sexual function] 78% (76/98) vs. 52% (31/60); RR, 1.5 (CI, 1.2 to 2.0)
Schapira et al, 2001^61^ 1 year | [underlined: Urinary incontinence] 44% (16/36) vs. 4% (1/25); RR, 11 (CI, 1.6 to 78) | [underlined: Impotence] 89% (33/37) vs. 68% (17/25); RR, 1.3 (CI, 0.98 to 1.8)
Siegel et al, 2001^62^ 4 years | NR | [underlined: Erection insufficient for intercourse] 90% (353/392) vs. 63% (40/64); RR, 1.4 (CI, 1.2 to 1.8)
Smith et al, 2009^64^ 3 years | [underlined: Urinary incontinence] 12% (111/981) vs. 3% (6/200); RR, 3.7 (CI, 2.4 to 5.7) | [underlined: Impotence] 71% (695/981) vs. 47% (94/200); RR, 1.5 (CI, 1.3 to 1.8)
Radiation therapy vs. watchful waiting
Randomized, controlled trials
Fransson et al, 2001^32^ 3 years | [underlined: Urinary incontinence, proportion of patients using pads] 17% (10/59) vs. 2% (1/49); RR, 8.3 (CI, 1.1 to 63) | NR
Cohort studies
Hoffman et al, 2003^55^ 2 years | [underlined: Urinary leakage, daily or more often] 12% (71/583) vs. 8% (19/230); RR, 1.5 (CI, 0.91 to 2.39) | [underlined: No erections at all] 39% (228/583) vs. 26% (60/230); RR, 1.5 (CI, 1.2 to 1.9)
Litwin et al, 1995b57 6 years | [underlined: No urinary control or frequent dribbling] 7% (4/56) vs. 10% (6/60); RR, 0.71 (CI, 0.21 to 2.4) | [underlined: Poor or very poor sexual function] 66% (39/59) vs. 52% (31/60); RR, 1.28 (CI, 0.94 to 1.7)
Schapira et al, 2001^61^ 1 year | [underlined: Urinary incontinence] 8% (3/38) vs. 4% (1/25); RR, 2.0 (CI, 0.22 to 18) | [underlined: Impotence] 75% (30/40) vs. 68% (17/25); RR, 1.1 (CI, 0.80 to 1.5)
Siegel et al, 2001^62^ 4 years | NR | [underlined: Erection insufficient for intercourse] 85% (269/315) vs. 63% (40/64); RR, 1.4 (CI, 1.1 to 1.7)
Smith et al, 2009^64^ 3 years | [underlined: Urinary incontinence] 2% (3/123) vs. 3% (6/200); RR, 0.81 (CI, 0.21 to 3.2) | [underlined: Impotence] 59% (72/123) vs. 47% (94/200); RR, 1.2 (CI, 1.0 to 1.5)
Thong et al, 2009^66^ 5–10 years | NR | [underlined: Problem getting an erection nearly all the time] 68% (43/63) vs. 47% (28/60); RR, 1.5 (CI, 1.1 to 2.0)
Androgen deprivation therapy vs. watchful waiting
Cohort studies
Hoffman et al, 2003^55^ 2 years | [underlined: Urinary leakage daily or more often] 11% (20/179) vs. 8% (19/230); RR, 1.4 (CI, 0.74 to 2.5) | [underlined: No erections at all] 75% (135/179) vs. 26% (60/230); RR, 2.9 (CI, 2.3 to 3.6)
Potosky et al, 2002^60^ 1 year | NR | [underlined: Impotence] 77% (68/88) vs. 27% (60/223); RR, 2.9 (CI, 2.2 to 3.7)
Smith et al, 2009^64^ 3 years | [underlined: Urinary incontinence] 3% (2/61) vs. 3% (6/200); RR, 1.1 (CI, 0.23 to 5.3) | [underlined: Impotence] 74% (45/61) vs. 47% (94/200); RR, 1.6 (CI, 1.3 to 1.9)
Cryotherapy vs. watchful waiting
Cohort studies
Smith et al, 2000^63^ 3.8 years | [underlined: Uninary incontinence] Age <70 years Total urinary control: 17/21 (81%) vs. 53/71 (74%) Occasional urinary dribbling: 4/21 (19%) vs. 15/71 (21%) Age >70 years Total urinary control: 5/21 (25%) vs. 39/71 (55%) Occasional urinary dribbling: 16/61 (75%) vs. 28/71 (39%) | [underlined: Erectile dysfunction] Age <70 years Erection firm enough for intercourse: 4/21 (20%) vs. 56/71 (81%) Age >70 years Erection firm enough for intercourse: 0/21 (0%) vs. 33/71 (47%)

Abbreviations: CI = confidence interval; NR = not reported; RR = relative risk.

Figure 2 Urinary Incontinence After Prostatectomy Versus Watchful Waiting for Treatment of Localized Prostate Cancer

Figure 2 displays a forest plot of studies reporting the relative risks for urinary incontinence in study subjects treated with prostatectomy compared with subjects undergoing watchful waiting or no active treatment. Data from Figure 2 are presented in Table 7, Appendix C2, and are described in Key Question 2 of the Results section of the evidence report. Data on urinary incontinence are described as follows: “In pooled analyses, prostatectomy was associated with a relative risk for urinary incontinence of 3.1 (95% CI, 2.0 to 4.8; risk difference, 22 percentage points [95% CI, 8.9 to 34]) compared with watchful waiting. Although statistical heterogeneity was present (I2=55%), all studies found prostatectomy to be associated with increased risk. Stratification by study type reduced statistical heterogeneity among the cohort studies (I2=22%), but the confidence intervals for the estimates overlapped.”

Prostatectomy was also associated with an increased risk of erectile dysfunction compared with watchful waiting in one RCT (RR, 1.8 [95% CI, 1.5 to 2.2])31 and five cohort studies (median RR, 1.5 [range, 1.3 to 2.1]) (Table 7, Appendix C2).55,57,61,62,64 In the RCT, the absolute increase in risk of erectile dysfunction with surgery was 36% (81% vs. 45%).31 In the cohort studies, the median rate of erectile dysfunction with watchful waiting was 52% (range, 26% to 68%), with prostatectomy associated with a median increase in absolute risk of 26 percentage points (range, 21 to 29).55,57,61,62,64 In pooled analyses, prostatectomy was associated with a relative risk for erectile dysfunction of 1.6 (95% CI, 1.4 to 1.8; I^2^=58%) (Figure 3) and pooled risk difference of 28 percentage points (95% CI, 24 to 32) compared with watchful waiting.31,55,57,61,62,64 Stratification by study type resulted in similar estimates from the one RCT (RR, 1.8 [95% CI, 1.5 to 2.2])31 and the cohort studies (RR, 1.6 [95% CI, 1.3 to 1.8]; I^2^=63%).

Figure 3 Erectile Dysfunction After Prostatectomy Versus Watchful Waiting for Treatment of Localized Prostate Cancer

Figure 3 displays a forest plot of studies reporting the relative risks for erectile dysfunction in study subjects treated with prostatectomy compared with subjects undergoing watchful waiting or no active treatment. Data from Figure 3 are presented in Table 7, Appendix C2, and are described in Key Question 2 of the Results section of the evidence report. Data on erectile dysfunction are described as follows: “In pooled analyses, prostatectomy was associated with a relative risk for erectile dysfunction of 1.6 (95% CI, 1.4 to 1.8; I2=58%; risk difference, 28 percentage points [95% CI, 24 to 32]) compared with watchful waiting. Stratification by study type results in similar estimates from the one randomized, controlled trial (RR, 1.8 [95% CI, 1.5 to 2.2]) and the cohort studies (RR, 1.6 [95% CI, 1.3 to 1.8]; I2=63%).”

For both of the above analyses, differences in study quality or mean age did not explain the observed statistical heterogeneity. Although meta-regression analysis found that studies with longer mean duration of followup tended to report smaller risk estimates for urinary incontinence (p=0.07), and including duration of followup in meta-regression analysis eliminated statistical heterogeneity (I^2^=0%), the one study that stratified patients by duration of followup reported no differences in risk estimates.31 The studies included in the meta-analysis provided few details about the specific surgical procedures evaluated. Based on practice patterns during the time periods covered by the studies, open retropubic radical prostatectomy was likely the dominant procedure. One observational study reported results for prostatectomy stratified by use of nerve sparing (n=494) or non-nerve sparing techniques (n=476); rates of erectile dysfunction were 68% and 87%, respectively, and rates of urinary incontinence were 9.4% and 15%, respectively (the combined data for both techniques were used in the meta-analysis).64

Consistent with the studies reporting dichotomous outcomes, eight cohort studies that evaluated urinary and sexual function outcomes using continuous scales found that prostatectomy was associated with worse outcomes compared with watchful waiting (Table 8, Table 9, and Appendix C2).51,54,56,59,61,63–65 All of the studies except for two54,65 used the PCI. Results based on the PCI found worse outcomes following prostatectomy compared with watchful waiting for urinary bother (median difference, −8 points [range, −17 to −1]), urinary function (median difference, −18 points [range, −30 to −9]), sexual bother (median difference, −27 points [range, −35 to 22]), and sexual function (median difference, −22 points [range, −34 to −2]) (Table 9). An outlier was one study that showed worse sexual bother scores in men following watchful waiting compared with prostatectomy.59 One RCT reported a greater likelihood of significant distress due to urinary incontinence and erectile dysfunction in prostatectomy compared with watchful waiting patients, but the difference was not statistically significant (unadjusted RR, 1.8 [95% CI, 0.8 to 4.1] and 1.3 [95% CI, 0.8 to 2.2], respectively).50

Table 8 Summary Scores for Disease-Specific and Generic Health-Related Quality of Life

Scale | Radical Prostatectomy vs. Watchful Waiting | | Radiotherapy vs. Watchful Waiting | | Androgen Deprivation Therapy vs. Watchful Waiting
Scale | Number of studies (References) | Median difference in mean scores (range) | Number of studies (References) | Median difference in mean scores (range) | Number of studies (References) | Median difference in mean scores (range)
UCLA-PCI scores
Urinary function | 6 (51, 56, 59, 61, 63, 64) | −18 (−30 to −9) | 7 (51, 56, 59, 61, 63, 64, 66) | −4 (−5 to 1) | 3 (51, 63, 64) | −4 (−9 to 1)
Urinary bother | 6 (51, 56, 59, 61, 63, 64) | −8 (−17 to −1) | 7 (51, 56, 59, 61, 63, 64, 66) | −3 (−19 to 3) | 3 (51, 63, 64) | −11 (−17 to −5)
Sexual function | 6 (51, 56, 59, 61, 63, 64) | −19 (−34 to −2) | 6 (51, 56, 59, 61, 63, 64) | −11 (−20 to −4) | 3 (51, 63, 64) | −31 (−36 to −29)
Sexual bother | 6 (51, 56, 59, 61, 63, 64) | −27 (−35 to 22) | 6 (51, 56, 59, 61, 63, 64) | −5 (−18 to 17) | 3 (51, 63, 64) | −15 (−20 to 1)
Bowel function | 5 (51, 56, 59, 61, 64) | −1 (−5 to 2) | 6 (51, 56, 59, 61, 64, 66) | −6 (−10 to −2) | 2 (51, 64) | Not calculated (−10 and −5)
Bowel bother | 5 (51, 56, 59, 61, 64) | 0 (−5 to 5) | 6 (51, 56, 59, 61, 64, 66) | −8 (−15 to −3) | 2 (51, 64) | Not calculated (−6 and −1)
SF-36 scores
Physical component summary score | 2 (51, 64) | Not calculated (2 and 3) | 3 (51, 64, 66) | 0 (−3 to 0) | 2 (51, 64) | Not calculated (−8 and −3)
Mental component summary score | 2 (51, 64) | Not calculated (0 and 1) | 3 (51, 64, 66) | 0 (−2 to 1) | 2 (51, 64) | Not calculated (−3 and 0)
Physical function | 6 (51, 54, 56, 59, 61, 63) | 8 (2 to 16) | 7 (51, 54, 56, 59, 61, 63, 66) | −5 (−10 to 4) | 2 (51, 64) | Not calculated (−7 and 3)
Physical role function | 6 (51, 54, 56, 59, 61, 63) | 2 (−10 to 9) | 7 (51, 54, 56, 59, 61, 63, 66) | −9 (−22 to 1) | 3 (51, 60, 64) | −11 (−23 to 11)
Bodily pain | 6 (51, 54, 56, 59, 61, 63) | 3 (−5 to 10) | 7 (51, 54, 56, 59, 61, 63, 66) | −5 (−11 to 0) | 3 (51, 60, 64) | −6 (−8 to −1)
General health | 6 (51, 54, 56, 59, 61, 63) | 4 (2 to 21) | 7 (51, 54, 56, 59, 61, 63, 66) | 1 (−9 to 3) | 2 (51, 64) | Not calculated (−5 and −2)
Vitality | 7 (51, 54, 56, 58, 59, 61, 63) | 3 (−2 to 14) | 8 (51, 54, 56, 58, 59, 61, 63, 66) | −4 (−5 to 1) | 3 (51, 60, 64) | −7 (−7 to −7)
Social function | 6 (51, 56, 58, 59, 61, 63) | 3 (−2 to 11) | 7 (51, 54, 56, 59, 61, 63, 66) | −2 (−9 to 1) | 2 (51, 64) | Not calculated (−10 and −4)
Emotional role function | 7 (51, 54, 56, 58, 59, 61, 63) | 8 (−5 to 13) | 8 (51, 54, 56, 58, 59, 61, 63, 66) | −4 (−9 to 19) | 3 (51, 60, 64) | −15 (−16 to −3)
Mental health | 7 (51, 54, 56, 58, 59, 61, 63) | −1 (−4 to 10) | 8 (51, 54, 56, 58, 59, 61, 63, 66) | −2 (−6 to 2) | 3 (51, 60, 64) | −4 (−6 to 0)

Abbreviations: UCLA-PCI = University of California, Los Angeles Prostate Cancer Index; SF-36 = Short-form 36-item Health Survey.

Table 9 Summary of UCLA Prostate Cancer Index Scores

Author, year Duration of followup | Urinary function | | | Urinary bother | | | Sexual function | | | Sexual bother | | | Bowel function | | | Bowel bother
Author, year Duration of followup | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD
Radical prostatectomy vs. watchful waiting
Bacon et al, 2001^51^ Up to 5 years | 76 | 93 | −17 | 82 | 89 | −7 | 26 | 54 | −28 | 43 | 74 | −31 | 86 | 91 | −5 | 86 | 89 | −3
Litwin et al, 1995a56 6 years | 65 | 86 | −21 | 68 | 80 | −12 | 19 | 41 | −22 | 13 | 37 | −24 | 82 | 84 | −2 | 80 | 85 | −5
Lubeck et al, 1999^59^ 2 years | 71 | 87 | −16 | 81 | 84 | −3 | 27 | 29 | −2 | 47 | 25 | 22 | 88 | 89 | −1 | 90 | 90 | 0
Schapira et al, 2001^61^ 1 year | 62 (−28) | 92 (+5) | −30 (−33) | 67 (−15) | 84 (−2) | −17 (−13) | 20 (−38) | 36 (−9) | −16 (−29) | 29 (−35) | 62 (+6) | −33 (−41) | 88 (0) | 86 (−3) | 2 (3) | 86 (−5) | 81 (−5) | +5 (0)
Smith et al, 2000^63^ 4 years | 75 | 94 | −19 | 78 | 88 | −10 | 26 | 60 | −34 | 34 | 69 | −35 | NR | NR | -- | NR | NR | --
Smith et al, 2009^64^ (Nerve sparing RP) 3 years | 86 | 92 | −6^*^ | 85 | 84 | 1^*^ | 35 | 44 | −9^*^ | 52 | 66 | −14^*^ | 88 | 87 | 1^*^ | 90 | 88 | 2^*^
Smith et al, 2009^64^ (Non-nerve sparing RP) 3 years | 83 | 92 | −9 | 83 | 84 | −1 | 22 | 44 | −22 | 54 | 66 | −12 | 89 | 87 | 2 | 91 | 88 | 3
No. of studies | 6 | | | 6 | | | 6 | | | 6 | | | 5 | | | 5
Median (range) | −18 (−30 to −9) | | | −8 (−17 to −1) | | | −19 (−34 to −2) | | | −27 (−35 to 22) | | | −1 (−5 to 2) | | | 0 (−5 to 5)

Author, year Duration of followup | Urinary function | | | Urinary bother | | | Sexual function | | | Sexual bother | | | Bowel function | | | Bowel bother
Author, year Duration of followup | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD
Radiotherapy vs. watchful waiting
Bacon et al, 2001^51^ (EBRT) Up to 5 years | 89 | 93 | −4 | 83 | 89 | −6 | 34 | 54 | −20 | 51 | 54 | −3 | 81 | 91 | −10 | 78 | 89 | −11
Bacon et al, 2001^51^ (Brachytherapy) Up to 5 years | 87 | 93 | −6^*^ | 75 | 89 | −14^*^ | 36 | 54 | −18^*^ | 54 | 74 | −20^*^ | 80 | 91 | −11^*^ | 72 | 89 | −17^*^
Litwin et al, 1995a56 6 years | 82 | 86 | −4 | 77 | 80 | −3 | 35 | 41 | −6 | 29 | 37 | −8 | 81 | 84 | −3 | 77 | 85 | −8
Lubeck et al, 1999^59^ 2 years | 85 | 87 | −2 | 65 | 84 | −19 | 25 | 29 | −4 | 32 | 25 | 7 | 83 | 89 | −6 | 75 | 90 | −15
Schapira et al, 2001^61^ 1 year | 89 (0) | 92 (+5) | −3 (−5) | 81 (+1) | 84 (−2) | −3 (3) | 25 (−14) | 36 (−9) | −11 (−5) | 60 (+5) | 62 (+6) | −2 (+11) | 79 (−10) | 86 (−3) | −7 (−7) | 77 (−9) | 81 (−5) | −4 (−4)
Smith et al, 2000^63^ 4 years | 89 | 94 | −5 | 81 | 88 | −7 | 40 | 60 | −20 | 51 | 69 | −18 | NR | NR | -- | NR | NR | --
Smith et al, 2009^64^ (EBRT) 3 years | 93 | 92 | 1 | 81 | 84 | −3 | 32 | 44 | −12 | 58 | 66 | −8 | 85 | 87 | −2 | 85 | 88 | −3
Smith et al, 2009^64^ (LDB) 3 years | 94 | 92 | 2^*^ | 84 | 84 | 0^*^ | 54 | 44 | 10^*^ | 67 | 66 | 1^*^ | 89 | 87 | 2^*^ | 91 | 88 | 3^*^
Smith et al, 2009^64^ (HDB) 3 years | 90 | 92 | −2^*^ | 77 | 84 | −7^*^ | 30 | 44 | −14^*^ | 61 | 66 | −5^*^ | 88 | 87 | 1^*^ | 84 | 88 | −4^*^
Thong et al, 2009^66,†^ 5–10 years | 82 | 86 | −4 | 75 | 78 | 3 | NR | NR | -- | NR | NR | -- | 87 | 93 | −6 | 85 | 94 | −9
No. of studies | 7 | | | 7 | | | 6 | | | 6 | | | 6 | | | 6
Median (range) | −4 (−5 to 1) | | | −3 (−19 to 3) | | | −11 (−20 to −4) | | | −5 (−18 to 17) | | | −6 (−10 to −2) | | | −8 (−15 to −3)

Author, year Duration of followup | Urinary function | | | Urinary bother | | | Sexual function | | | Sexual bother | | | Bowel function | | | Bowel bother
Author, year Duration of followup | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD
Androgen deprivation therapy vs. watchful waiting
Bacon et al, 2001^51^ Up to 5 years | 84 | 93 | −9 | 72 | 89 | −17 | 25 | 54 | −29 | 59 | 74 | −15 | 81 | 91 | −10 | 83 | 89 | −6
Smith et al, 2000^63^ 4 years^‡^ | 90 | 94 | −4 | 83 | 88 | −5 | 29 | 60 | −31 | 49 | 69 | −20 | NR | NR | -- | NR | NR | --
Smith et al, 2009^64^ 3 years | 93 | 92 | 1 | 73 | 84 | −11 | 8 | 44 | −36 | 67 | 66 | 1 | 82 | 87 | −5 | 87 | 88 | −1
No. of studies | 3 | | | 3 | | | 3 | | | 3 | | | 2 | | | 2
Median (range) | −4 (−9 to 1) | | | −11 (−17 to −5) | | | −31 (−36 to −29) | | | −15 (−20 to 1) | | | NA | | | NA

Author, year Duration of followup | Urinary function | | | Urinary bother | | | Sexual function | | | Sexual bother | | | Bowel function | | | Bowel bother
Author, year Duration of followup | CRYO | WW | MD | CRYO | WW | MD | CRYO | WW | MD | CRYO | WW | MD | CRYO | WW | MD | CRYO | WW | MD
Cryotherapy vs. watchful waiting
Smith et al, 2000^63^ 4 years^‡^ | 93 | 94 | -1 | 90 | 88 | 2 | 26 | 60 | -34 | 43 | 69 | -26 | NR | NR | _ | NR | NR | _
No. of studies | 1 | | | 1 | | | 1 | | | 1 | | | 0 | | | 0
Median (range) | NA | | | NA | | | NA | | | NA | | | NA | | | NA

Note: All scores are mean scores at followup (i.e., mean change from baseline), on a 0-to-100 scale.

* Not included in calculation of median.

† Expanded Prostate Cancer Index Composite scores.

‡ For the subset of patients diagnosed after 1994 (806/2334), mean duration of followup was 1 year.

Abbreviations: ADT = androgen deprivation therapy; CRYO = cryotherapy; EBRT = external beam radiation therapy; HDB = high-dose brachytherapy; LDB = low-dose brachytherapy; MD = mean difference; NA = not applicable; RP = radical prostatectomy; RT=radiotherapy; UCLA = University of California, Los Angeles; WW = watchful waiting.

Quality of life. Nine studies reported generic quality of life (Table 8, Table 10, and Appendix C2).51,54,56,58,59,61,63,64 Two studies reported very similar SF-36 physical and mental component summary scores following prostatectomy and watchful waiting.51,64 On specific SF-36 subscales, prostatectomy was associated with better physical function (6 studies; median difference, 8 points [range, 2 to 16])51,54,56,59,61,63 and emotional role function scores (7 studies; median difference, 8 points [range, −5 to 13]),51,54,56,58,59,61,63 with small or no clear differences on other SF-36 subscales.

Table 10 Summary of Short-Form 36-Item Health Survey Scores

Author, year Duration of followup | Physical component summary score | | | Mental component summary score | | | Physical function | | | Physical role function | | | Bodily pain | | | General health | | | Vitality | | | Social function | | | Emotional role function | | | Mental Health
Author, year Duration of followup | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD | RP | WW | MD
Prostatectomy vs. watchful waiting
Bacon et al, 2001^51^ Up to 5 years | 52^*^ | 49^*^ | 3 | 55^*^ | 55^*^ | 0 | 90 | 79 | 11 | 86 | 85 | 1 | 85 | 81 | 4 | 80 | 71 | 9 | 71 | 68 | 3 | 92 | 87 | 5 | 90 | 90 | 0 | 84 | 83 | 1
Galbraith et al, 2001^54^ 1.5 years | NR | NR | _ | NR | NR | _ | 81 (1) | 75 (0) | 6 (1) | 55 (−12) | 65 (12) | −10 (−24) | 85 (−2) | 84 (4) | 1 (−6) | 58 (6) | 54 (6) | 4 (0) | 62 (−1) | 64 (2) | 2 (1) | NR | NR | _ | 80 (18) | 70 (9) | 10 (9) | 77 (1) | 79 (7) | −2 (−6)
Litwin et al, 1995a56 5.6 years | NR | NR | _ | NR | NR | _ | 75 | 71 | 4 | 61 | 55 | 6 | 77 | 74 | 3 | 65 | 63 | 2 | 60 | 60 | 0 | 80 | 80 | 0 | 70 | 57 | 13 | 76 | 77 | −1
Litwin et al, 2002^58^ 2 years | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | 73 | 66 | 7 | 100 | 89 | 11 | 94 | 86 | 8 | 85 | 81 | 4
Lubeck et al, 1999^59^ 2 years | NR | NR | _ | NR | NR | _ | 86 | 71 | 15 | 72 | 63 | 9 | 84 | 76 | 8 | 75 | 54 | 21 | 71 | 57 | 14 | 89 | 78 | 11 | 84 | 73 | 11 | 86 | 76 | 10
Schapira et al, 2001^61^ 1 year | NR | NR | _ | NR | NR | _ | 84 (−5) | 68 (−8) | 16 (3) | 72 (−11) | 64 (−2) | 8 (−9) | 78 (−10) | 68 (−2) | 10 (−8) | 71 (−3) | 68 (4) | 3 (−7) | 69 (−2) | 60 (−4) | 9 (2) | 88 (0) | 86 (−1) | 2 (1) | 83 (3) | 77 (−7) | 6 (10) | 77 (2) | 81 (0) | −4 (2)
Smith et al, 2000^63^ 3.8 years | NR | NR | _ | NR | NR | _ | 87 | 85 | 2 | 78 | 80 | −2 | 82 | 87 | −5 | 76 | 71 | 5 | 67 | 69 | −2 | 90 | 92 | −2 | 86 | 91 | −5 | 81 | 82 | −1
Smith et al, 2009^64^ 3 years (Nerve- sparing) | 50^*^ | 47^*^ | 3 | 53^*^ | 53^*^ | 0 | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _
Smith et al, 2009^64^ 3 years (Non nerve- sparing) | 49^*^ | 47^*^ | 2 | 54^*^ | 53^*^ | 1 | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _
Number of studies | 2 | | | 2 | | | 6 | | | 6 | | | 6 | | | 6 | | | 7 | | | 6 | | | 7 | | | 7
Median (range) | NA | | | NA | | | 8 (2 to 16) | | | 2 (−10 to 9) | | | 3 (−5 to 10) | | | 4 (2 to 21) | | | 3 (−2 to 14) | | | 3 (−2 to 11) | | | 8 (−5 to 13) | | | −1 (−4 to 10)

Author, year Duration of followup | Physical component summary score | | | Mental component summary score | | | Physical function | | | Physical role function | | | Bodily pain | | | General health | | | Vitality | | | Social function | | | Emotional role function | | | Mental Health
Author, year Duration of followup | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD | RT | WW | MD
Radiation therapy vs. watchful waiting
Bacon et al, 2001^51^ Up to 5 years (EBRT) | 49^*^ | 49^*^ | 0 | 53^*^ | 55^*^ | −2 | 83 | 79 | 4 | 72 | 85 | −13 | 79 | 81 | −2 | 74 | 71 | 3 | 64 | 68 | −4 | 87 | 87 | 0 | 82 | 90 | −4 | 81 | 83 | −2
Bacon et al, 2001^51^ Up to 5 years (Brachytherapy) | 51^*^ | 49^*^ | 2^ | 54^*^ | 55^*^ | −1^ | 90 | 79 | 11^ | 79 | 85 | −6^ | 81 | 81 | 0^ | 78 | 71 | 7^ | 66 | 68 | −2^ | 92 | 87 | 5^ | 86 | 90 | −4^ | 84 | 83 | 1^
Galbraith et al, 2001^54^ 1.5 years (Conventional radiation) | NR | NR | _ | NR | NR | _ | 70 (−9) | 75 (0) | −5 (−9) | 53 (−15) | 67 (12) | −14 (−27) | 73 (−13) | 84 (4) | −11 (−17) | 55 (−3) | 54 (6) | 1 (−9) | 59 (−7) | 64 (2) | −5 (−9) | NR | NR | _ | 61 (−17) | 70 (9) | −9 (−26) | 77 (4) | 79 (7) | −2 (−3)
Galbraith et al, 2001^54^ 1.5 years (Proton-beam radiation) | NR | NR | _ | NR | NR | _ | 78 (−6) | 75 (0) | 3^ (−6) | 82 (0) | 67 (+12) | 15^ (+12) | 80 (+1) | 84 (+4) | −4^ (+5) | 59 (+5) | 54 (+6) | 5^ (+1) | 63 (+12) | 64 (+2) | −1^ (+10) | NR | NR | _ | 90 (+8) | 70 (+9) | 20^ (−1) | 82 (+12) | 79 (+7) | 3^ (+5)
Galbraith et al, 2001^54^ 1.5 years (Mixed- beam radiation) | NR | NR | _ | NR | NR | _ | 78 (−6) | 75 (0) | 3^ (−6) | 67 (−6) | 67 (+12) | 0^ (−18) | 82 (0) | 84 (+4) | −2^ (−4) | 58 (−2) | 54 (+6) | 4^ (−8) | 63 (+2) | 64 (+2) | −1^ (0) | NR | NR | _ | 80 (+8) | 70 (+9) | 10^ (−1) | 80 (+5) | 79 (+7) | 1^ (−2)
Litwin et al, 1995a56 5.6 years | NR | NR | _ | NR | NR | _ | 74 | 71 | 3 | 56 | 55 | 1 | 74 | 74 | 0 | 66 | 63 | 3 | 61 | 60 | 1 | 81 | 80 | 1 | 76 | 57 | 19 | 79 | 77 | 2
Litwin et al, 2002^58^ 2 years | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | 61 | 66 | −5 | 86 | 89 | −3 | 81 | 86 | −5 | 75 | 81 | −6
Lubeck et al, 1999^59^ 2 years | NR | NR | _ | NR | NR | _ | 65 | 71 | −6 | 55 | 63 | −8 | 74 | 76 | −2 | 54 | 54 | 0 | 54 | 57 | −3 | 77 | 78 | −1 | 76 | 73 | 3 | 78 | 76 | 2
Schapira et al, 2001^61^ 1 year | NR | NR | _ | NR | NR | _ | 58 (−5) | 68 (−8) | −10 (3) | 42 (−15) | 64 (−2) | −22 (−13) | 61 (−2) | 68 (−4) | −7 (2) | 59 (−1) | 68 (4) | −9 (−5) | 55 (−4) | 60 (−4) | −5 (0) | 59 (−19) | 68 (−1) | −9 (−18) | 70 (−1) | 77 (−7) | −7 (6) | 76 (1) | 81 (0) | −5 (1)
Smith et al, 2000^63^ 3.8 years | NR | NR | _ | NR | NR | _ | 80 | 85 | −5 | 71 | 80 | −9 | 82 | 87 | −5 | 70 | 71 | −1 | 65 | 69 | −4 | 88 | 92 | −4 | 85 | 91 | −6 | 82 | 82 | 0
Smith et al, 2009^64^ 3 years (EBRT) | 47^*^ | 47^*^ | 0 | 53^*^ | 53^*^ | 0 | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _
Smith et al, 2009^64^ 3 years (LDB) | 49^*^ | 47^*^ | 2^†^ | 54^*^ | 53^*^ | 1^†^ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _
Smith et al, 2009^64^ 3 years (HDB) | 49^*^ | 47^*^ | 2^†^ | 52^*^ | 53^*^ | −1^†^ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _
Thong et al, 2009^66^ 5–10 years | 42 | 45 | −3 | 50 | 49 | 1 | 62 | 70 | −8 | 56 | 57 | −1 | 70 | 77 | −7 | 60 | 59 | 1 | 62 | 65 | −3 | 81 | 79 | −2 | 78 | 71 | 7 | 73 | 77 | −4
Number of studies | 3 | | | 3 | | | 7 | | | 7 | | | 7 | | | 7 | | | 8 | | | 7 | | | 8 | | | 8
Median (range) | 0 (−3 to 0) | | | 0 (−2 to 1) | | | −5 (−10 to 4) | | | −9 (−22 to 1) | | | −5 (−11 to 0) | | | 1 (−9 to 3) | | | −4 (−5 to 1) | | | −2 (−9 to 1) | | | −4 (−9 to 19) | | | −2 (−6 to 2)

Author, year Duration of followup | Physical component summary score | | | Mental component summary score | | | Physical function | | | Physical role function | | | Bodily pain | | | General health | | | Vitality | | | Social function | | | Emotional role function | | | Mental Health
Author, year Duration of followup | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD | ADT | WW | MD
Androgen deprivation therapy vs. watchful waiting
Bacon et al, 2001^51^ Up to 5 years | 46^*^ | 49^*^ | −3 | 52^*^ | 55^*^ | −3 | 76 | 79 | 3 | 62 | 85 | −23 | 75 | 81 | −6 | 66 | 71 | −5 | 61 | 68 | −7 | 83 | 87 | −4 | 74 | 90 | −16 | 79 | 83 | −4
Potosky et al, 2002^60^ 1 year | NR | NR | _ | NR | NR | _ | NR | NR | _ | 50 | 61 | −11 | 73 | 74 | −1 | NR | NR | _ | 53 | 60 | −7 | NR | NR | _ | 74 | 77 | −3 | 78 | 78 | 0
Smith et al, 2000^63^ 3.8 years | NR | NR | _ | NR | NR | _ | 72 | 85 | −7 | 69 | 80 | −11 | 79 | 87 | −8 | 69 | 71 | −2 | 62 | 69 | −7 | 82 | 92 | −10 | 76 | 91 | −15 | 76 | 82 | −6
Smith et al, 2009^64^ 3 years | 39^*^ | 47^*^ | −8 | 53^*^ | 53^*^ | 0 | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _ | NR | NR | _
Number of studies | 2 | | | 2 | | | 2 | | | 3 | | | 3 | | | 2 | | | 3 | | | 2 | | | 3 | | | 3
Median (range) | NA | | | NA | | | NA | | | −11 (−23 to −11) | | | −6 (−8 to −1) | | | NA | | | −7 (−7 to −7) | | | NA | | | −15 (−16 to −3) | | | −4 (−6 to 0)

Author, year Duration of followup | Physical component summary score | | | Mental component summary score | | | Physical function | | | Physical role function | | | Bodily pain | | | General health | | | Vitality | | | Social function | | | Emotional role function | | | Mental Health
Author, year Duration of followup | CRY | WW | MD | CRY | WW | MD | CRY | WW | MD | CRY | WW | MD | CRY | WW | MD | CRY | WW | MD | CRY | WW | MD | CRY | WW | MD | CRY | WW | MD | CRY | WW | MD
Cryotherapy vs. watchful waiting
Smith et al, 2000^63^ 3.8 years | NR | NR | _ | NR | NR | _ | 87 | 85 | 3 | 84 | 80 | 4 | 87 | 87 | 0 | 72 | 71 | 1 | 69 | 69 | 0 | 95 | 92 | 3 | 97 | 91 | 6 | 86 | 82 | 4
Number of studies | 0 | | | 0 | | | 1 | | | 1 | | | 1 | | | 1 | | | 1 | | | 1 | | | 1 | | | 1
Median (range) | NA | | | NA | | | NA | | | NA | | | NA | | | NA | | | NA | | | NA | | | NA | | | NA

Note: All data are mean scores (i.e., mean change from baseline) on a 0-to-100 scale (higher scores indicate better function), unless indicated otherwise.

* Scores standardized to the U.S. general population, mean of 50 (standard deviation, 10).

† Not included in calculation of median.

Abbreviations: ADT = androgen deprivation therapy; CRY = cryotherapy; EBRT = external beam radiation therapy; HDB = high-dose brachytherapy; LDB = low-dose brachytherapy; RP = radical prostatectomy; RT = radiotherapy; MD=mean difference; NA = not applicable; WW = watchful waiting.

Surgical complications. Evidence on short-term (≤30 days) complications following prostatectomy is available from large database studies and case series of patients with localized or more advanced prostate cancer. The largest study (n=101,604 Medicare claimants) reported a 30-day perioperative mortality of 0.5%^68^; three large observational studies reported nearly identical perioperative mortality rates (about 0.5%) (Appendix C5).67,69,70 Studies showed that advanced age and a higher number of more serious comorbidities were associated with higher mortality rates, although absolute rates remained low even in men at higher risk (<1%). Some studies have also shown that low surgical volume is associated with higher postsurgical mortality,68,70 while others have not found such an association.69 In the Medicare database study, the perioperative rate of serious cardiovascular events was 3% and the rate of vascular events (including pulmonary embolism and deep vein thrombosis) was 2%.68 In two other large studies (n=1,243^71^ and n=11,010^67,71^), rates of cardiovascular events were 0.6% and 3%, respectively, while rates of vascular events (including pulmonary embolism and deep vein thrombosis) were 1% and 2%, respectively. Serious rectal or ureteral injury due to surgery ranged from 0.3% to 0.6%.68,71

Comparative data on the effects of surgical technique on complication rates are limited. In the largest cohort study (n=4,592), medical complications were more likely to occur with laparoscopic compared with open prostatectomy in men with localized prostate cancer (HR, 1.9 [95% CI, 1.5 to 2.4]).72 When limited to serious medical complications, rates were about 2% for both open and laparoscopic prostatectomy patients. Corresponding rates of all surgical complications were 5% and 7%. Mortality was not reported.

Other harms. Five studies (reported in six publications) found no clear differences between prostatectomy and watchful waiting in risk of bowel dysfunction (Appendix C2).31,50,54,55,57,64 One RCT found similar rates of constipation (9% for prostatectomy vs. 8% for watchful waiting), blood or mucus in stool (1% in both groups), and diarrhea (6% vs. 5%, respectively).50 Bowel urgency rates ranged from 7% to 16% in the prostatectomy groups and 6% to 15% in watchful waiting groups in three studies.31,55,57 There was a nonsignificant trend toward decreased incidence of fecal leakage in the prostatectomy group (RR, 0.3 [95% CI, 0.04 to 3.2]) compared with watchful waiting in one study.31 One RCT found no difference between prostatectomy and watchful waiting in risk of high levels of anxiety, depression, or worry after 4 years (Appendix C2).50

#### Radiation therapy

Urinary incontinence and erectile dysfunction. Radiation therapy was associated with increased risk of urinary incontinence compared with watchful waiting in one small RCT, but the estimate was very imprecise (RR, 8.3 [95% CI, 1.1 to 63]) due to small numbers of events (one in the watchful waiting group) (Table 7, Appendix C2).32 There was no clear increase in risk in four (total n=1,910) cohort studies (median RR, 1.1 [range, 0.71 to 2.0]).55,57,61,64 Pooled analyses showed no statistically significant difference in risk of urinary incontinence (RR, 1.4 [95% CI, 0.78 to 2.4]; I^2^=20%; risk difference, 3.1 percentage points [95% CI, −1.8 to 8.0]) (Figure 4). The single RCT32 reported a substantially larger risk ratio (8.3 [95% CI, 1.1 to 63]) than the cohort studies (1.3 [95% CI, 0.85 to 2.0]; I^2^=0%), but excluding the RCT did not change the overall pooled estimate. Differences in study quality, duration of followup, or mean age did not explain the observed statistical heterogeneity.

Figure 4 Urinary Incontinence After Radiation Therapy Versus Watchful Waiting for Treatment of Localized Prostate Cancer

Figure 4 displays a forest plot of studies reporting the relative risks for urinary incontinence in study subjects treated with radiation therapy compared with subjects undergoing watchful waiting or no active treatment. Data from Figure 4 are presented in Table 7, Appendix C2, and are described in Key Question 2 of the Results section of the evidence report. Data on urinary incontinence are described as follows: “Pooled results showed no statistically significant difference in risk of urinary incontinence (RR, 1.4 [95% CI, 0.78 to 2.4]; I2=20%; risk difference, 3.1 percentage points [95% CI, −1.8 to 8.0]). The single randomized, controlled trial (RCT) reported a substantially larger risk ratio (8.3 [95% CI, 1.1 to 63]) than the cohort studies (1.3 [95% CI, 0.85 to 2.0]; I2=0%), but excluding the RCT did not change the overall pooled estimate. Differences in study quality, duration of followup, or mean age did not explain the observed statistical heterogeneity.”

Radiation therapy was associated with increased risk of erectile dysfunction compared with watchful waiting in six cohort studies, with similar estimates across studies (median RR, 1.3 [range, 1.1 to 1.5]) (Table 7, Appendix Table C2).55,57,61,62,64,66 Rates of erectile dysfunction ranged from 26% to 68% (median, 50%) with watchful waiting; radiation therapy was associated with a median increase in pooled absolute risk of 14 percentage points (range, 7 to 22). In pooled analyses, radiation therapy was associated with a relative risk for erectile dysfunction of 1.3 (95% CI, 1.2 to 1.5; I^2^=0%) (Figure 5) and risk difference of 15 percentage points (95% CI, 10 to 20).

Figure 5 Erectile Dysfunction After Radiation Therapy Versus Watchful Waiting for Treatment of Localized Prostate Cancer

Figure 5 displays a forest plot of studies reporting the relative risks for erectile dysfunction in study subjects treated with prostatectomy compared with subjects undergoing watchful waiting or no active treatment. Data from Figure 5 are presented in Table 7, Appendix C2, and are described in Key Question 2 of the Results section of the evidence report. Data on erectile dysfunction are described as follows: “In pooled analyses, radiation therapy was associated with a relative risk for erectile dysfunction of 1.3 (95% CI, 1.2 to 1.5; I2=0%; risk difference, 15 percentage points [95% CI, 10 to 20]).”

In six studies included in the meta-analyses, details about the type of radiation therapy (e.g., EBRT vs. brachytherapy) or dosing regimen were not provided. The exception was one good-quality cohort study that reported urinary incontinence after 3 years in 7.0% of men following high-dose brachytherapy (n=47), 5.4% following low-dose brachytherapy (n=58), and 2.7% following EBRT (n=123).64 Rates of erectile dysfunction were 72%, 36%, and 68%, respectively. For the meta-analysis, we used the rates for men who underwent EBRT, which was the presumed focus of the other pooled studies.

Consistent with the studies reporting dichotomous outcomes, 11 studies found that radiation therapy was associated with worse sexual function compared with watchful waiting based on continuous scales, though no clear differences were seen in sexual bother scores and measures of urinary function (Table 8, Table 9, and Appendix C2).33,51,52,54,56,59,61,63–66 Most studies used the PCI to measure urinary and sexual function and bother (Table 8 and Table 9),51,56,59,61,63,64,66 though results appeared similar in studies that used other measures.

Quality of life. Ten studies reported generic quality of life (Table 8, Table 10, and Appendix C3).33,51,54,56,58,59,61,63,64,66 Three studies found no differences between radiation therapy and watchful waiting in SF-36 physical (median difference, 0 [range, −3 to 0]) or mental component summary scores (median difference, 0 [range, −2 to 1]) (Table 8 and Table 10).51,64,66 Results favored watchful waiting on the physical role function subscale (7 studies; median difference, −9 points [range, −22 to 1]),51,54,56,59,61,63,66 with no clear differences on other SF-36 subscales. All of the studies except for the one RCT33 used the SF-36 or a modified version of the SF-36 (SF-12)64 to measure quality of life. Results from the RCT, which used the Quality of Life Questionnaire for Cancer to measure general quality of life, also found no clear differences between radiation therapy and watchful waiting (Appendix Table C2).33

Other harms. Six cohort studies consistently found that radiotherapy was associated with worse PCI bowel bother (median difference, −8 points [range, −15 to −3]) and function (median difference, −6 points [range, −10 to −2]) compared with watchful waiting (Table 9).51,56,59,61,64,66 Studies that used measures other than the PCI also reported more bowel dysfunction following radiotherapy compared with watchful waiting (Appendix Table C2).33,54,65,66 In studies that evaluated bowel function serially, effects appeared most pronounced in the first few months after radiation therapy and gradually improved.33,54,59,65 This might help explain the inconsistent results among studies that reported dichotomous outcomes: although one study found that radiation therapy was associated with substantially increased risk of bowel urgency after 2 years (3.2% vs. 0.4%; RR, 7.5 [95% CI, 1.0 to 56]),55 two studies with longer duration of followup (5.6^57^ and 3 years64) found no increased risk.

One cohort study reported comparable effects of EBRT and brachytherapy on PCI bowel function and bother (Table 9).51 One other study found that low-dose brachytherapy was associated with smaller effects on bowel bother (about 3-point change from baseline) compared with high-dose brachytherapy (9-point change) or EBRT (8-point change).64

No study reported effects of radiation therapy versus watchful waiting on anxiety or depression.

#### Androgen deprivation therapy

Urinary incontinence and erectile dysfunction. There was no difference between ADT and watchful waiting in risk of urinary incontinence in two cohort studies (RR, 1.4 [95% CI, 0.74 to 2.5]55 and RR, 1.1 [95% CI, 0.23 to 5.3])64 (Table 7 and Appendix C2). ADT was associated with an increased risk of erectile dysfunction in two cohort studies (RR, 2.9 [95% CI, 2.3 to 3.6]55 and RR, 1.6 [95% CI, 1.3 to 1.9])64 (Table 7). Rates of erectile dysfunction with watchful waiting were 26% and 47% in the two studies; ADT was associated with a median increase in pooled absolute risk of 49 and 27 percentage points, respectively. One study did not provide details about the ADT regimen.64 In the other study, ADT consisted of orchiectomy, luteinizing hormone-releasing hormone agonist injections, or central androgen block, either with or without flutamide or bicalutamide.55,60

Three cohort studies (duration of followup, 3 to 6 years) reported urinary and sexual quality of life scores following ADT versus watchful waiting using the PCI (Table 8, Table 9, and Appendix C2).51,63,64 Mean PCI sexual function scores were lower following ADT compared with watchful waiting (3 studies; median difference, −31 points [range, −36 to −29]) (Table 8 and Table 9). Men treated with ADT had more sexual bother compared with men treated with watchful waiting in two studies (mean differences of −15 and −20 points),51,63 but the third found no difference.64 Differences in PCI urinary function ranged from −9 points (favoring watchful waiting) to no difference.51,63,64 Unlike the other studies, which adjusted for age and other confounders, the latter study reported unadjusted scores. Differences in PCI urinary bother scores ranged from −5 to −17 points.51,63,64

Quality of life. General quality of life following ADT compared with watchful waiting was assessed in four cohort studies, all of which reported SF-36 scores (Table 8, Table 10, and Appendix C2).51, 60,63,64 Compared with watchful waiting, ADT was associated with somewhat worse SF-36 physical component summary scores (mean differences of −3 and −8 points)51,64 and most SF-36 subscales, but there were too few studies to draw strong conclusions.

In two studies with overlapping patient populations, ADT was associated with greater risk of limitations in daily functioning compared with watchful waiting at 1 year (22% vs. 9%)60 and 2 years (17% vs. 4%).55

Other harms. Other harms associated with ADT were infrequently reported. In one cohort study, gynecomastia (20% for ADT vs. 4% for watchful waiting) and hot flashes (58% vs. 11%) were more frequent with ADT than watchful waiting (p<0.001 for both outcomes).60 In two studies, bowel dysfunction was similar in men who received ADT compared with those who underwent watchful waiting at 2^55^ or 3 years64 of followup. There was no difference in the proportion of men who reported some or a lot of worry about their prostate cancer in one study of ADT compared with watchful waiting (26% vs. 27%; p=0.3).60

Studies that reported other important harms (such as coronary heart disease, myocardial infarction, diabetes, or fractures) associated with ADT for prostate cancer did not meet our inclusion criteria because they did not evaluate patients with localized prostate cancer79–82 or did not compare ADT with watchful waiting.83

#### Cryotherapy

Evidence on harms associated with cryotherapy for localized prostate cancer is very limited. One fair-quality cohort study followed a small (n=21) group of men who received cryotherapy for a mean duration of 46 months (Table 7, Table 10, and Appendix C2).63 Among men older than age 70 years at diagnosis, 25% of those who received cryotherapy reported total urinary control and 75% reported occasional urinary dribbling compared with 55% and 39% among men who underwent watchful waiting. Among men younger than age 70 years at diagnosis, 81% of those who received cryotherapy had total urinary control and 19% had occasional dribbling compared with 74% and 21% in those who underwent watchful waiting. In the same study, 0% and 20% of men older and younger than age 70 years at diagnosis, respectively, reported erections firm enough for intercourse after cryotherapy compared with 47% and 81% among those who underwent watchful waiting.

A 2008 Cochrane review of cryotherapy for localized prostate cancer identified no randomized trials.84 From case series, it reported rates of erectile dysfunction that ranged from 47% to 100% and rates of urinary incontinence from 1% to 19%.

#### High-intensity focused ultrasonography

We identified no randomized trials or cohort studies on harms associated with HIFU for localized prostate cancer. Five uncontrolled studies reported harms associated with HIFU for localized prostate cancer (Appendix C5).73–77 No study enrolled more than 1,000 patients (sample sizes ranged from 63 to 402 [median, 142]), and methodological shortcomings were present in all of the studies (e.g., incomplete information regarding method of patient selection). Harms were voluntarily reported76 or actively elicited73–75,77 using a patient questionnaire. Only one study reported use of a formal, disease-specific measure to assess harms.75 Duration of followup ranged from 407 days to 34 months. Rates of urinary incontinence ranged from 2% to 11% (four studies)73,74,76,77 and rates of urinary tract infection ranged from 5% to 14% (three studies).73,74,76 In two studies, about half of men with potency at baseline (45% and 53%) developed erectile dysfunction following HIFU.73,74 One study used the PCI and the International Prostate Symptom Score (IPSS) to assess outcomes of whole versus focal HIFU.75 There were no significant differences between the two types of HIFU in IPSS (8.1 vs. 9.2) or urinary bother (86 vs. 80) or urinary function (97 vs. 86) scores.

## Contextual Question How Often is Each Treatment Currently Performed in U.S. Men With PSA-Detected Cancer?

Data on the proportion of men who receive various prostate cancer treatments in the United States are available from the SEER program and the Cancer of the Prostate Strategic Urologic Research Endeavor (CaPSURE) registry.7,85,86 SEER collects data from population-based cancer registries covering approximately one quarter of the U.S. population. CaPSURE includes data from 37 community urology practices, three academic medical centers, and three Veterans Health Administration hospitals throughout the United States, with 23 active sites.

An analysis of 19 years of SEER data from 1986 (1 year prior to the introduction of PSA testing) to 2005 found that of approximately 1,300,000 men diagnosed with prostate cancer as a result of PSA testing, 44% elected to have surgical treatment and 37% chose radiation therapy. About 80% had either or both treatments. Men ages 20 to 49 years were more likely to undergo surgery, while older men (ages>70 years) were more likely to choose radiation.85 Data on the proportion of men who underwent other treatments were not reported.

A separate analysis of SEER data from 2004–2006 focused specifically on men (n=123,934) with low PSA values (≤10 ng/mL) at the time of prostate cancer diagnosis.7 Among men with PSA values of 0.0 to 4.0 ng/mL (n=17,343), most chose prostatectomy (44%) or radiation (33%; either EBRT [17%], brachytherapy [12%], or a combination of both [4%]) as primary therapy. Conservative management—described as receiving neither prostatectomy nor radiation, and presumably referring to some type of watchful waiting or active surveillance—was chosen by 23% of men. Rates were similar among men with PSA values of up to 10.0 ng/mL (n=71,352). Men with screen-detected cancer were significantly more likely to undergo prostatectomy (odds ratio [OR], 1.49 [95% CI, 1.38 to 1.62]) or radiation therapy (OR, 1.39 [95% CI, 1.30 to 1.49]) compared with men without screen-detected cancer.

CaPSURE stratifies treatment groups by age, race, baseline risk (low, intermediate, or high), geographic location, and several other variables.86 Baseline PSA level and method of prostate cancer detection are not specifically reported in CaPSURE, although methods for risk stratification are based on the D’Amico classification and the Cancer of the Prostate Risk Assessment (CAPRA) score, both of which incorporate PSA levels. Of 4,314 men classified as low risk, most (57%) chose radical prostatectomy as a primary therapy. Sixteen percent of men chose brachytherapy as a primary treatment, while less than 10% of men elected each of the other treatments (9% watchful waiting/active surveillance, 7% EBRT, 7% ADT, and 3% cryotherapy). Although prostatectomy was the most popular choice of primary treatment among low-risk patients overall, geographic and age variations in treatment choices were observed. For example, 75% of patients at one site (average CAPRA score, 2.4 [indicating low risk]) chose prostatectomy as primary therapy. At another site where patients had a similar risk score (average CAPRA score, 2.5), only 16% chose prostatectomy as primary therapy, with most patients choosing brachytherapy as primary treatment. Regarding age, 74% of men ages 65 years or younger chose prostatectomy. By age 75 years or older, that proportion dropped to 3%; instead, the higher proportion (42%) of men older than age 75 years opted for primary ADT.