# Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,27 the USPSTF and Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework with the key questions and the patient populations, interventions, and outcomes reviewed (Figure 1). The target population for this review was men treated for screen-detected prostate cancer. Since most studies do not describe whether prostate cancer was identified through screening or some other method, we also included studies of localized (T1 or T2) prostate cancer, as most screen-detected prostate cancer is localized. A contextual question was also requested by the USPSTF to help inform the report. (Contextual questions are not reviewed using systematic review methodology.)

Figure 1 Analytic Framework and Key Questions

Key Questions*

1. What are the benefits of treatment of early-stage or screen-detected prostate cancer?
2. What are the harms of treatment of early-stage or screen-detected prostate cancer?

Contextual Question

1. How often is each treatment currently performed in U.S. men with PSA-detected cancer (i.e., what percentage of men initially choose watchful waiting versus surgery, radiation therapy, cryotherapy, etc.)?

*This targeted update focuses on the benefits and harms of treatments. The included treatments are listed in the analytic framework. The harms include overall and disease-specific mortality, reduced quality of life or function, and increased risk of urinary incontinence, bowel dysfunction, erectile dysfunction, surgical complications, and psychological or endocrinological effects.

Figure 1 is an analytic framework for the key questions of this report that depicts the events that men could experience as a result of undergoing screening for prostate cancer, with the ultimate goal of reducing mortality and morbidity related to prostate cancer. The figure illustrates how screening can result in early detection of prostate cancer, and detection can lead to various treatments. Treatments include surgery (prostatectomy), radiation therapy, hormonal therapy, cryotherapy, ultrasound therapy, active surveillance, or watchful waiting. The figure also depicts the possibility of harms or adverse events occurring as a result of treatment for screen-detected prostate cancer.

### Key Questions

1. What are the benefits of treatment of early-stage or screen-detected prostate cancer?
2. What are the harms of treatment of early-stage or screen-detected prostate cancer?

### Contextual Question

1. How often is each treatment currently performed in U.S. men with PSA-detected cancer (i.e., what percentage of men initially choose watchful waiting versus surgery, radiation therapy, cryotherapy, etc.)?

## Search Strategy

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through the second quarter of 2011), and Ovid MEDLINE (2002 to July 2011) for relevant studies and systematic reviews. Search strategies and additional details are described in Appendix B1. We also reviewed reference lists of relevant articles.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We restricted inclusion to published studies. We selected studies on the basis of inclusion and exclusion criteria developed for each key question (Appendix B2). Appendix B3 shows the results of our literature search and selection process.

We excluded studies that did not adequately report baseline tumor stage or that enrolled more than 10% of patients with stage T3 tumors or higher unless results related to harms were stratified according to tumor stage at baseline. We also excluded studies that evaluated patients with recurrent or refractory prostate cancer. Studies that described the population as having localized prostate cancer were included even if they did not report specific tumor stage information, as this term typically refers to T1 and T2 cancer.28 Appendix B4 lists studies that were excluded after full-text review.

We included randomized, controlled trials (RCTs) and cohort studies that reported all-cause mortality, prostate cancer-specific mortality, or prespecified harms and compared radical prostatectomy, radiation therapy (EBRT or brachytherapy), ADT, cryoablation, or HIFU with watchful waiting or active surveillance. For assessment of all-cause and prostate cancer-specific mortality, we only included studies that reported risk estimates adjusted at a minimum for age at diagnosis and tumor grade (no study reported adjusted risk estimates for treatment harms). We also included large (n>1,000) uncontrolled observational studies of harms if RCTs and cohort studies were not available. If no RCTs, cohort studies, or large uncontrolled studies of harms were available for a specific intervention, we included smaller uncontrolled studies. We excluded head-to-head studies of active treatments unless there was also a watchful waiting or active surveillance group. Prespecified harms were mortality related to treatment (i.e., not mortality related to prostate cancer itself) and included quality of life and functional status, urinary incontinence, bowel dysfunction, erectile dysfunction, harms related to endocrinological effects, psychological effects, and surgical complications.

We classified “no treatment,” “observation,” or “deferred treatment” as watchful waiting, since patients probably received at least watchful waiting. We also grouped watchful waiting with active surveillance unless studies of active surveillance provided sufficient information to determine that more active followup actually occurred,29 as older studies used these terms interchangeably.

## Data Abstraction and Quality Rating

One investigator abstracted details about the patient population, study design, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. Two investigators independently applied criteria developed by the USPSTF27 to rate the quality of each study as good, fair, or poor (Appendix B5). Discrepancies were resolved through a consensus process.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each key question (“good,” “fair,” or “poor”) using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence.27 For all outcomes, we synthesized results descriptively, using medians and ranges, since few RCTs were available and studies varied in the populations and interventions evaluated, methodological quality, duration of followup, and other factors. We stratified results according to study type, and qualitatively assessed effects of study quality, duration of followup, year of publication, and mean age on results.

We also conducted meta-analyses on urinary incontinence and erectile dysfunction, the most commonly reported harms, using studies that reported dichotomous measures. We pooled results separately for prostatectomy and radiation therapy versus watchful waiting. There were too few studies to pool trials of ADT (two studies) or cryotherapy (one study), and no studies of HIFU versus watchful waiting. Data were pooled using the DerSimonian-Laird random effects model with Stata Version 11.1 software (StataCorp, College Station, TX). We calculated pooled relative risks as well as pooled risk differences. Statistical heterogeneity was assessed using the I^2^ statistic.30 Because few RCTs were available for any of the analyses, we pooled both RCTs and cohort studies. As none of the cohort studies reported adjusted risk estimates, we used raw event rates. We stratified analyses by study type in order to assess effects of including cohort studies. If four or more studies were available for pooling, we performed additional analyses based on study quality, duration of followup, and age to evaluate effects on results. For one study that reported results separately for patients followed for varying durations, we combined the data into a single estimate, since an analysis showed no effect related to followup duration.31 For one study that reported results from the same cohort at 30 to 41 months’ followup32 and 10 years’ followup,33 we used the earlier data, since it was more complete (n=108 vs. n=54) and pooled estimates using either results were similar in sensitivity analyses.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners (Appendix B6), and then revised for the final version.