# Evidence Tables and Quality Tables

Appendix C1 Randomized, Controlled Trials and Cohort Studies of Treatment Benefits

Author, Year Title | Study name | Inclusion criteria | Exclusion criteria | Number screened/eligible/enrolled | Subject age and race Stage at diagnosis Screen detected | Country and setting or data source | Sponsor | Variables adjusted for in analysis | Subgroup analyses | Intervention type | Outcomes method of ascertainment | Results | Mean duration and loss to followup | Quality rating
Randomized, Controlled Trials
Bill-Axelson et al, 2011^35^ Other publications: Bill-Axelson et al, 2008^34^ Holmberg et al, 2006^39^ Bill-Axelson et al, 2005^36^ Steineck et al, 2002^50^ Holmberg et al, 2002^40^ | Scandinavian Prostate Cancer Center Group Study 4 (SPCG-4) | Include: ages <75 yrs with newly diagnosed moderately or well- differentiated T0d, T1, or T2 tumors; PSA <50 ng/mL; negative bone scan; free of other cancer; healthy enough to allow prostatectomy; life expectancy >10 yrs | Poorly differentiated tumor | NR/NR/695 | Mean age: 65 yrs Race: NR Mean PSA: 12.9 ng/mL T1b: 12% (83/695) T1c: 12% (81/695) T2: 76% (529/695) Unknown: <1% (2/695) Screen detected: no | Sweden, Finland, Iceland 14 cancer centers | National Institutes of Health; Swedish Cancer Society | Not applicable (RCT) | [underlined: Risk] Low risk (PSA <10 ng/mL and Gleason score <7 or WHO grade 1) [underlined: Age] <65 yrs ≥65 yrs | Radical prostatectomy (n=347) Watchful waiting (n=348) | All-cause mortality Prostate cancer mortality Distant metastases | [underlined: All-cause mortality, radical prostatectomy vs. watchful waiting] All patients: cumulative incidence, 46.1% (CI, 40.8 to 52.0) vs. 52.7% (CI, 47.4 to 58.6); HR, 0.75 (CI, 0.61 to 0.92); ARR, 6.6 (CI, −1.3 to 14.5) Low risk: cumulative incidence, 31.4% (CI, 23.9 to 41.3) vs. 44.6% (CI, 36.6 to 54.4); HR, 0.62 (CI, 0.42 to 0.92); ARR, 13.2 (CI, 0.9 to 25.5) Age <65 yrs: cumulative incidence, 33.9% (CI, 26.9 to 42.6) vs. 47.4% (CI, 40.4 to 56.1); HR, 0.52 (CI, 0.37 to 0.73); ARR, 13.5 (CI, 2.4 to 24.7) Age <65 yrs and low risk: cumulative incidence, 16.9% (CI, 9.5 to 30.1) vs. 36.2% (CI, 26.1 to 50.2); HR, 0.36 (CI, 0.18 to 0.70); ARR, 19.3 (CI, 4.0 to 34.7) Age ≥65 yrs: cumulative incidence, 56.7% (CI, 49.5 to 65.0) vs. 57.4% (CI, 50.2 to 65.8); HR, 0.98 (CI, 0.75 to 1.28); ARR, 0.7 (CI, −10.3 to 11.7) Age ≥65 yrs and low risk: cumulative incidence, 46.8% (CI, 35.1 to 62.3) vs. 52.9% (CI, 41.3 to 67.6); HR, 0.92 (CI, 0.57 to 1.49); ARR, 6.1 (CI, −12.6 to 24.8) [underlined: Prostate cancer mortality, radical prostatectomy vs. watchful waiting] All patients: cumulative incidence, 14.6% (CI, 11.2 to 19.1) vs. 20.7% (CI, 16.7 to 25.6); HR, 0.62 (CI, 0.44 to 0.87); ARR, 6.1 (CI, 0.2 to 12.0) Low risk: cumulative incidence, 6.8% (CI, 3.5 to 13.5) vs. 11.0 (CI, 6.8 to 17.8); HR, 0.53 (CI, 0.24 to 1.14); ARR, 4.2 (CI, −2.9 to 11.2) Age <65 yrs and low risk: cumulative incidence, 7.1% (CI, 2.7 to 18.6) vs. 11.6 (CI, 6.0 to 22.6); HR, 0.41 (CI, 0.14 to 1.17); ARR, 4.5 (CI, −5.7 to 14.8) Age <65 yrs: Cumulative incidence, 16.4% (CI, 11.3 to 23.8) vs. 25.8% (CI, 19.7 to 33.7); HR, 0.49 (CI, 0.31 to 0.79); ARR, 4.5 (CI, −5.7 to 14.8) Age ≥65 yrs: cumulative incidence, 13.0% (CI, 8.9 to 18.9) vs. 16.0% (CI, 11.4 to 22.6); HR, 0.83 (CI, 0.50 to 1.30); ARR, 3.8 (CI, −5.9 to 13.4) Age ≥65 yrs and low risk: cumulative incidence, 6.6% (CI, 2.5 to 17.1) vs. 10.3% (CI, 5.1 to 21.0); HR, 0.76 (CI, 0.35 to 2.32); ARR, 3.8 (CI, −5.9 to 13.4) [underlined: Distant metastases, radical prostatectomy vs. watchful waiting] All patients: cumulative incidence, 21.7% (CI, 17.6 to 26.7) vs. 33.4 (CI, 28.6 to 39.0); HR, 0.59 (CI, 0.45 to 0.79); ARR, 11.7 (CI, 4.8 to 18.6) Low risk: cumulative incidence, 9.9% (CI, 5.8 to 17.1) vs. 21.4% (CI, 15.4 to 29.6); HR, 0.43 (CI, 0.23 to 0.79); ARR, 11.4 (CI, 2.6 to 20.2) Age <65 yrs: cumulative incidence, 21.5% (CI, 15.9 to 29.2) vs. 39.8% (CI, 32.6 to 48.5); HR, 0.47 (CI, 0.32 to 0.70); ARR, 18.3 (CI, 8.0 to 28.5) Age <65 yrs and low risk: cumulative incidence, 9.5% (CI, 4.4 to 20.4) vs. 20.6% (CI, 12.8 to 33.0); HR, 0.41 (CI, 0.18 to 0.95); ARR, 11.1 (CI, −1.0 to 23.2) Age >65 yrs: cumulative incidence, 22.1% (CI, 16.6 to 29.4) vs. 27.5% (CI, 21.5 to 35.1); HR, 0.77 (CI, 0.51 to 1.15); ARR, 5.4 (CI, −3.9 to 14.6) Age >65 yrs and low risk: cumulative incidence, 10.5% (CI, 4.8 to 23.0) vs. 21.8% (CI, 13.9 to 34.3); HR, 0.46 (CI, 0.19 to 1.11); ARR, 11.3 (CI, −1.6 to 24.1) | Duration: 12.8 yrs (range, 3 wks to 20.2 yrs) Loss to followup: none | Good
Iversen et al, 1995^41^ Other publications: Byar et al, 1981^37^ Graversen et al, 1990^38^ | Veterans Administration Cooperative Urological Research Group (VACURG) | Newly diagnosed and untreated stage I (no palpable tumor on digital rectal exam) or II (palpable tumor believed to be confined within prostatic capsule) prostate cancer with no metastases and normal prostatic acid phosphatase level | None reported | NR/NR/142 | Mean age: 64 yrs Race: NR Stage I: n=76 Stage II: n=66 Screen detected: no | United States 15 Veterans Health Administration hospitals | Veterans Health Administration | Not applicable (RCT) | None | Radical prostatectomy (n=74) Watchful waiting (n=68) | All-cause mortality Prostate cancer mortality Distant metastases | [underlined: All-cause mortality, radical prostatectomy vs. watchful waiting] Median duration of survival: 10.6 yrs vs. 8 yrs; p=NS | Duration: 23 yrs (range, 19–27) Loss to followup: 22% (31/142) | Poor
Observational Studies
Albertsen et al, 2007^42^ | Study not named | Age ≤75 yrs diagnosed with prostate cancer between January 1, 1990 and December 31, 1992 | Advanced prostate cancer or initial PSA of ≥50 ng/mL | 3739/1862/1618 | Median age: 68 yrs Race: NR 4% Gleason score 2–4 6% Gleason score 5 47% Gleason score 6 26% Gleason score 7 17% Gleason score 8–10 Screen detected: unclear | United States Connecticut Tumor Registry | AHRQ; Catherine Weldon Donaghue Foundation Grant; Veterans Affairs Health Services Research and Development Service | Gleason score, PSA, clinical stage, age at diagnosis, Charlson comorbidity score | None | No initial therapy (n=114) Surgery (n=802) Radiation (n=702) | Prostate cancer mortality Connecticut Department of Public Health Records | [underlined: Prostate cancer mortality] Surgery vs. radiation: rate ratio, 2.2 (CI, 1.6 to 3.1) Surgery vs. observation: rate ratio, 3.4 (CI, 1.9 to 5.9) No initial therapy vs. radiation: rate ratio, 1.5 (CI, 0.9 to 2.6) Estimated 10-yr absolute rate of prostate cancer mortality: surgery, 4% vs. radiation, 9% vs. observation, 14% | Duration: varied according to treatment group; median, 13.1 to 13.6 yrs Loss to followup: none reported | Fair
Ladjevardi et al, 2009^43^ | Study not named | Age <75 yrs; stage T1- T3, NO/NX, MO/MX; PSA <20 ng/mL | None reported | 81,195/34,902/31,903 | Mean age: 65 yrs Race: NR <1% T0 49% T1 35% T2 15% T3 <1% TX Screen detected: 33%; others were symptomatic or detected for other reasons | Sweden National Prostate Cancer Registry | No sponsor | Age, Gleason score, PSA | [underlined: Risk] Gleason score 7 Gleason score 8–10 | Conservative management (watchful waiting [n=9435] and palliative treatment, including androgen deprivation [n=3210]) Radical prostatectomy (n=12,950) Radiotherapy (n=6308; EBRT n=4443; brachytherapy n=1865) | All-cause mortality Registered deaths | [underlined: All-cause mortality vs. conservative management (reference standard)] Radical prostectomy Gleason score 2–10: HR, 0.41 (CI, 0.36 to 0.48) Gleason score 7: HR, 0.78 (CI, 0.63 to 0.97) Gleason score 8–10: HR, 0.65 (CI, 0.47 to 0.90) Radiotherapy Gleason score 2–10: HR, 0.62 (CI, 0.54 to 0.71) Gleason score 7: HR, 0.81 (CI, 0.66 to 0.99) Gleason score 8–10: HR, 0.71 (CI, 0.55 to 0.92) | Duration: median, 4 yrs (range, 0–12) Loss to followup: none reported | Fair
Lu-Yao et al, 2008^44^ | Study not named | Age >66 yrs diagnosed with T1-T2 prostate cancer between 1992 and 2002 | Death within 180 days of diagnosis; use of radiation or prostatectomy within 180 days of diagnosis; no Medicare Part A or B coverage; missing data; unknown cancer grade; initiation of ADT before cancer diagnosis | 89,877/22,266/19,271 | Mean age; 78 yrs 11% black (other races NR) 58% T1 42% T2 Screen detected: unclear | United States SEER data | US Army Medical ResearchAcquisition Activity; Cancer Institute of New Jersey; US Department of Defense; Ohl Foundation; National Cancer Institute | Instrumental variable analysis (covariates in analysis included age, race, comorbidity status, cancer stage, cancer grade, income status, urban resident, marital status, and year of diagnosis) | [underlined: Risk] Moderately differentiated tumors Poorly differentiated tumors | Conservative management (no use of surgery, radiation, or androgen deprivation; n=11,404) Primary androgen deprivation therapy (PADT; n=7867) | Prostate cancer mortality All-cause mortality SEER data (confirmed in medical records for 87%–88% of cases) | [underlined: All-cause mortality] Conservative management, 6316/66,567 events per person-yr (rate, 9.5/100) vs. PADT, 4729/39,767 events per person-yr (rate, 11.9/100); HR, 1.17 (CI, 1.12 to 1.21) Moderately differentiated tumors: HR, 1.15 (CI, 1.10 to 1.21) Poorly differentiated tumors: HR, 1.04 (CI, 0.97 to 1.13) [underlined: Prostate cancer mortality] Conservative management, 693/55,424 events per person-yr (rate, 1.3/100) vs. PADT, 867/32,744 events per person-yr (rate 2.6/100); HR, 1.76 (CI, 1.59 to 1.95) Moderately differentiated tumors: HR, 1.83 (CI, 1.58 to 2.12) Poorly differentiated tumors: HR, 1.12 (CI, 0.96 to 1.29) | Duration: median, 7 yrs Loss to followup: none reported | Fair
Merglen et al, 2007^45^ | Study not named | Patients in Geneva Cancer Registry between 1989–1998 | Diagnosis of prostate cancer at time of death; previous; previous invasive cancer except non- melanoma skin cancer | 1,740/1,495 844 | Mean age 71 years (range 44–97 years) Race not reported 29% Stage 1 40% Stage 2 31% Stage 3 PSA <10 22% PSA 11–29 28% PSA >30 23% PSA unknown 27% Screen detected: unclear | Switzerland Geneva Cancer Registry data | Swiss National Science Foundation | Age, period of diagnosis, method of detection, lymph node status, clinical tumor stage, differentiation, and PSA level | [underlined: Risk] Gleason score <7 Gleason score ≥7 [underlined: Age] <70 yrs ≥70 yrs | Watchful waiting (n=378) Prostatectomy (n=158) Any EBRT (n=205; EBRT alone [n=152] or EBRT + ADT [n=53]) ADT (n=72) Other treatment (n=31; not described) | Prostate cancer mortality All-cause mortality Registry data | [underlined: Prostate cancer mortality, 5 yrs] Prostatectomy (reference standard): 8/158 (5%) vs.: All EBRT: 13/205 (6%); HR, 1.3 (CI, 0.6 to 3.5) EBRT alone: 10/152 (7%); HR, 1.3 (CI, 0.5 to 3.4) EBRT + ADT: 3/53 (6%); HR, 1.5 (CI, 0.4 to 6.1) Watchful waiting: 43/378 (11%); HR, 1.8 (CI, 0.8 to 4.1) ADT: 18/72 (25%); HR, 3.5 (CI, 1.6 to 9.6) Other treatment: 8/31 (26%); HR, 5.8 (CI, 2.2 to 15.3) [underlined: Prostate cancer mortality, 10 yrs (all ages)] Prostatectomy (reference standard): 15/158 (9%) vs.: All EBRT: 36/205 (18%); HR, 2.3 (CI, 1.2 to 4.3) EBRT alone: 30/152 (20%); HR, 2.4 (CI, 1.2 to 4.6) EBRT + ADT: 6/53 (11%); HR, 1.9 (CI, 0.7 to 5.1) Watchful waiting: 70/378 (11%); HR, 2.0 (CI, 1.1 to 3.8) ADT: 28/72 (25%); HR, 4.4 (CI, 2.2 to 8.8) Other treatment: 8/31 (26%); HR, 3.1 (CI, 1.3 to 7.5) [underlined: Prostate cancer mortality, 10 yrs (ages <70 yrs)] Prostatectomy (reference standard): 5/118 (4%) vs.: All EBRT: 19/125 (15%); HR, 6.7 (CI, 2.2 to 20.7) EBRT alone: 15/89 (17%); HR, 6.9 (CI, 2.2 to 21.5) EBRT + ADT: 4/36 (11%); HR, 4.2 (CI, 1.0 to 10.3) Watchful waiting: 13/104 (13%); HR, 8.4 (CI, 2.4 to 28.5) ADT: 8/18 (44%); HR, 10.7 (CI, 3.2 to 36.2) Other treatment: 5/17 (29%); HR, 7.0 (CI, 1.9 to 25.9) [underlined: Prostate cancer mortality, 10 yrs (ages ≥70 yrs)] Prostatectomy (reference standard): 10/40 (25%) vs.: All EBRT: 17/80 (22%); HR, 1.0 (CI, 0.4 to 2.4) EBRT alone: 15/63 (24%); HR, 1.1 (CI, 0.5 to 2.6) EBRT + ADT: 2/17 (12%); HR, 1.4 (CI, 0.3 to 6.9) Watchful waiting: 57/274 (21%); HR, 0.8 (CI, 0.4 to 1.7) ADT: 20/54 (37%); HR, 1.7 (CI, 0.7 to 3.8) Other treatment: 3/14 (21%); HR, 1.8 (CI, 0.5 to 7.3) [underlined: Prostate cancer mortality, 10 yrs (Gleason score <7)] Prostatectomy (reference standard): 9/112 (8%) vs.: All EBRT: 17/143 (12%); HR, 1.7 (CI, 0.7 to 3.9) EBRT alone: 15/110 (14%); HR, 1.8 (CI, 0.7 to 4.2) EBRT + ADT: 2/33 (6%); HR, 1.2 (CI, 0.2 to 5.7) Watchful waiting: 31/225 (14%); HR, 2.0 (CI, 0.9 to 4.5) ADT: 12/31 (39%); HR, 3.9 (CI, 1.5 to 10.5) Other treatment: 2/13 (15%); HR, 1.0 (CI, 0.2 to 4.7) [underlined: Prostate cancer mortality, 10 yrs (Gleason score ≥7)] Prostatectomy (reference standard): 4/31 (13%) vs.: All EBRT: 10/32 (31%); HR, 7.1 (CI, 1.7 to 29.9) EBRT alone: 6/14 (43%); HR, 6.9 (CI, 1.5 to 32.9) EBRT + ADT: 4/18 (22%); HR, 7.3 (CI, 1.4 to 38.1) Watchful waiting: 28/76 (37%); HR, 4.3 (CI, 1.1 to 17.0) ADT: 13/25 (52%); HR, 10.6 (CI, 2.5 to 45.5) Other treatment: 6/14 (43%); HR, 26.7 (CI, 5.7 to 126.0) [underlined: All-cause mortality, 5 yrs] Prostatectomy (reference standard): 21/158 (13%) vs.: All EBRT: 26/205 (13%); HR, 0.7 (CI, 0.3 to 1.5) EBRT alone: 22/152 (14%); HR, 0.7 (CI, 0.3 to 1.6) EBRT + ADT: 4/53 (8%); HR, 0.4 (CI, 0.1 to 2.8) Watchful waiting: 147/378 (39%); HR, 1.4 (CI, 0.7 to 2.5) ADT: 36/72 (50%); HR, 1.4 (CI, 0.7 to 3.0) Other treatment: 11/31 (35%); HR, 1.5 (CI, 0.4 to 5.3) [underlined: All-cause mortality, 10 yrs] Prostatectomy (reference standard): 34/158 (22%) vs.: All EBRT: 71/205 (35%); HR, 1.1 (CI, 0.6 to 2.0) EBRT alone: 62/152 (41%); HR, 1.2 (CI, 0.7 to 2.2) EBRT + ADT: 9/53 (17%); HR, 0.7 (CI, 0.2 to 2.4) Watchful waiting: 223/378 (60%); HR, 1.5 (CI, 0.9 to 2.5) ADT: 54/72 (75%); HR, 1.6 (CI, 0.8 to 2.9) Other treatment: 11/31 (35%); HR, 0.9 (CI, 0.3 to 2.9) | Duration: mean, 7 yrs (range, 0–16) Loss to followup: 6% (47/844) | Fair
Schymura et al, 2010^46^ | CDC-NPCR Breast, Colon and Prostate Cancer Data Quality and Patterns of Care Study (PoC1) | Diagnosis in 1997 with first primary prostate cancer; clinically localized (clinically inapparent or T1c or T2); no evidence of metastasis; alive 6 months following diagnosis | None reported | 3504/3504/3328 (for mortality outcome, n=3297) | Mean age: NR 18% <60 yrs 17% 60–64 yrs 22% 65–69 yrs 21% 70–74 years 14% 75–79 yrs 8% ≥80 yrs 80% white 14% black 3% Hispanic 2% other 1% unknown 57% PSA <10 ng/mL 26% PSA 10–20 ng/mL 11% PSA >20 ng/mL 13% PSA unknown Screen detected: 63% (26% not screen detected, 11% unknown method of detection) | United States Database registries from California, Colorado, Illinois, Louisiana, New York, Rhode Island, and South Carolina | CDC; States of California, Colorado, Illinois, Louisiana, New York, Rhode Island, and South Carolina | Age at diagnosis, race/ethnicity, marital status, State, PSA value, Gleason score, comorbidity score, time since diagnosis | None | Watchful waiting (n=614) Radical prostatectomy (n=1310) Radiation therapy (EBRT or brachy- therapy; n=1037) ADT (n=339) | All-cause mortality Registry data | [underlined: All-cause mortality, 5 yrs] Radical prostatectomy (reference standard): 6% vs.: Watchful waiting: 25%; HR, 2.3 (CI, 1.7 to 3.12) Radiation: 14%; HR, 1.66 (CI, 1.24 to 2.21) Hormone therapy: 35%; HR, 2.83 (CI, 2.06 to 3.9) | Duration: 5 yrs Loss to followup: 3/3328 (0.9%) | Fair
Stattin et al, 2010^10^ | National Prostate Cancer Register (NPCR) of Sweden Follow- up Study | Age ≤70 yrs; registration in NPCR between January 1, 1997 and December 31, 2002; stage T1-T2; no lymph node involvement or metastases; PSA <20 ng/mL | Primary hormone treatment; poorly differentiated tumors | 8304/7960/6849 | Mean age: 63 yrs Race: NR 59% T1 41% T2 Mean PSA: 8.2 ng/mL Screen detected: unclear | Sweden National Prostate Cancer Registry | Swedish Research Council; Swedish Cancer Foundation; Vasterbotten County Council | Prostate cancer risk category, Charlson comorbidity index, socioeconomic status | [underlined: Risk] Low risk (T1a, b, or c; Gleason score 2–6 or WHO grade I or II; and PSA <10 ng/mL) Intermediate risk (Gleason score 7, stage T2, or PSA ≥10 ng/mL) | Surveillance (n=2021) Radical prostatectomy (n=3399) Radiation (n=1429) | Prostate cancer mortality All-cause mortality | [underlined: Prostate cancer mortality] Surveillance (reference standard): 3.6% (CI, 2.7 to 4.8) vs.: Radical prostatectomy: 2.4% (CI, 1.8 to 3.3); HR, 0.49 (CI, 0.34 to 0.71) Radiation: 3.3% (CI, 2.5 to 5.7); HR, 0.70 (CI, 0.45 to 1.09) [underlined: Prostate cancer mortality, low-risk patients] Surveillance (reference standard): 2.4% (CI, 1.2 to 4.1) vs.: Radical prostatectomy: 0.4% (CI, 0.13 to 0.97); HR, 0.29 (CI, 0.09 to 0.87) Radiotherapy: 1.8% (CI, 0.65 to 4.0); HR, 0.94 (CI, 0.31 to 2.85) [underlined: Prostate cancer mortality, intermediate-risk patients] Surveillance (reference standard): 5.2% (CI, 3.7 to 6.9) vs.: Radical prostatectomy: 3.4% (CI, 2.5 to 4.7); HR, 0.53 (CI, 0.35 to 0.80) Radiation: 3.8% (CI, 2.6 to 5.4); HR, 0.66 (CI, 0.42 to 1.06) [underlined: All-cause mortality] Surveillance (reference standard): 23.4% (CI, 21.3 to 25.8) vs.: Radical prostatectomy: 11.3% (CI, 10.0 to 12.9); HR, 0.49 (CI, 0.41 to 0.57) Radiation: 18.3% (CI, 15.7 to 21.3); HR, 0.68 (CI, 0.57 to 0.82) | Duration: median, 8.2 yrs Loss to followup: none reported | Fair
Tewari et al, 2007^47^ | Study not named | Registered in the Henry Ford Health System with ICD code 185 (diagnosis of prostate cancer) between January 1, 1980 and December 31, 1997 with tumor grade and Gleason score; localized, grade 3 or Gleason score 8–10 | Age >75 yrs; grade 1 or 2 or Gleason score <8; in- complete followup; bone metastases within 1 year of diagnosis | 4387/3371/453 | Mean age: 63 yrs 100% stage 3 28% adjuvant hormone therapy (40% watchful waiting; 26% radiotherapy; 22% prostatectomy patients) Screen detected: unclear | United States Henry Ford Health System data | Not reported | Propensity analysis (propensity score based on age at diagnosis, race, socioecononomic status, Charlson comorbidity index, and year of diagnosis) | None | Conservative management (n=197) Radiotherapy (n=137) Radical prostatectomy (n=119) | Prostate cancer mortality All-cause mortality Registry data | [underlined: Prostate cancer mortality] Conservative management (reference standard): 85/197 (43%) vs.: Radical prostatectomy: 18/119 (15%); HR, 0.32 (CI, 0.17 to 1.22; p=0.16) Radiotherapy: 23/137 (17%); HR, 0.63 (CI, 0.38 to 1.06; p=0.81) Radical prostatectomy vs. radiotherapy: HR, 0.51 (CI, 0.26 to 1.01; p=0.05) [underlined: All-cause mortality] Conservative management (reference standard): 139/197 (71%) vs.: Radical prostatectomy: 27/119 (23%); HR, 0.32 (CI, 0.20 to 0.51; p=0.001) Radiotherapy: 58/137 (42%); HR, 0.70 (CI, 0.50 to 0.99; p=0.04) Radical prostatectomy vs. radiotherapy: HR, 0.46 (CI, 0.28 to 0.75; p=0.002) | Duration: varied by group - median 4 years conservative management, 6 years radical prostatectomy, 5 years radiotherapy Loss to follow-up: none reported | Fair
Wong et al, 2006^48^ | Study not named | Age 65–80 yrs; prostate cancer diagnosis between 1991 and 1999; well or moderately differentiated T1 or T2 tumors | Diagnosis of prostate cancer at autopsy or time of death; end-stage renal disease (per Medicare); initial enrollment in managed care 3 mo prior to 6 mo after diagnosis; T3, T4, poorly differentiated, or anaplastic tumors; metastatic disease; unknown tumor size or grade; disability; age >80 yrs; use of hormone therapy; history of cancer; missing data; death within 1 year of diagnosis | 111,640/44,603/44,630 | Mean age: 72 yrs (73 yrs in observation group; 71 yrs in active treatment group; p≤0.01) 80% white 10% black 10% other 55% stage ≤T2a 45% stage T2b-T2c Screen detected: unclear | United States SEER/Medicare data | NIH; Center for Population Health and Health Disparities (University of Pennsylvania) | Propensity-adjusted (propensity score based on age at diagnosis, SEER site, year of diagnosis, tumor size, tumor grade, marital status, residence in urban setting, race, income, educational achievement, and comorbidities) | [underlined: Age] 65–67 yrs 68–70 yrs 71–73 yrs 74–77 yrs 78–80 yrs | Observation (n=12,608) Active treament (n=32,022; includes radical prostatectomy [n=13,292] and EBRT or brachytherapy [n=18,249], alone or in combination) | Prostate cancer mortality All-cause mortality Registry data | [underlined: Prostate cancer mortality] Active treatment, 612/32,022 (2%) vs. observation, 314/12,608 (3%); HR, 0.67 (CI, 0.58 to 0.77; adjusted for propensity score only) [underlined: All-cause mortality] Active treatment, 7639/32,022 (24%) vs. observation, 4663/12,608 (37%); HR, 0.69 (CI, 0.66 to 0.72) Radical prostatectomy vs. observation: HR, 0.50 (CI, 0.47 to 0.53) Radiation vs. observation: HR, 0.81 (CI, 0.78 to 0.85) [underlined: All-cause mortality, active treament vs. observation, stratified by age] Age 65–67: HR, 0.67 Age 68–70: HR, 0.61 Age 71–73: HR, 0.70 Age 74–77: HR, 0.71 Age 78–80: HR, 0.74 [underlined: Median survival] Observation, 47 months vs. active treatment, 55 months; p<0.001 | Duration: 12 yrs Loss to followup: none reported | Fair
Zhou et al, 2008^49^ | Study not named | Age ≥65 yrs residing in Ohio; prostate cancer diagnosis between January 1, 1999 and December 31, 2001; continuous Medicare coverage for at least 6 months prior to diagnosis | Initial enrollment in Medicare-managed care program 6 mo prior or 1 mo after prostate cancer diagnosis; diagnosis at time of death | 10,632/10,179/10,179 (8255 local-regional prostate cancer) | Mean age: NR; for total cohort (including 1924 patients with distant or unknown stage): 21% 65–69 yrs 32% 70–74 yrs 46% ≥75 yrs 9% black 91% other (primarily white) 66% Gleason score <7 Screen detected: unclear | United States Ohio Cancer Incidence Surveillance System/Medicare data | National Cancer Institute; National Institutes of Health Cancer-Aging Research Development Grant | Age, race, tumor stage, Gleason score, pretreatment comorbidity | None | No treatment (no definitive therapy within 6 mo of diagnosis, n=1716) [underlined: Monotherapy] Radical prostatectomy (n=889) EBRT (n=783) Brachytherapy (n=595) ADT (n=2049) [underlined: Combination therapy] Radical prostatectomy + EBRT, ADT, or both (n=181) EBRT + ADT (n=1286) Brachytherapy + EBRT or ADT (n=756) | Prostate cancer mortality All-cause mortality Registry data | [underlined: Prostate cancer mortality vs. no treatment (localized disease only)] Monotherapy Radical prostatectomy: HR, 0.25 (CI, 0.13 to 0.48; p<0.0001) EBRT: HR, 0.66 (CI, 0.41 to 1.04; p=0.07) Brachytherapy: HR, 0.45 (CI, 0.23 to 0.87; p=0.02) ADT: HR, 1.32 (CI, 1.01 to 1.73; p=0.05) [underlined: All-cause mortality vs. no treatment (localized disease only)] Monotherapy Radical prostatectomy: HR, 0.32 (CI, 0.24 to 0.41; p<0.0001) EBRT: HR, 0.63 (CI, 0.53 to 0.75; p<0.0001) Brachytherapy: HR, 0.40 (CI, 0.32 to 0.52; p<0.0001) ADT: HR, 0.89 (CI, 0.80 to 0.98; p=0.02) | Duration: 7 yrs Loss to followup: none reported | Fair

Abbreviations: ADT = androgen deprivation therapy; ARR = adjusted relative risk; CI = confidence interval; EBRT = external beam radiation therapy; HR = hazard ratio; NR = not reported; NS = not signficant; PSA = prostate-specific antigen; RCT = randomized, controlled trial; SEER = Surveillance, Epidemiology, and End Results; WHO = World Health Organization.

Appendix C2 Harms of Radical Prostatectomy, Radiation, Androgen Deprivation Therapy, and Cryotherapy Versus Watchful Waiting

Author, year Followup | General QOL scores | Disease-specific QOL scores | Urinary incontinence | Erectile dysfunction | Other outcomes
Radical prostatectomy vs. watchful waiting
Randomized, controlled trials
Johansson et al, 2009^*,31^ and Steineck et al, 2002^*,50^ 8 years | NR | NR | [underlined: 2–3 yr followup] Weak urinary stream: 12/51 (24%) vs. 19/52 (37%); RR, 0.6 (CI, 0.4 to 1.2) Urinary incontinence: 22/52 (42%) vs. 6/53 (11%); RR, 3.7 (CI, 1.6 to 8.5) [underlined: 4–5 yr followup] Weak urinary stream: 17/55 (31%) vs. 23/52 (44%); RR, 0.7 (CI, 0.4 to 1.2) Urinary incontinence: 26/55 (47%) vs. 15/54 (28%); RR, 1.7 (CI, 1.0 to 2.8) [underlined: 6–8 yr followup] Weak urinary stream: 16/56 (29%) vs. 26/49 (53%); RR, 0.5 (CI, 0.3 to 0.9) Urinary incontinence: 31/55 (56%) vs. 12/48 (25%); RR, 2.3 (CI, 1.3 to 3.9) [underlined: Other outcomes (4 yr followup)] Moderate or severe symptoms: 55/159 (35%) vs. 74/150 (49%); RR, 0.7 (CI, 0.5 to 0.9) Leakage, once a week or more: 80/164 (49%) vs. 33/155 (21%); RR, 2.3 (CI, 1.6 to 3.2) Regular dependence on protective aids: 71/165 (43%) vs. 16/154 (10%); RR, 4.1 (CI, 2.5 to 6.8) Regular dependence on diaper or urine bag: 23/165 (14%) vs. 1/154 (1%); RR, 21.5 (CI, 2.9 to 157.0) Urinary problems moderately or severely affecting sex life: 15/159 (9%) vs. 5/158 (3%); RR, 3.0 (CI, 1.1 to 8.0) | [underlined: 2–3 yr followup] Erectile dysfunction: 41/51 (80%) vs. 19/51 (37%); RR, 2.2 (CI, 1.5 to 3.2) [underlined: 4–5 yr followup] Erectile dysfunction: 42/54 (78%) vs. 23/54 (43%); RR, 1.8 (CI, 1.3 to 2.6) [underlined: 6–8 yr followup] Erectile dysfunction: 45/54 (83%) vs. 29/53 (55%); RR, 1.5 (CI, 1.2 to 2.0) [underlined: Other outcomes (4 yr followup)] Voluntary penile stiffness seldom or never sufficient: 135/158 (85%) vs. 79/158 (50%); RR, 1.7 (CI, 1.4 to 2.0) Penile stiffness at awakening seldom or never sufficient: 131/158 (83%) vs. 93/157 (59%); RR, 1.4 (CI, 1.2 to 1.6) Spontaneous penile stiffness seldom or never sufficient: 141/157 (90%) vs. 93/152 (61%); RR, 1.5 (CI, 1.3 to 1.7) Erectile function seldom or never sufficient: 129/161 (80%) vs. 71/158 (45%); RR, 1.8 (CI, 1.5 to 2.2) Great distress from erectile dysfunction: 45/160 (28%) vs. 25/153 (16%); RR, 1.7 (CI, 1.1 to 2.7) Insufficient maintenance of erection: 24/44 (55%) vs. 29/98 (30%); RR, 1.8 (CI, 1.2 to 2.8) Intercourse less than once a month: 130/162 (80%) vs. 91/154 (59%); RR, 1.4 (CI, 1.2 to 1.6) No orgasm in past 6 months: 101/162 (62%) vs. 48/153 (31%); RR, 2.0 (CI, 1.5 to 2.6) | [underlined: 2–3 yr followup] Fecal leakage: 1/52 (2%) vs. 3/53 (6%); RR, 0.3 (CI, 0.04 to 3.2) Moderate or high anxiety: 8/51 (16%) vs. 17/52 (33%); RR, 0.5 (CI, 0.2 to 1.0) Moderate or high level of depression: 13/51 (26%) vs. 23/52 (44%); RR, 0.6 (CI, 0.3 to 1.0) Low or moderate self-assessed QOL: 18/51 (35%) vs. 19/52 (36%); RR, 1.0 (CI, 0.6 to 1.6) [underlined: 4–5 yr followup] Fecal leakage: 0/53 (0%) vs. 4/53 (8%); RR, not calculable Moderate or high anxiety: 15/54 (28%) vs. 12/53 (23%); RR, 1.2 (CI, 0.6 to 2.4) Moderate or high level of depression: 26/54 (48%) vs. 16/53 (30%); RR, 1.6 (CI, 1.0 to 2.6) Low or moderate self-assessed QOL: 24/54 (44%) vs. 22/51 (43%); RR, 1.0 (CI, 0.7 to 1.6) [underlined: 6–8 yr followup] Fecal leakage: 0/57 (0%) vs. 2/51 (3.9%); RR, not calculable Moderate or high anxiety: 13/57 (23%) vs. 19/52 (36%); RR, 0.6 (CI, 0.3 to 1.1) Moderate or high level of depression: 18/57 (32%) vs. 21/52 (40%); RR, 0.8 (CI, 0.5 to 1.3) Low or moderate self-assessed QOL: 22/54 (42%) vs. 27/48 (56%); RR, 0.8 (CI, 0.5 to 1.1) [underlined: Other outcomes (4 yr followup)] Decreased physical capacity: 89/164 (54%) vs. 89/157 (57%); RR, 1.0 (CI, 0.8 to 1.2) Low or moderate physical well-being: 68/164 (41%) vs. 78/157 (50%); RR, 0.8 (CI, 0.7 to 1.1) Distress from bowel symptoms: 5/159 (3%) vs. 10/156 (6%); RR, 0.49 (CI, 0.17 to 1.40) High level of anxiety (score >90th percentile on State-Trait Anxiety Inventory): 15/159 (9%) vs. 16/157 (10%); RR, 0.9 (CI, 0.5 to 1.8) High level of depression (score >90th percentile, Center for Epidemiological Studies Measure of Depression): 10/153 (7%) vs. 16/151 (11%); RR, 0.6 (CI, 0.3 to 1.3) Low or moderate psychological well-being: 57/164 (35%) vs. 57/158 (36%); RR, 1.0 (CI, 0.7 to 1.3) Low or moderate subjective QOL: 64/159 (40%) vs. 68/151 (45%); RR, 0.9 (CI, 0.7 to 1.2)
Cohort studies
Bacon et al, 2001^51^ Up to 5 years | [underlined: SF-36 mean scores] PCS: 52 vs. 49 MCS: 55 vs. 55 Physical function: 90 vs. 79 Physical role function: 86 vs. 85 Bodily pain: 85 vs. 81 General health: 80 vs. 71 Vitality: 71 vs. 68 Social function: 92 vs. 87 Emotional role function: 90 vs. 90 Mental health: 84 vs. 83 [underlined: CARES-SF mean scores]^†^ Physical: 0.20 vs. 0.16 Sexual problems: 1.04 vs. 0.70 Global summary: 0.26 vs. 0.19 | [underlined: UCLA PCI mean scores] Urinary function: 76 vs. 93 Urinary bother: 82 vs. 89 Sexual function: 26 vs. 54 Sexual bother: 43 vs. 74 Bowel function: 86 vs. 91 Bowel bother: 86 vs. 89 | NR | NR | NR
Galbraith et al, 2001^54^ 1.5 years | [underlined: SF-36 mean scores] Physical function: 81 vs. 75 Physical role function: 55 vs. 65 Bodily pain: 85 vs. 84 General health: 58 vs. 54 Vitality: 62 vs. 64 Emotional role function: 80 vs. 70 Mental health: 77 vs. 79 [underlined: Quality of Life Index mean scores] Overall QOL: 57 vs. 59 | [underlined: PTSS mean scores] Sexual symptoms: 4.0 vs. 3.6 Urinary symptoms: 1.7 vs. 2.0 Gastrointestinal symptoms: 1.3 vs. 1.3 | NR | NR | NR
Hoffman et al, 2003^55^ 2 years | NR | NR | Urinary leakage, daily or more often: 35% (484/1373) vs. 8% (19/230) | Erectile dysfunction, no erections at all: 55% (757/1373) vs. 26% (60/230) | Cancer treatment limits activities some or a lot: 14% (196/1373) vs. 4% (10/230) Bowel urgency, almost every day: 0.8% (11/1373) vs. 0.4% (1/230)
Litwin et al, 1995a56 5.6 years | [underlined: SF-36 mean scores] Physical function: 75 vs. 71 Physical role function: 61 vs. 55 Bodily pain: 77 vs. 74 General health: 65 vs. 63 Vitality: 60 vs. 60 Social function: 80 vs. 80 Emotional role function: 70 vs. 57 Mental health: 76 vs. 77 [underlined: CARES-SF mean scores]^†^ Physical: 0.64 vs. 0.79 Psychosocial: 0.71 vs. 0.73 Marital: 0.56 vs. 0.70 Sexual: 1.32 vs. 1.12 | [underlined: UCLA-PCI] Urinary function: 65 vs. 86 Urinary bother: 68 vs. 80 Sexual function: 19 vs. 41 Sexual bother: 13 vs. 37 Bowel function: 82 vs. 84 Bowel bother: 80 vs. 85 | NR | NR | NR
Litwin et al, 1995b57 5.6 years | NR | NR | [underlined: Urinary control] Total control: 33/94 (35%) vs. 39/63 (62%) Occasional dribbling: 42/94 (45%) vs. 18/63 (29%) Frequent dribbling: 10/94 (11%) vs. 4/63 (6%) No control: 9/94 (10%) vs. 2/63 (3%) | [underlined: Sexual function] Very good: 5/96 (5%) vs. 4/63 (6%) Good: 6/96 (6%) vs. 9/63 (14%) Fair: 9/96 (9%) vs. 19/63 (30%) Poor: 12/96 (12%) vs. 7/63 (11%) Very poor: 64/96 (67%) vs. 24/63 (38%) | [underlined: Rectal urgency] Rarely or never: 62/97 (64%) vs. 43/63 (68%) About once/week: 15/97 (15%) vs. 6/63 (10%) More than once/week: 7/97 (7%) vs. 3/63 (5%) About once/day: 9/97 (9%) vs. 8/63 (13%) More than once/day: 4/97 (4%) vs. 3/63 (5%)
Litwin et al, 2002^58^ 2 years | [underlined: SF-36 mean scores] Vitality: 73 vs. 66 Social function: 100 vs. 89 Emotional role function: 94 vs. 86 Mental health: 85 vs. 81 | NR | NR | NR | NR
Lubeck et al, 1999^59^ 2 years | [underlined: SF-36 mean scores] Physical function: 86 vs. 71 Physical role function: 72 vs. 63 Bodily pain: 84 vs. 76 General health: 75 vs. 54 Vitality: 71 vs. 57 Social function: 89 vs. 78 Emotional role function: 84 vs. 73 Mental health: 86 vs. 76 | [underlined: UCLA PCI] Urinary function: 71 vs. 87 Urinary bother: 81 vs. 84 Sexual function: 27 vs. 29 Sexual bother: 47 vs. 25 Bowel function: 88 vs. 89 Bowel bother: 90 vs. 90 | NR | NR | NR
Schapira et al, 2001^61^ 1 year | [underlined: SF-36 mean scores] Physical function: 84 vs. 68 Physical role function: 72 vs. 64 Bodily pain: 78 vs. 68 General health: 71 vs. 68 Vitality: 69 vs. 60 Social function: 88 vs. 86 Emotional role function: 83 vs. 77 Mental health: 77 vs. 81 | [underlined: UCLA PCI mean scores] Urinary function: 62 vs. 92 Urinary bother: 67 vs. 84 Sexual function: 20 vs. 36 Sexual bother: 29 vs. 62 Bowel function: 88 vs. 86 Bowel bother: 86 vs. 81 | [underlined: Urinary incontinence] 16/36 (44%) vs. 1/25 (4%) | [underlined: Erectile dysfunction] 33/37 (89%) vs. 17/25 (68%) | NR
Siegel et al, 2001^62^ 4.4 years | NR | NR | NR | [underlined: Erectile dysfunction] 353/392 (90%) vs. 40/64 (63%) | NR
Smith et al, 2000^63^ 3.8 years | [underlined: SF-36 mean scores] Physical function: 87 vs. 85 Physical role function: 78 vs. 80 Bodily pain: 82 vs. 87 General health: 76 vs. 71 Vitality: 67 vs. 69 Social function: 90 vs. 92 Emotional role function: 86 vs. 91 Mental health: 81 vs. 82 | [underlined: UCLA PCI mean scores] Urinary function: 75 vs. 94 Urinary bother: 78 vs. 88 Sexual function: 26 vs. 60 Sexual bother: 34 vs. 69 | NR | NR | NR
Smith et al, 2009^64^ 3 years | [underlined: SF-36 mean scores] Nerve sparing vs. non-nerve sparing radical prostatectomy vs. watchful waiting PCS: 50 vs. 49 vs. 47 MCS: 53 vs. 54 vs. 53 | [underlined: UCLA PCI mean scores] Nerve sparing vs. non-nerve sparing radical prostatectomy vs. watchful waiting Urinary function: 86 vs. 83 vs. 92 Urinary bother: 85 vs. 83 vs. 84 Sexual function: 35 vs. 22 vs. 44 Sexual bother: 52 vs. 54 vs. 66 Bowel function: 88 vs. 89 vs. 87 Bowel bother: 90 vs. 91 vs. 88 | [underlined: Urinary incontinence] 111/981 (12%) vs. 6/200 (3%) | [underlined: Erectile dysfunction] 695/981 (71%) vs. 94/200 (47%) | [underlined: Moderate or severe bowel problems] 32/981 (3%) vs. 11/200 (6%)
Talcott et al, 2003^65^ 2 years | NR | [underlined: Urinary incontinence mean scores] 23 vs. 18 [underlined: Sexual function mean scores] 69 vs. 51 [underlined: Bowel problems mean scores] 5 vs. 7 | NR | NR | NR
Radiotherapy vs. watchful waiting
Randomized, controlled trials
Fransson et al, 2001^32^ and Fransson et al, 2009^33^ 10 years | [underlined: QLQ-C30 mean scores] 3-yr followup Physical functioning: 83 vs. 85 Role functioning: 80 vs. 87 Emotional functioning: 85 vs. 86 Cognitive functioning: 85 vs. 86 Social functioning: 80 vs. 93 Global health: 68 vs. 71 | [underlined: QUFW94]^‡^ [underlined: mean scores] 3-yr followup Urinary incontinence: 1.5 (CI, 0.55 to 2.18) vs. 0.6 (CI, 0.13 to 1.0); p=0.008 Urinary problems in general: 1.8 (CI, 1.15 to 2.42) vs. 1.2 (CI, 0.60 to 1.86); p=0.23 Limitation in daily activity due to urinary problems: 1.1 (CI, 0.63 to 1.62) vs. 0.9 (CI, 0.27 to 1.47); p=0.06 | [underlined: Urinary incontinence, proportion of patients using pads] 3-yr followup 10/59 (17%) vs. 1/49 (2%) | NR | NR
Fransson et al, 2001^32^ and Fransson et al, 2009^33^ 10 years | [underlined: QLQ-C30 mean scores] 10-yr followup Physical functioning: 82 vs. 76 Role functioning: 77 vs. 82 Emotional functioning: 84 vs. 82 Cognitive functioning: 78 vs. 83 Social functioning: 83 vs. 85 Global health: 63 vs. 75 | [underlined: PCSS]^‡^ [underlined: mean scores] 10-yr followup Urinary function: 2 vs. 1 Urinary bother: 3 vs. 2 Urinary interference with daily activity: 1 vs. 2 Sexual function: 8 vs. 7 Sexual bother: 7 vs. 4 | [underlined: Urinary incontinence, proportion of patients regularly using pads] 10-yr followup 5/27 (19%) vs. 2/27 (7%) | NR | NR
Cohort studies
Bacon et al, 2001^51^ Up to 5 years | [underlined: SF-36 mean scores] EBRT vs. brachytherapy vs. watchful waiting PCS: 49 vs. 51 vs. 49 MCS: 53 vs. 54 vs. 55 Physical function: 83 vs. 90 vs. 79 Physical role function: 72 vs. 79 vs. 85 Bodily pain: 79 vs. 81 vs. 81 General health: 74 vs. 78 vs. 71 Vitality: 64 vs. 66 vs. 68 Social function: 87 vs. 92 vs. 87 Emotional role function: 82 vs. 86 vs. 90 Mental health: 81 vs. 84 vs. 83 | [underlined: UCLA-PCI mean scores] EBRT vs. brachytherapy vs. watchful waiting Urinary function: 89 vs. 87 vs. 93 Urinary bother: 83 vs. 75 vs. 89 Sexual function: 34 vs. 36 vs. 54 Sexual bother: 51 vs. 54 vs. 74 Bowel function: 81 vs. 80 vs. 91 Bowel bother: 78 vs. 72 vs. 89 | NR | NR | NR
Choo et al, 2010^52^ 2 years | NR | [underlined: BSFI mean scores] Sexual drive: 3.3 (EBRT, 3.3; brachytherapy, 3.3) vs. 3.4 Erectile function: 5.3 (EBRT, 4.3; brachytherapy, 6.3) vs. 6.5 Ejaculation: 4.0 (EBRT, 3.5; brachytherapy, 4.5) vs. 6.3 Sexual problem assessment: 7.7 (EBRT, 6.4; brachytherapy, 8.8) vs. 7.7 Overall satisfaction with sexual function: 2.0 (EBRT, 1.9; brachytherapy, 2.1) vs. 2.7 | NR | NR | NR
Galbraith et al, 2001^54^ 1.5 years | [underlined: SF-36 mean scores] Conventional radiation vs. proton-beam radiation vs. mixed-beam radiation vs. watchful waiting Physical function: 70 vs. 78 vs. 78 vs. 75 Physical role function: 53 vs. 82 vs. 67 vs. 67 Bodily pain: 73 vs. 80 vs. 82 vs. 84 General health: 56 vs. 59 vs. 58 vs. 54 Vitality: 59 vs. 63 vs. 63 vs. 64 Emotional role function: 61 vs. 90 vs. 80 vs. 70 Mental health: 77 vs. 82 vs. 80 vs. 79 [underlined: Quality of Life Index mean scores] Overall QOL: 57 vs. 61 vs. 61 vs. 59 | [underlined: PTSS mean scores] Conventional radiation vs. proton-beam radiation vs. mixed-beam radiation vs. watchful waiting Sexual symptoms: 3.5 vs. 3.8 vs. 3.5 vs. 3.6 Urinary symptoms: 1.7 vs. 1.7 vs. 1.6 vs. 2.0 Gastrointestinal symptoms: 1.8 vs. 1.6 vs. 1.6 vs. 1.3 | NR | NR | NR
Hoffman et al, 2003^55^ 2 years | NR | NR | [underlined: Urinary incontinence (leakage)] Daily or more often: 12% (71/583) vs. 8% (19/230) | [underlined: Erectile dysfunction] No erections at all: 39% (228/583) vs. 26% (60/230) | [underlined: Bowel urgency] Almost every day: 3% (19/583) vs. 0.4% (1/230), RR, 7.5 (CI, 1.0 to 56)
Litwin et al, 1995a56 5.6 years | [underlined: SF-36 mean scores] Physical function: 74 vs. 71 Physical role function: 56 vs. 55 Bodily pain: 74 vs. 74 General health: 66 vs. 63 Vitality: 61 vs. 60 Social function: 81 vs. 80 Emotional role function: 76 vs. 57 Mental health: 79 vs. 77 | [underlined: UCLA-PCI mean scores] Urinary function: 82 vs. 86 Urinary bother: 77 vs. 80 Sexual function: 35 vs. 41 Sexual bother: 29 vs. 37 Bowel function: 81 vs. 84 Bowel bother: 77 vs. 85 | NR | NR | NR
Litwin et al, 1995b57 5.6 years | NR | NR | [underlined: Urinary incontinence] Total urinary control: 28/54 (52%) vs. 39/63 (62%) Occasional urinary dribbling: 22/54 (41%) vs. 18/63 (29%) Frequent urinary dribbling: 3/54 (6%) vs. 4/63 (6%) No control: 1/54 (2%) vs. 2/63 (3%) | [underlined: Sexual function] Very good: 1/55 (2%) vs. 4/63 (6%) Good: 7/55 (13%) vs. 9/63 (14%) Fair: 8/55 (15%) vs. 19/63 (30%) Poor: 5/55 (9%) vs. 7/63 (11%) Very poor: 34/55 (62%) vs. 24/63 (38%) | [underlined: Bowel urgency] Rarely or never: 36/54 (67%) vs. 43/63 (68%) About once/week: 2/54 (4%) vs. 6/63 (10%) More than once/week: 4/54 (7%) vs. 3/63 (5%) About once/day: 3/54 (6%) vs. 8/63 (13%) More than once/day: 9/54 (17%) vs. 3/63 (5%)
Litwin et al, 2002^58^ 1.6 years | [underlined: SF-36 mean scores] Vitality: 61 vs. 66 Social function: 86 vs. 89 Emotional role function: 81 vs. 86 Mental health: 75 vs. 81 | NR | NR | NR | NR
Lubeck et al, 1999^59^ 2 years | [underlined: SF-36 mean scores] Physical function: 65 vs. 71 Physical role function: 55 vs. 63 Bodily pain: 74 vs. 76 General health: 54 vs. 54 Vitality: 54 vs. 57 Social function: 77 vs. 78 Emotional role function: 76 vs. 73 Mental health: 78 vs. 76 | [underlined: UCLA-PCI mean scores] Urinary function: 85 vs. 87 Urinary bother: 65 vs. 84 Sexual function: 25 vs. 29 Sexual bother: 32 vs. 25 Bowel function: 83 vs. 89 Bowel bother: 75 vs. 90 | NR | NR | NR
Schapira et al, 2001^61^ 1 year | [underlined: SF-36 mean scores] Physical function: 58 vs. 68 Physical role function: 42 vs. 64 Bodily pain: 61 vs. 68 General health: 59 vs. 68 Vitality: 55 vs. 60 Social function: 59 vs. 86 Emotional role function: 70 vs. 77 Mental health: 76 vs. 81 | [underlined: UCLA-PCI mean scores] Urinary function: 89 vs. 92 Urinary bother: 81 vs. 84 Sexual function: 25 vs. 36 Sexual bother: 60 vs. 62 Bowel function: 79 vs. 86 Bowel bother: 77 vs. 81 | [underlined: Urinary incontinence] 3/38 (8%) vs. 1/25 (4%) | [underlined: Erectile dysfunction] 30/40 (75%) vs. 17/25 (68%) | NR
Siegel et al, 2001^62^ 4.4 years | NR | NR | NR | [underlined: Erectile dysfunction] 269/315 (85%) vs. 40/64 (63%) | NR
Smith et al, 2000^63^ 3.8 years | [underlined: SF-36 mean scores] Physical function: 80 vs. 85 Physical role function: 71 vs. 80 Bodily pain: 82 vs. 87 General health: 70 vs. 71 Vitality: 65 vs. 69 Social function: 88 vs. 92 Emotional role function: 85 vs. 91 Mental health: 82 vs. 82 | [underlined: UCLA-PCI mean scores] Urinary function: 89 vs. 94 Urinary bother: 81 vs. 88 Sexual function: 40 vs. 60 Sexual bother: 51 vs. 69 | NR | NR | NR
Smith et al, 2009^64^ 3 years | [underlined: SF-36 mean scores] PCS: EBRT, 47 vs. LDB, 49 vs. HDB, 49 vs. watchful waiting, 47 MCS: EBRT, 53 vs. low-dose brachytherapy, 54 vs. high-dose brachytherapy, 52 vs. watchful waiting, 53 | [underlined: UCLA-PCI mean scores] Urinary function: EBRT, 93 vs. LDB, 94 vs. HDB, 90 vs. watchful waiting, 92 Urinary bother: EBRT, 81 vs. LDB, 84 vs. HDB, 77 vs. watchful waiting, 84 Sexual function: EBRT, 32 vs. LDB, 54 vs. HDB, 30 vs. watchful waiting, 44 Sexual bother: EBRT, 58 vs. LDB, 67 vs. HDB, 61 vs. watchful waiting, 66 Bowel function: EBRT, 85 vs. LDB, 89 vs. HDB, 88 vs. watchful waiting, 87 Bowel bother: EBRT, 85 vs. LDB, 91 vs. HDB, 84 vs. watchful waiting, 88 | [underlined: Urinary incontinence] EBRT, 3/123 (2%) vs. LDB, 3/58 (5%) vs. HDB, 3/47 (6%) vs. watchful waiting 6/200 (3%) | [underlined: Erectile dysfunction] EBRT, 72/123 (59%) vs. LDB, 20/58 (34%) vs. HDB, 31/47 (66%) vs. watchful waiting, 94/200 (47%) | [underlined: Moderate or severe bowel problems] EBRT, 6/123 (13%) vs. LDB, 0/58 (0%) vs. HDB, 4/47 (9%) vs. watchful waiting, 11/200 (6%)
Talcott et al, 2003^65^ 2 years | NR | [underlined: Talcott Scale mean scores] Urinary incontinence: EBRT, 9 (SD, 16) vs. brachytherapy, 8 (SD, 15) vs. watchful waiting, 18 (SD, 19) Sexual function: EBRT, 69 (32) vs. brachytherapy, 45 (SD, 33) vs. watchful waiting, 51 (SD, 34) Bowel problems: EBRT, 9 (SD, 9) vs. brachytherapy, 7 (SD, 9) vs. watchful waiting, 7 (SD, 11) | NR | NR | NR
Thong et al, 2009^66^ 5–10 years following diagnosis | [underlined: SF-36 mean scores] PCS: 42 vs. 45 MCS: 50 vs. 49 Physical function: 62 vs. 70 Physical role function: 56 vs. 57 Bodily pain: 70 vs. 77 General health: 60 vs. 59 Vitality: 62 vs. 65 Social function: 81 vs. 79 Emotional role function: 78 vs. 71 Mental health: 73 vs. 77 | [underlined: EPIC mean scores –physical symptoms] Urinary function: 82 vs. 86 Urinary bother: 75 vs. 78 Bowel function: 87 vs. 93 Bowel bother: 85 vs. 94 | NR | [underlined: Erectile dysfunction, proportion of patients] Problem getting an erection Nearly always: 68% (43/63) vs. 47% (28/60) Occasionally: 16% (10/63) vs. 8% (5/60) Never: 16% (10/63) vs. 45% (27/60) Problem maintaining an erection Nearly always: 71% (43/63) vs. 48% (28/60) Occasionally: 6% (4/63) vs. 5% (3/60) Never: 23% (14/63) vs. 47% (28/60) | NR
Androgen deprivation therapy vs. watchful waiting
Cohort studies
Bacon et al, 2001^51^ Up to 5 years | [underlined: SF-36 mean scores] PCS: 46 vs. 49 MCS: 52 vs. 55 Physical function: 76 vs. 79 Physical role function: 62 vs. 85 Bodily pain: 75 vs. 81 General health: 66 vs. 71 Vitality: 61 vs. 68 Social function: 83 vs. 87 Emotional role function: 74 vs. 90 Mental health: 79 vs. 83 | [underlined: UCLA-PCI mean scores] Urinary function: 84 vs. 93 Urinary bother: 72 vs. 89 Sexual function: 25 vs. 54 Sexual bother: 59 vs. 74 Bowel function: 81 vs. 91 Bowel bother: 83 vs. 89 | NR | NR | NR
Hoffman et al, 2003^55^ 2 years | NR | NR | [underlined: Urinary incontinence] Leakage daily or more often: 11% (20/179) vs. 8% (19/230) | [underlined: Erectile dysfunction] No erections at all: 75% (135/179) vs. 26% (60/230) | Bowel urgency, almost every day: 4% (7/179) vs. 0.4% (1/230) Cancer treatment limits activities some or a lot: 16% (29/179) vs. 4% (10/230)
Potosky et al, 2002^60^ 1 year | [underlined: SF-36 mean scores] Physical role function: 50 vs. 61 Bodily pain: 73 vs. 74 Vitality: 53 vs. 60 Emotional role function: 74 vs. 77 Mental health: 78 vs. 78 | NR | NR | [underlined: Erectile dysfunction] Mean change from baseline: 68/88 (80% [CI, 70 to 89]) vs. 60/223 (30% [CI, 22 to 36]); p<0.001 Loss of libido, mean change from baseline: 79/149 (54% [CI, 45 to 64]) vs. 35/295 (12% [CI, 8 to 17]); p<0.001 Sexually inactive, mean change from baseline: 104/139 (75% [CI, 65 to 85]) vs. 52/248 (21% [CI, 15 to 27]); p<0.001 | Gynecomastia: 49/245 (20%) vs. 16/416 (4%); p<0.001 Hot flashes, any occurrence: 142/245 (58%) vs. 46/416 (11%); p<0.001
Smith et al, 2000^63^ 3.8 years^**^ | [underlined: SF-36 mean scores] Physical function: 72 vs. 85 Physical role function: 69 vs. 80 Bodily pain: 79 vs. 87 General health: 69 vs. 71 Vitality: 62 vs. 69 Social function: 82 vs. 92 Emotional role function: 76 vs. 91 Mental health: 76 vs. 82 | [underlined: UCLA-PCI mean scores] Urinary function: 90 vs. 94 Urinary bother: 83 vs. 88 Sexual function: 29 vs. 60 Sexual bother: 49 vs. 69 | NR | NR | NR
Smith et al, 2009^64^ 3 years | [underlined: SF-36 mean scores] PCS: 39 vs. 47 MCS: 53 vs. 53 | [underlined: UCLA-PCI mean scores] Urinary function: 93 vs. 92 Urinary bother: 73 vs. 84 Sexual function: 8 vs. 44 Sexual bother: 67 vs. 66 Bowel function: 82 vs. 87 Bowel bother: 87 vs. 88 | [underlined: Urinary incontinence] 2/61 (3%) vs. 6/200 (3%) | [underlined: Erectile dysfunction] 45/61 (74%) vs. 94/200 (47%) | [underlined: Moderate or severe bowel problems] 3/61 (5%) vs. 11/200 (6%)
Cryotherapy vs. watchful waiting
Cohort studies
Smith et al, 2000^63^ 3.8 years | [underlined: SF-36 mean scores] Physical function: 87 vs. 85 Physical role function: 84 vs. 80 Bodily pain: 87 vs. 87 General health: 72 vs. 71 Vitality: 69 vs. 69 Social function: 95 vs. 92 Emotional role function: 97 vs. 91 Mental health: 86 vs. 82 | [underlined: UCLA-PCI mean scores] Urinary function: 93 vs. 94 Urinary bother: 90 vs. 88 Sexual function: 26 vs. 60 Sexual bother: 43 vs. 69 | [underlined: Uninary incontinence] Age <70 years Total urinary control: 17/21 (81%) vs. 53/71 (74%) Occasional urinary dribbling: 4/21 (19%) vs. 15/71 (21%) Age >70 years Total urinary control: 5/21 (25%) vs. 39/71 (55%) Occasional urinary dribbling: 16/61 (75%) vs. 28/71 (39%) | [underlined: Erectile dysfunction] Age <70 years Erection firm enough for intercourse: 4/21 (20%) vs. 56/71 (81%) Age >70 years Erection firm enough for intercourse: 0/21 (0%) vs. 33/71 (47%) | NR

* Number of respondents varied according to question.

** For the subset of patients diagnosed after 1994 (806/2234), mean followup was 1 year.

† Cancer Rehabilitation Evaluation System-Short Form scores range from 0–4.

‡ Scored 0–10, higher scores indicate worse function.

Abbreviations: ADT = androgen deprivation therapy; BSFI = Brief Sexual Function Inventory; CI = confidence interval; CARES-SF = Cancer Rehabilitation Evaluation System-Short Form; EBRT = external beam radiotherapy; EPIC = Expanded Prostate Cancer Index Composite; HDB = high-dose brachytherapy; LDB = low-dose brachytherapy; MCS = mental component score; NR = not reported; PCS = physical component score; PCSS = Prostate Cancer Symptom Scale; PTSS = Southwest Oncology Group Prostate Treatment-Specific Symptoms Measure; QOL = quality of life; QLQ-C30 = Quality of Life Questionnaire for Cancer; ; RR = relative risk; SD = standard deviation; SE = standard error; SF-36 = Short-form 36-item Health Survey; UCLA-PCI = University of California, Los Angeles Prostate Cancer Index.

Appendix C3 Quality Assessment of Randomized, Controlled Trials

Trial Author, Year | Adequate randomization | Adequate allocation concealment | Similar groups at baseline | Comparable groups maintained | Eligibility criteria specified | Outcome assessors masked | Care provider masked | Patient masked | Reporting of attrition, crossovers, adherence, and contamination | Loss to followup differential or high | Intention-to-treat analysis | Post-randomization exclusions | Outcomes prespecified | Quality rating
Bill-Axelson et al, 2011^35^ | Unclear | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Differential: no High overall: no | Yes | Unclear | Yes | Good
Fransson et al, 2001^32^ | Unclear | Unclear | Yes | Yes | Yes | Unclear | No | No | No | Differential: no High overall: yes | No | Yes | Yes | Fair
Iversen et al, 1995^41^ | Unclear | Unclear | Unclear | Unclear | Yes | Unclear | No | No | Yes | Differential: no High overall: yes | No | Yes | Yes | Poor

Appendix C4 Quality Assessment of Cohort Studies

Author, Year | Study attempted to enroll a random sample or consecutive patients meeting inclusion criteria (inception cohort) | Groups comparable at baseline | Study used accurate methods for ascertaining exposures, potential confounders, and outcomes | Outcome assessors and/or data analysts blinded to treatment | Article reported attrition | Study performed appropriate statistical analyses on potential confounders | Important differential or overall high loss to followup | Outcomes prespecified, defined, and ascertained using accurate methods | Quality rating
Albertsen et al, 2007^42^ | Yes | No | Yes | Unclear | No | Yes | Differential: unclear High overall: unclear | Yes | Fair
Bacon et al, 2001^51^ | Yes | No | Yes | Unclear | No | Yes | Differential: unclear High overall: unclear | Yes | Fair
Choo et al, 2010^52^ | Yes | Unclear | Yes | Unclear | Yes | No | Differential: unclear High overall: yes | Yes | Fair
Galbraith et al, 2001^54^ | Unclear | Yes | Yes | Unclear | Yes | No | Differential: unclear High overall: yes | Yes | Fair
Hoffman et al, 2003^55^ | Yes | No | Yes | Unclear | No | No | Differential: unclear High overall: yes | Yes | Fair
Ladjevardi et al, 2010^43^ | Yes | No | Yes | Unclear | No | Yes | Differential: unclear High overall: unclear | Yes | Fair
Litwin et al, 1995a56 | Yes | No | Yes | Unclear | No | Yes | Differential: no High overall: unclear (patients per analysis varied) | Yes | Fair
Litwin et al, 1995b57 (Methods reported in Litwin et al, 1995a56) | Yes | No | Yes | Unclear | No | Yes | Differential: no High overall: no | Yes | Fair
Litwin et al, 2002^58^ | Yes | Yes | Yes | Unclear | No | Yes | Differential: unclear High overall: unclear | Yes | Fair
Lu-Yao et al, 2008^44^ | Yes | No | Yes | Unclear | No | Yes | Differential: unclear High overall: unclear | Yes | Fair
Lubeck et al, 1999^59^ | Yes | No | Yes | Unclear | Yes | Yes | Differential: unclear High overall: yes | Yes | Fair
Merglen et al, 2007^45^ | Yes | No | Yes | Unclear | Yes | Yes | Differential: unclear High overall: no | Yes | Fair
Potosky et al, 2002^60^ | Yes | Yes | Yes | Unclear | Yes | Yes | Differential: no High overall: no | Yes | Good
Schapira et al, 2001^61^ | Unclear | Yes | Yes | Unclear | Yes | Yes | Differential: unclear High overall: no | Yes | Fair
Schymura et al, 2010^46^ | Yes | No | Yes | Unclear | Yes | Yes | Differential: no High overall: No | Yes | Fair
Siegel et al, 2001^62^ | Unclear | Unclear | Yes | Unclear | No | No | Differential: no High overall: no | Yes | Fair
Smith et al, 2000^63^ | Yes | No | Yes | Unclear | Yes | Yes | Differential: unclear High overall: yes | Yes | Fair
Smith et al, 2009^64^ | Yes | No | Yes | Yes | Yes | Yes | Differential: unclear High overall: no | Yes | Good
Stattin et al, 2010^10^ | Yes | No | Yes | Unclear | No | Yes | Differential: unclear High overall: unclear | Yes | Fair
Talcott et al, 2003^65^ | Yes | No | Yes | Unclear | Yes | No | Differential: no High overall: no | Yes | Fair
Tewari et al, 2007^47^ | Yes | No | Yes | Unclear | No | Yes | Differential: unclear High overall: unclear | Yes | Fair
Thong et al, 2009^66^ | Yes | Yes | Yes | Unclear | Yes | Yes | Differential: no High overall: no | Yes | Good
Wong et al, 2006^48^ | Yes | No | Yes | Unclear | No | Yes | Differential: unclear High overall: unclear | Yes | Fair
Zhou et al, 2009^49^ | Yes | No | Yes | Unclear | No | Yes | Differential: unclear High overall: unclear | Yes | Fair

Appendix C5 Evidence Table of Uncontrolled Observational Studies

Study, Year Title | Inclusion & exclusion criteria | Number screened/ eligible/enrolled | Subject age & race Stage at diagnosis Screen detected | Country & data source | Sponsor | Statistical analysis/ adjustment for potential confounders (for cohort studies) | Method of outcome ascertainment | Adverse events | Duration of followup | Loss to followup
Prostatectomy
Alibhai et al, 2005^67^ | All RP patients in Ontario, Canada 1990–1999 | NR/NR/11,010 | Mean age: 63 yrs Race: NR Stage: NR Screen detected: NR | Canada; database | Canadian Institutes of Health Research; Toronto Rehabilitation Foundation; Mary Trimmer Chair in Geriatric Medicine Research (University of Toronto) | Charlson index; diagnosis count; AIDS; anemia; cardiac disease; COPD; connective tissue disease; dementia; diabetes; hypercholesterolemia; hypertension; liver disease; obesity; other malignancy; peptic ulcer disease; peripheral vascular disease; renal failure; stroke | Database | 30-day mortality: 53/11,010 (0.5%) Any complication: 2246/11,000 (20%) Cardiovascular: 309/11,010 (3%) Vascular: 215/11,010 (2%) Wound: 555/11,010 (5%) Genitourinary: 829/11,010 (8%) | 30 days | NR
Augustin et al, 2003^71^ | Prostatectomy patients between January 1999 and February 2002 | NR/NR/1243 | Mean age: 62 yrs (SD, 6; range, 40–76) Race: NR T1: 65% (806/1243) T2: 34% (422/1243) T3: 1% (15/1243) Screen detected: NR | Germany; single center | NR | NR | Blinded chart review | Any AE: 20% (247/1243) Major complication: 4% (50/1243) Rehospitalization due to major complication: 0.6% (8/1243) Mortality: 0/1243 (0%) Any intraoperative AE: 0.7% (9/1243); - AV blockage: 0.1% (1/1243); - Orturator nerve injury: 0.1% (1/1243); - Rectal injury: 0.1% (1/1243); - Ureteral injury: 0.1% (4/1243); Any postoperative AE: 4% (51/1243); - Arrythmia: 0.2% (2/1243); - CHF: 0.2% (3/1243); - MI: 0.1% (1/1243); - Myocardial ischemia: 0.1% (1/1243); - Severe hypotension: 0.1% (1/1243); - DVT: 1% (12/1243); - PE: 0.2% (2/1243); - Acute renal insufficency: 0.2% (2/1243); - Sepsis: 0.2% (3/1243); - Wound infection: 0.1% (1/1243); - Postoperative bleeding: 0.2% (3/1243); Minor complications: 16% (197/1243) | 30 days | NR
Begg et al, 2002^69^ | Prostate cancer patients age ≥ 65 yrs in SEER database diagnosed between 1992 and 1996 Exclusion: Treated outside of a SEER state; not enrolled in Medicare Part A and B; did not have prostatectomy w/in 6 mo of diagnosis | 77,796/11,522/ 10,737 | Mean age: 70 yrs 85% white Other races NR 44% stage ≥ T3 Screen detected: NR | United States; SEER database | NR | Age, stage, comorbidities using the Romano-Charlson Index | Database | 30-day mortality: 0.5% (number of patients NR) | 60 days | NR
Rabbani et al, 2010^72^ | Consecutive prostatectomy patients between January 1999 and June 2007 | NR/NR/4592 | Mean age: 60 yrs (range, 55 to 64) 89% (4067/4592) white 7% (317/4592) black 4% (208/4592) other/unknown T1: 62% (2864/4592) T2: 34% (1571/4592) T3: 3% (150/4592) Tx: <1% (7/4592) Screen detected: NR | United States; single center database | Sidney Kimmel Center for Prostate and Urologic Cancers (?) | Age, ethnicity, BMI, stage (clinical and pathological), Gleason (clinical and pathologic) score, PSA, use of neoadjuvant hormone therapy, ASA score, Charlson score, individual comorbidity, surgical approach, nodal status, positive surgical margins, specimen weight, estimated blood loss, need for blood tranfusion, operative time | Incidence reported in prostatectomy and morbidity databases | [underlined: Early RP complications (<30 days)] Hypotension: 0.4% (14/3458) Respiratory distress: 0.2% (7/3458) Acute renal insufficiency: 0.2% (7/3458) Lymphocele: 0.8% (28/3458) Rectal or bowel injury: 0.7% (24/3458) Hematoma: 0.5% (17/3458) [underlined: Intermediate complications (31–90 days)] Sepsis: 0.03% (1/3458) Bladder neck contracture: 2.3% (80/3458) Urethral stricture: 0.6% (21/3458) Urinary retention: 0.4% (14/3458) [underlined: Late complications (>90 days)] Cerebrovascular accident or transient ischemic attack: 0.09% (3/3458) Acute renal insufficiency: 0.03% (1/3458) Bladder neck contracture: 2.8% (97/3458) Inguinal hernia: 1.2% (41/3458) Urethral stricture: 0.4% (14/3458) [underlined: Any complication] 27% (950/3458) [underlined: Early LP complications (<30 days)] Hypotension: 0.5% (6/1134) PE: 0.4% (5/1134) MI/ischemia: 0.3% (3/1134) Urinoma/urine leak: 1.3% (15/1134) Lymphocele: 1.1% (12/1134) Abscess: 1.1% (12/1134) [underlined: Intermediate LP complications (31–90 days)] Lymphocele: 0.4% (5/1134) Incisional hernia: 0.2% (2/1134) Urethral stricture: 0.2% (2/1134) [underlined: Late LP complications (>90 days)] Incisional hernia: 1.1% (12/1134) Bladder neck contracture: 0.7% (8/1134) Inguinal hernia: 0.5% (6/1134) [underlined: Any complication] 39% (442/1134) [underlined: Hazard ratios] Risk of any medical complication, RP vs. LP: HR, 1.9 (CI, 1.5 to 2.4; p<0.001) Risk of any surgical complication, RP vs. LP: HR, 1.6 (CI, 1.3 to 1.9; p<0.001) Risk of complication according to race, black vs. white: HR, 1.4 (CI, 1.0 to 2.0; p=0.027) [underlined: Mortality (results not stratified by surgery type)] 0.1% (6/4592) | 37 mos (range, 20–61) | NR
Walz et al, 2008^70^ | Prostatectomy patients included in Quebec Health Plan database diagnosed between 1989 and 2000 | NR/9739/9208 | Mean age: 65 yrs (range, 45–89) Race NR Stage NR Screen detected: NR | Canada; database | NR | Age, Charlson index, surgical volume, year of surgery | Billing codes | 30-day mortality: 0.5% (48/9208) | 30 days | NR
Yao et al, 1999^68^ | Prostatectomy patients in Medicare data-base diagnosed between 1991 and 1994 Excluded: Enrollment in HMO or treated at VHA hospital | NR/NR/101,604 | Mean age: 69 yrs 90% white 5% black 5% other Stage NR Screen detected: NR | United States; database | NR | Age, race, type of surgeon, surgical volume, teaching status of hospital, year of surgery | Procedure code 60.5 and CPT codes 55810, 55812, 55815, 55840, 55842, and 55845 | 30-day mortality: 0.5% Serious cardiac event: 3% Serious pulmonary event: 6%; - PE: 0.4%; - DVT: 0.05%; Serious wound: 0.7% Serious surgical complication: 0.8% | 30 days | NR
High-intensity focused ultrasonography
Blana et al, 2004^73^ | Stage T1-T2N0 M0; PSA <15 ng/mL; Gleason score ≤ 7; unsuitable for prostatectomy or unwilling to risk potential morbidity of prostatectomy | NR/NR/146 | Mean age: 67 yrs (SD, 7) Race NR Stage NR (all were T1-T2N0M0) Screen detected: NR | Germany; consecutive patients | NR | NR | Physician-elicited and patient self-report (questionnaire) | Symptomatic UTI: 6/137 (5%) Chronic pelvic pain: 2/137 (2%) Stress incontinence (grade 1): 8/137 (6%) Posttreatment erectile dys-function (among pretreatment potent patients; n=NR): 53% | Mean, 23 mo (range, 4–62) | n=142 6% (9/142)
Blana et al, 2008^74^ | Prostate cancer patients unsuitable for prostatectomy (comorbidity or life expectancy <10 yrs); refusal to undergo surgery or EBRT | NR/NR/163 | Mean age: 66 yrs (SD, 7) Race NR Stage T1: 39/163 (24%) Stage T2: 124/163 (76%) Screen detected: NR | Germany; consecutive patients | NR | Age, prostate volume, PSA level, Gleason score, clinical stage, use of neadjuvant hormone therapy and transurethral resection of the prostate | Physician-elicited and patient self-report (questionnaire) | Urinary incontinence, grade 1: 10/163 (6%) Grade 2: 3/163 (2%) Posttreatment erectile dys-function (among 76 pretreatment potent patients): 34/76 (45%) UTI: 11/163 (8%) Need for surgical intervention: 40/163 (25%) | Mean, 4.8 yrs (SD, 1.2 range, 3–8.6) | NR
Muto et al, 2008^75^ | Age >60 yrs; stage T1c-T2N0 M0; biopsy and MRI indicating localized disease; unsuitable for prostatectomy due to comorbidity or personal preference | NR/NR/70 | Median age: 72 yrs (range, 61–80) Race NR T1: 57/70 (81%) T2: 13/70 (19%) Screen detected: NR | Japan; method of patient selection unclear | NR | NR | Patient self-report using UCLA-PCI and IPSS | IPS score: whole HIFU, 8.13 (SD, 5.5); focal HIFU, 9.25 (SD, 7.3); p=0.37 Urinary function: whole HIFU, 97.2 (SD, 11.4); focal HIFU, 86.0 (SD, 20.8); p=0.68 Urinary bother: whole HIFU, 85.7 (SD, 24.4); focal HIFU, 80.0 (SD, 20.9); p=0.19 | Median, 34 mo (range, 8–45) | NR
Thuroff et al, 2003^76^ | Biopsy-proven prostate cancer; not suitable for prostatectomy | NR/NR/402 | Mean age: 69 yrs (SD, 7; range, 51–80) Race NR Stage NR (all were T1-T2N0M0) Screen detected: NR | Germany, France and Netherlands; method of patient selection unclear | NR | NR | Unclear | Urethrorectal fistula: 5/402 Urinary incontinence, grade 1: 44/402 (11%) Urinary incontinence, grade 2: 12/402 (3%) Urinary incontinence, grade 3: 6/402 (2%) UTI: 56/402 (14%) Erectile dysfunction: 35/402 (8%; proportion with pretreatment potency NR) | Mean, 407 days (range, 0–1541) | NR
Uchida et al, 2006^77^ | Stage T1c-T2N0 M0 without anal stricture | NR/NR/63 | Mean age: 71 yrs (SD, 1; range, 45–87) Race NR T1: 39/63 (62%) T2: 24/63 (38%) Screen detected: NR | Japan; method of patient selection unclear | NR | Age, clinical stage, Gleason score, prostate volume, PSA level | Physician-elicited and patient self-report (questionnaire) | Urethral stricture: 15/63 (24%) Retrograde ejaculation: 2/63 (3%) Urinary incontinence, grade 1: 1/63 (2%) Erectile dysfunction: 8/34 (24% among patients with pretreatment erectile function) | Mean, 22 mo (range, 3–63) | None

Abbreviations: AE = adverse event; ASA = American Society of Anesthesiologists; AV = atrioventricular; BMI = body mass index; CHF = congestive heart failure; CI = confidence interval; COPD = chronic obstructive pulmonary disease; CPT = Current Procedural Terminology; DVT = deep vein thrombosis; EBRT = external beam radiotherapy; HIFU = high-intensity focused ultrasonography; HMO = health maintenance organization; HR = hazard ratio; IPSS = International Prostate Symptom Score; LP = laparoscopic radical prostatectomy; MI = myocardial infarction; MRI = magnetic resonance imaging; NR = not reported; PE = pulmonary embolism; PSA = prostate-specific antigen; RP = radical prostatectomy; SD = standard deviation; SEER = Surveillance, Epidemiology, and End Results; UCLA-PCI = University of California, Los Angeles Prostate Cancer Index; UTI = urinary tract infection; VHA = Veterans Health Administration.