# Detailed Methods

## Appendix B1 Search Strategies

### Database: Ovid MEDLINE and Cochrane Central Register of Controlled Trials

1. Prostatic Neoplasms/dh, dt, rt, su, th, us
2. prostate cancer.mp. or Prostatic Neoplasms/
3. Treatment Outcome/
4. 2 and 3
5. 1 or 4
6. (ae or co or de or mo).fs.
7. (adverse and (effect$ or event$)).mp.
8. (safe$ or harm$ or side effect$).mp.
9. or/6–8
10. “Quality of Life”/
11. Anxiety/
12. Depression/
13. px.fs.
14. or/10–13
15. 5 and (9 or 14)
16. 15 and (20021$ or 2003$ or 2004$ or 2005$ or 2006$ or 2007$ or 2008$ or 2009$ or 2010$ or 2011$).ed.
17. 16 not (case reports or comment or editorial or letter).pt^*^
  * Search phrase not used in CCRCT search.
18. limit 17 to (English language and humans)

### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. prostate cancer.mp.
2. (harm$ or safe$ or adverse$).mp.
3. 1 and 2
4. limit 3 to full systematic review

## Appendix B2 Inclusion and Exclusion Criteria

| Include | Exclude
Population | Men with screen-detected or early-stage prostate cancer (defined as stage I or II) | Men with later-stage prostate cancer Men with refractory, hormone refractory, or recurrent prostate cancer
Interventions | Surgery (radical prostatectomy, including different surgical techniques, such as nerve sparing, robotic) Androgen deprivation therapy (androgen deprivation therapy via luteinizing hormone-releasing hormone agonists, antiandrogen therapy, and/or orchiectomy) Radiation therapy (external-beam radiation therapy, brachytherapy, and combination therapies) Cryotherapy Ultrasonography (high-intensity focused ultrasonography) | Chemotherapy (this treatment is typically used for later-stage cancer)
Outcomes (unintended effects of therapies) | Mortality (overall and disease-specific) Quality of life (overall and disease-specific) Function (overall and disease-specific) Bowel, urinary, and sexual dysfunction Psychological effects (e.g., mental status, depression, cognitive dysfunction) Endocrinological effects (e.g., bone health, hot flashes, gynecomastia) Surgical complications
Study types and designs | Randomized, controlled trials of included treatments versus watchful waiting/active surveillance or no treatment Cohort studies of included treatments versus watchful waiting/active surveillance or no treatment Uncontrolled observational studies of harms (sample size of at least 1,000), if randomized, controlled trials and cohort studies not available Smaller, uncontrolled observational studies of harms, if randomized, controlled trials, cohort studies, and larger uncontrolled studies not available
Duration | 30 days for perioperative complications >12 months for other harms

## Appendix B3 Literature Flow Diagram for Treatment Effectiveness and Harms

*Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

†Identified from reference lists, suggested by experts, etc.

Appendix B3 displays an accounting of studies reviewed for the evidence report. A total of 7920 studies were identified through searches of online databases and other sources as being potentially relevant to the evidence report. Of those, 7085 were excluded at the title or abstract level for not meeting inclusion criteria. The full text of 835 studies were reviewed for inclusion in the evidence report. Of those, 797 were excluded for not meeting inclusion criteria. The remaining 38 studies were included in the final evidence report. Of those, 11 studies were included for Key Question 1 and 27 studies were included for Key Question 2.

## Appendix B4 Excluded Studies

### Ineligible Population

Abdel-Wahab M, Reis IM, Hamilton K. Second primary cancer after radiotherapy for prostate cancer: a SEER analysis of brachytherapy versus external beam radiotherapy. Int J Radiat Oncol Biol Phys. 2008;72(1):58-68. [pmid: 18374503].
Akaza H, Homma Y, Usami M, et al. Efficacy of primary hormone therapy for localized or locally advanced prostate cancer: results of a 10-year follow-up. BJU Int. 2006;98(3):573-9. [pmid: 16925756].
Akimoto T, Ito K, Saitoh J, et al. Acute genitourinary toxicity after high-dose-rate (HDR) brachytherapy combined with hypofractionated external-beam radiation therapy for localized prostate cancer: correlation between the urethral dose in HDR brachytherapy and the severity of acute genitourinary toxicity. Int J Radiat Oncol Biol Phys. 2005;63(2):463-71. [pmid: 16168838].
Akimoto T, Katoh H, Kitamoto Y, et al. Rectal bleeding after high-dose-rate brachytherapy combined with hypofractionated external-beam radiotherapy for localized prostate cancer: impact of rectal dose in high-dose-rate brachytherapy on occurrence of grade 2 or worse rectal bleeding. Int J Radiat Oncol Biol Phys. 2006;65(2):364-70. [pmid: 16690428].
Akimoto T, Kitamoto Y, Saito J, et al. External beam radiotherapy for clinically node-negative, localized hormone-refractory prostate cancer: impact of pretreatment PSA value on radiotherapeutic outcomes. Int J Radiat Oncol Biol Phys. 2004;59(2):372-9. [pmid: 15145150].
Alibhai SM, Breunis H, Timilshina N, et al. Impact of androgen-deprivation therapy on physical function and quality of life in men with nonmetastatic prostate cancer. J Clin Oncol. 2010;28(34):5038-45. [pmid: 21041715].
Al-Mamgani A, van Putten WL, Heemsbergen WD, et al. Update of Dutch multicenter dose-escalation trial of radiotherapy for localized prostate cancer. Int J Radiat Oncol Biol Phys. 2008;72(4):980-8. [pmid: 18495377].
Anastasiadis AG, Salomon L, Katz R, et al. Radical retropubic versus laparoscopic prostatectomy: a prospective comparison of functional outcome. Urology. 2003;62(2):292-7. [pmid: 12893338].
Arcangeli S, Strigari L, Soete G, et al. Clinical and dosimetric predictors of acute toxicity after a 4-week hypofractionated external beam radiotherapy regimen for prostate cancer: results from a multicentric prospective trial. Int J Radiat Oncol Biol Phys. 2009;73(1):39-45. [pmid: 18538488].
Arlen PM, Gulley JL, Todd N, et al. Antiandrogen, vaccine and combination therapy in patients with nonmetastatic hormone refractory prostate cancer. J Urol. 2005;174(2):539-46. [pmid: 16006888].
Arredondo SA, Downs TM, Lubeck DP, et al. Watchful waiting and health-related quality of life for patients with localized prostate cancer: data from CaPSURE. J Urol. 2004;172(5 Pt 1):1830-4. [pmid: 15540732].
Artibani W, Grosso G, Novara G, et al. Is laparoscopic radical prostatectomy better than traditional retropubic radical prostatectomy? An analysis of peri-operative morbidity in two contemporary series in Italy. Eur Urol. 2003;44(4):401-6. [pmid: 14499672].
Ashman JB, Zelefsky MJ, Hunt MS, et al. Whole pelvic radiotherapy for prostate cancer using 3D conformal and intensity-modulated radiotherapy. Int J Radiat Oncol Biol Phys. 2005;63(3):765-71. [pmid: 15913914].
Aström L, Pedersen D, Mercke C, et al. Long-term outcome of high dose rate brachytherapy in radiotherapy of localised prostate cancer. Radiother Oncol. 2005;74(2):157-61. [pmid: 15734203].
Ataman F, Zurlo A, Artignan X, et al. Late toxicity following conventional radiotherapy for prostate cancer: analysis of the EORTC trial 22863. Eur J Cancer. 2004;40(11):1674-81. [pmid: 15251156].
Aus G, Pileblad E, Hugosson J, et al. Cryosurgical ablation of the prostate: 5-year follow-up of a prospective study. Eur Urol. 2002;42(2):133-8. [pmid: 12160583].
Bahn DK, Lee F, Badalament R, et al. Targeted cryoablation of the prostate: 7-year outcomes in the primary treatment of prostate cancer. Urology. 2002;60(2 Suppl 1):3-11. [pmid: 12206842].
Ballare A, Di Salvo M, Loi G, et al. Conformal radiotherapy of clinically localized prostate cancer: analysis of rectal and urinary toxicity and correlation with dose-volume parameters. Tumori. 2009;95(2):160-8. [pmid: 19579861].
Bartsch GC, Kuefer R, Braun C, et al. Nosocomial bacteriuria in patients with indwelling catheter after radical retropubic prostatectomy for prostate cancer. Urol Int. 2008;81(4):389-93. [pmid: 19077397].
Basaria S, Lieb J 2nd, Tang AM, et al. Long-term effects of androgen deprivation therapy in prostate cancer patients. Clin Endocrinol (Oxf). 2002;56(6):779-86. [pmid: 12072048].
Basaria S, Muller DC, Carducci MA, et al. Hyperglycemia and insulin resistance in men with prostate carcinoma who receive androgen-deprivation therapy. Cancer. 2006;106(3):581-8. [pmid: 16388523].
Berthelet E, Pickles T, Lee KW, et al. Long-term androgen deprivation therapy improves survival in prostate cancer patients presenting with prostate-specific antigen levels > 20 ng/mL. Int J Radiat Oncol Biol Phys. 2005;63(3):781-7. [pmid: 16199312].
Bhatnagar V, Stewart ST, Huynh V, et al. Estimating the risk of long-term erectile, urinary and bowel symptoms resulting from prostate cancer treatment. Prostate Cancer Prostatic Dis. 2006;9(2):136-46. [pmid: 16402091].
Bolla M, Collette L, Blank L, et al. Long-term results with immediate androgen suppression and external irradiation in patients with locally advanced prostate cancer (an EORTC study): a phase III randomised trial. Lancet. 2002;360(9327):103-6. [pmid: 12126818].
Bolla M, Gonzalez D, Warde P, et al. Improved survival in patients with locally advanced prostate cancer treated with radiotherapy and goserelin. New Engl J Med. 1997;337(5):295-300. [pmid: 9233866].
Borchers H, Kirschner-Hermanns R, Brehmer B, et al. Permanent 125I-seed brachytherapy or radical prostatectomy: a prospective comparison considering oncological and quality of life results. BJU Int. 2004;94(6):805-11. [pmid: 15476513].
Bria E, Cuppone F, Giannarelli D, et al. Does hormone treatment added to radiotherapy improve outcome in locally advanced prostate cancer? Meta-analysis of randomized trials. Cancer. 2009;115(15):3446-56. [pmid: 19484790].
Brown JA, Garlitz C, Gomella LG, et al. Perioperative morbidity of laparoscopic radical prostatectomy compared with open radical retropubic prostatectomy. Urol Oncol. 2004;22(2):102-6. [pmid: 15082005].
Brown JA, Rodin DM, Lee B, Dahl DM. Laparoscopic radical prostatectomy and body mass index: an assessment of 151 sequential cases. J Urol. 2005;173(2):442-5. [pmid: 15643198].
Brown MW, Brooks JP, Albert PS, Poggi MM. An analysis of erectile function after intensity modulated radiation therapy for localized prostate carcinoma. Prostate Cancer Prostatic Dis. 2007;10(2):189-93. [pmid: 17189954].
Bylow K, Dale W, Mustian K, et al. Falls and physical performance deficits in older patients with prostate cancer undergoing androgen deprivation therapy. Urology. 2008;72(2):422-7. [pmid: 18561991].
Cahlon O, Zelefsky MJ, Shippy A, et al. Ultra-high dose (86.4 Gy) IMRT for localized prostate cancer: toxicity and biochemical outcomes. Int J Radiat Oncol Biol Phys. 2008;71(2):330-7. [pmid: 18164858].
Chen Z, Maricic M, Nguyen P, et al. Low bone density and high percentage of body fat among men who were treated with androgen deprivation therapy for prostate carcinoma. Cancer. 2002;95(10):2136-44. [pmid: 12412167].
Cheng JC, Schultheiss TE, Nguyen KH, et al. Acute toxicity in definitive versus postprostatectomy image-guided radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. 2008;71(2):351-7. [pmid: 18164841].
Cherrier MM, Aubin S, Higano CS. Cognitive and mood changes in men undergoing intermittent combined androgen blockade for non-metastatic prostate cancer. Psychooncology. 2009;18(3):237-47. [pmid: 18636420].
Chien GW, Mikhail AA, Orvieto MA, et al. Modified clipless antegrade nerve preservation in robotic- assisted laparoscopic radical prostatectomy with validated sexual function evaluation. Urology. 2005;66(2):419-23. [pmid: 16040100].
Chin JL, Ng CK, Touma NJ, et al. Randomized trial comparing cryoablation and external beam radiotherapy for T2C-T3B prostate cancer. Prostate Cancer Prostatic Dis. 2008;11(1):40-5. [pmid: 17579613].
Chin YS, Bullard J, Bryant L, et al. High dose rate iridium-192 brachytherapy as a component of radical radiotherapy for the treatment of localised prostate cancer. Clin Oncol. 2006;18(6):474-9.
Chism DB, Horwitz EM, Hanlon AL, et al. Late morbidity profiles in prostate cancer patients treated to 79–84 Gy by a simple four-field coplanar beam arrangement. Int J Radiat Oncol Biol Phys. 2003;55(1):71-7. [pmid: 12504038].
Chung HT, Xia P, Chan LW, et al. Does image-guided radiotherapy improve toxicity profile in whole pelvic-treated high-risk prostate cancer? Comparison between IG-IMRT and IMRT. Int J Radiat Oncol Biol Phys. 2009;73(1):53-60. [pmid: 18501530].
Coelho RF, Palmer KJ, Rocco B, et al. Early complication rates in a single-surgeon series of 2500 robotic-assisted radical prostatectomies: report applying a standardized grading system. Eur Urol. 2010;57(6):945-52. [pmid: 20181424].
Collette L, van Poppel H, Bolla M, et al. Patients at high risk of progression after radical prostatectomy: do they all benefit from immediate post-operative irradiation? (EORTC trial 22911). Eur J Cancer. 2005;41(17):2662-72. [pmid: 16223581].
Corner C, Rojas AM, Bryant L, et al. A Phase II study of high-dose-rate afterloading brachytherapy as monotherapy for the treatment of localized prostate cancer. Int J Radiat Oncol Biol Phys. 2008;72(2):441-6. [pmid: 18249501].
Cozzarini C, Fiorino C, Ceresoli GL, et al. Significant correlation between rectal DVH and late bleeding in patients treated after radical prostatectomy with conformal or conventional radiotherapy (66.6- 70.2 Gy). Int J Radiat Oncol Biol Phys. 2003;55(3):688-94. [pmid: 12573756].
Cresswell J, Asterling S, Chaudhary M, et al. Third-generation cryotherapy for prostate cancer in the UK: a prospective study of the early outcomes in primary and recurrent disease. BJU Int. 2006;97(5):969-74. [pmid: 16643478].
Crook J, Ludgate C, Malone S, et al. Report of a multicenter Canadian phase III randomized trial of 3 months vs. 8 months neoadjuvant androgen deprivation before standard-dose radiotherapy for clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. 2004;60(1):15-23. [pmid: 15337535].
Dahl DM, Barry MJ, McGovern FJ, et al. A prospective study of symptom distress and return to baseline function after open versus laparoscopic radical prostatectomy. J Urol. 2009;182(3):956-65. [pmid: 19616252].
Dahm P, Silverstein AD, Weizer AZ, et al. A longitudinal assessment of bowel related symptoms and fecal incontinence following radical perineal prostatectomy. J Urol. 2003;169(6):2220-4. [pmid: 12771754].
Dahm P, Yang BK, Salmen CR, et al. Radical perineal prostatectomy for the treatment of localized prostate cancer in morbidly obese patients. J Urol. 2005;174(1):131-4. [pmid: 15947597].
D’Amico AV, McLeod DG, Carroll PR, et al. Time to an undetectable prostate-specific antigen (PSA) after androgen suppression therapy for postoperative or postradiation PSA recurrence and prostate cancer-specific mortality. Cancer. 2007;109(7):1290-5. [pmid: 17315162].
Dattoli M, Wallner K, True L, et al. Long-term prostate cancer control using palladium-103 brachytherapy and external beam radiotherapy in patients with a high likelihood of extracapsular cancer extension. Urology. 2007;69(2):334-7. [pmid: 17320673].
Conti PD, Atallah AN, Arruda H, et al. Intermittent versus continuous androgen suppression for prostatic cancer. Cochrane Database Syst Review. 2007;(4):CD005009.
de Crevoisier R, Tucker SL, Dong L, et al. Increased risk of biochemical and local failure in patients with distended rectum on the planning CT for prostate cancer radiotherapy. Int J Radiat Oncol Biol Phys. 2005;62(4):965-73. [pmid: 15989996].
De Meerleer G, Vakaet L, Meersschout S, et al. Intensity-modulated radiotherapy as primary treatment for prostate cancer: acute toxicity in 114 patients. Int J Radiat Oncol Biol Phys. 2004;60(3):777-87. [pmid: 15465194].
De Meerleer GO, Fonteyne VH, Vakaet L, et al. Intensity-modulated radiation therapy for prostate cancer: late morbidity and results on biochemical control. Radiother Oncol. 2007;82(2):160-6. [pmid: 17222931].
de Vries RR, Nieuwenhuijzen JA, van Tinteren H, et al. Prostate-sparing cystectomy: long-term oncological results. BJU Int. 2009;104(9):1239-43. [pmid: 19549261].
Dearnaley DP, Hall E, Lawrence D, et al. Phase III pilot study of dose escalation using conformal radiotherapy in prostate cancer: PSA control and side effects. Br J Cancer. 2005;92(3):488-98. [pmid: 15685244].
Dearnaley DP, Sydes MR, Graham JD, et al. Escalated-dose versus standard-dose conformal radiotherapy in prostate cancer: first results from the MRC RT01 randomised controlled trial. Lancet Oncol. 2007;8(6):475-87. [pmid: 17482880].
Dearnaley DP, Sydes MR, Langley RE, et al. The early toxicity of escalated versus standard dose conformal radiotherapy with neo-adjuvant androgen suppression for patients with localised prostate cancer: results from the MRC RT01 trial (ISRCTN47772397). Radiother Oncol. 2007;83(1):31-41. [pmid: 17391791].
Deichmueller CM, Wegener G, Karstens JH, Bruns F. Definitive conformal radiotherapy for localized prostate cancer: a long-term follow-up study. Anticancer Res. 2009;29(7):2627-34. [pmid: 19596938].
Demanes DJ, Brandt D, Schour L, Hill DR. Excellent results from high dose rate brachytherapy and external beam for prostate cancer are not improved by androgen deprivation. Am J Clin Oncol. 2009;32(4):342-7. [pmid: 19398902].
Denham JW, Steigler A, Lamb DS, et al. Short-term androgen deprivation and radiotherapy for locally advanced prostate cancer: results from the Trans-Tasman Radiation Oncology Group 96.01 randomised controlled trial. Lancet Oncol. 2005;6(11):841-50. [pmid: 16257791].
Di Lorenzo G, Perdonà S, De Placido S, et al. Gynecomastia and breast pain induced by adjuvant therapy with bicalutamide after radical prostatectomy in patients with prostate cancer: the role of tamoxifen and radiotherapy. J Urol. 2005;174(6):2197-203. [pmid: 16280763].
Donnelly BJ, Saliken JC, Brasher PM, et al. A randomized trial of external beam radiotherapy versus cryoablation in patients with localized prostate cancer. Cancer. 2010;116(2):323-30. [pmid: 19937954].
Donnelly BJ, Saliken JC, Ernst DS, et al. Prospective trial of cryosurgical ablation of the prostate: five- year results. Urology. 2002;60(4):645-9. [pmid: 12385926].
Efstathiou JA, Bae K, Shipley WU, et al. Cardiovascular mortality and duration of androgen deprivation for locally advanced prostate cancer: analysis of RTOG 92–02. Eur Urol. 2008;54(4):816-23. [pmid: 18243498].
Egawa S, Kuruma H, Suyama K, et al. Delayed recovery of urinary continence after laparoscopic radical prostatectomy. Int J Urol. 2003;10(4):207-12. [pmid: 12657100].
El Hayek OR, Alfer W Jr, Reggio E, et al. Percutaneous prostate cryoablation as treatment for high-risk prostate cancer. Clinics (Sao Paulo). 2007;62(2):109-12. [pmid: 17505693].
Engels B, Soete G, Tournel K, et al. Helical tomotherapy with simultaneous integrated boost for high- risk and lymph node-positive prostate cancer: early report on acute and late toxicity. Technol Cancer Res Treat. 2009;8(5):353-9. [pmid: 19754211].
Eton DT, Lepore SJ, Helgeson VS. Psychological distress in spouses of men treated for early-stage prostate carcinoma. Cancer. 2005;103(11):2412-8. [pmid: 15858824].
Feng M, Hanlon AL, Pisanksy TM, et al. Predictive factors for late genitourinary and gastrointestinal toxicity in patients with prostate cancer treated with adjuvant or salvage radiotherapy. Int J Radiat Oncol Biol Phys. 2007;68(5):1417-23. [pmid: 17418972].
Fontaine E, Ben Mouelli S, Thomas L, et al. Urinary continence after salvage radiation therapy following radical prostatectomy, assessed by a self-administered questionnaire: a prospective study. BJU Int. 2004;94(4):521-3. [pmid: 15329104].
Fonteyne V, De Neve W, Villeirs G, et al. Late radiotherapy-induced lower intestinal toxicity (RILIT) of intensity-modulated radiotherapy for prostate cancer: the need for adapting toxicity scales and the appearance of the sigmoid colon as co-responsible organ for lower intestinal toxicity. Radiother Oncol. 2007;84(2):156-63. [pmid: 17692976].
Fonteyne V, Villeirs G, Lumen N, et al. Urinary toxicity after high dose intensity modulated radiotherapy as primary therapy for prostate cancer. Radiother Oncol. 2009;92(1):42-7. [pmid: 19356817].
Fonteyne V, Villeirs G, Speleers B, et al. Intensity-modulated radiotherapy as primary therapy for prostate cancer: report on acute toxicity after dose escalation with simultaneous integrated boost to intraprostatic lesion. Int J Radiat Oncol Biol Phys. 2008;72(3):799-807. [pmid: 18407430].
Franca CA, Vieira SL, Bernabe AJ, Penna AB. The seven-year preliminary results of brachytherapy with iodine-125 seeds for localized prostate cancer treated at a Brazilian single-center. Int Braz J Urol. 2007;33(6):752-62. [pmid: 18199343].
Fransson P, Bergström P, Lofröth PO, et al. Daily-diary evaluated side effects of dose-escalation radiotherapy of prostate cancer using the stereotactic BeamCath technique. Acta Oncol. 2003;42(4):326-33. [pmid: 12899504].
Fransson P, Bergström P, Lofröth PO, Widmark A. Prospective evaluation of urinary and intestinal side effects after BeamCath stereotactic dose-escalated radiotherapy of prostate cancer. Radiother Oncol. 2002;63(3):239-48. [pmid: 12142087].
Fransson P, Bergström P, Lofröth PO, Widmark A. Five-year prospective patient evaluation of bladder and bowel symptoms after dose-escalated radiotherapy for prostate cancer with the BeamCath technique. Int J Radiat Oncol Biol Phys. 2006;66(2):430-8. [pmid: 16904846].
Froehner M, Koch R, Hakenberg OW, Wirth MP. Second cancers as competing causes of death after radical prostatectomy. J Urol. 2009;182(3):967-70. [pmid: 19616262].
Fujioka H, Ishimura T, Sakai Y, et al. Erectile function after brachytherapy with external beam radiation for prostate cancer. Arch Androl. 2004;50(4):295-301. [pmid: 15277008].
Gacci M, Lapini A, Serni S, et al. Predictors of quality of life after radical treatment for prostate cancer. Urol Int. 2008;80(3):231-6. [pmid: 18480622].
Gacci M, Simonato A, Masieri L, et al. Urinary and sexual outcomes in long-term (5+ years) prostate cancer disease free survivors after radical prostatectomy. Health Qual Life Outcomes. 2009;7:94. [pmid: 19912640].
Galalae RM, Loch T, Riemer B, et al. Health-related quality of life measurement in long-term survivors and outcome following radical radiotherapy for localized prostate cancer. Strahlenther Onkol. 2004;180(9):582-9. [pmid: 15378189].
Galvão DA, Spry NA, Taaffe DR, et al. Changes in muscle, fat and bone mass after 36 weeks of maximal androgen blockade for prostate cancer. BJU Int. 2008;102(1):44-7. [pmid: 18336606].
Geinitz H, Thamm R, Scholz C, et al. Longitudinal analysis of quality of life in patients receiving conformal radiation therapy for prostate cancer. Strahlenther Onkol. 2010;186(1):46-52. [pmid: 20082188].
Geinitz H, Zimmermann FB, Thamm R, et al. 3D conformal radiation therapy for prostate cancer in elderly patients. Radiother Oncol. 2005;76(1):27-34. [pmid: 15990188].
Ghadjar P, Vock J, Vetterli D, et al. Acute and late toxicity in prostate cancer patients treated by dose escalated intensity modulated radiation therapy and organ tracking. Radiat Oncol. 2008;3:35. [pmid: 18937833].
Goldner G, Dimopoulos J, Kirisits C, Pötter R. Moderate dose escalation in three-dimensional conformal localized prostate cancer radiotherapy: single-institutional experience in 398 patients comparing 66 Gy versus 70 Gy versus 74 Gy. Strahlenther Onkol. 2009;185(7):438-45. [pmid: 19714305].
Goldner G, Zimmermann F, Feldmann H, et al. 3-D conformal radiotherapy of localized prostate cancer: a subgroup analysis of rectoscopic findings prior to radiotherapy and acute/late rectal side effects. Radiother Oncol. 2006;78(1):36-40. [pmid: 16271410].
Gontero P, Fontana F, Zitella A, et al. A prospective evaluation of efficacy and compliance with a multistep treatment approach for erectile dysfunction in patients after non-nerve sparing radical prostatectomy. BJU Int. 2005;95(3):359-65. [pmid: 15679794].
Goodin S, Medina P, Capanna T, et al. Effect of docetaxel in patients with hormone-dependent prostate- specific antigen progression after local therapy for prostate cancer. J Clin Oncol. 2005;23(15):3352-7. [pmid: 15738531].
Greco C, Castiglioni S, Fodor A, et al. Androgen ablation therapy does not increase the risk of late morbidity following 3D-conformal radiotherapy of organ-confined prostate cancer: the experience of the European Institute of Oncology. Tumori. 2004;90(6):567-72. [pmid: 15762358].
Green HJ, Pakenham KI, Headley BC, Gardiner RA. Coping and health-related quality of life in men with prostate cancer randomly assigned to hormonal medication or close monitoring. Psychooncology. 2002;11(5):401-14. [pmid: 12228873].
Gregori A, Simonato A, Lissiani A, et al. Laparoscopic radical prostatectomy: perioperative complications in an initial and consecutive series of 80 cases. Eur Urol. 2003;44(2):190-4. [pmid: 12875937].
Prostate Cancer Trialists’ Collaborative Group. Maximum androgen blockade in advanced prostate cancer: an overview of the randomised trials. Lancet. 2000;355(9214):1491-8. [pmid: 10801170].
Hara I, Kawabata G, Miyake H, et al. Comparison of quality of life following laparoscopic and open prostatectomy for prostate cancer. J Urol. 2003;169(6):2045-8. [pmid: 12771715].
Heemsbergen WD, Hoogeman MS, Hart GA, et al. Gastrointestinal toxicity and its relation to dose distributions in the anorectal region of prostate cancer patients treated with radiotherapy. Int J Radiat Oncol Biol Phys. 2005;61(4):1011-8. [pmid: 15752880].
Heemsbergen WD, Peeters ST, Koper PC, et al. Acute and late gastrointestinal toxicity after radiotherapy in prostate cancer patients: consequential late damage. Int J Radiat Oncol Biol Phys. 2006;66(1):3-10. [pmid: 16814954].
Hervouet S, Savard J, Simard S, et al. Psychological functioning associated with prostate cancer: cross- sectional comparison of patients treated with radiotherapy, brachytherapy, or surgery. J Pain Symptom Manage. 2005;30(5):474-84. [pmid: 16310621].
Higano C, Shields A, Wood N, et al. Bone mineral density in patients with prostate cancer without bone metastases treated with intermittent androgen suppression. Urology. 2004;64(6):1182-6. [pmid: 15596194].
Hisasue S, Kato R, Takahashi A, et al. Erectile function following external beam radiotherapy for clinically organ-confined or locally advanced prostate cancer. Jpn J Clin Oncol. 2004;34(5):269-73. [pmid: 15231862].
Holmes L Jr, Chan W, Jiang Z, et al. Impact of androgen deprivation therapy on racial/ethnic disparities in the survival of older men treated for locoregional prostate cancer. Cancer Control. 2009;16(2):176-85. [pmid: 19337204].
Homma Y, Akaza H, Okada K, et al. Endocrine therapy with or without radical prostatectomy for T1b-T3N0M0 prostate cancer. Int J Urol. 2004;11(4):218-24. [pmid: 15028100].
Hoskin PJ, Motohashi K, Bownes P, et al. High dose rate brachytherapy in combination with external beam radiotherapy in the radical treatment of prostate cancer: initial results of a randomised phase three trial. Radiother Oncol. 2007;84(2):114-20. [pmid: 17531335].
Howlett K, Koetters T, Edrington J, et al. Changes in sexual function on mood and quality of life in patients undergoing radiation therapy for prostate cancer. Oncol Nurs Forum. 2010;37(1):E58-66. [pmid: 20044333].
Hu JC, Elkin EP, Krupski TL, et al. The effect of postprostatectomy external beam radiotherapy on quality of life: results from the Cancer of the Prostate Strategic Urologic Research Endeavor. Cancer. 2006;107(2):281-8. [pmid: 16779794].
Inoue T, Segawa T, Kamba T, et al. Prevalence of skeletal complications and their impact on survival of hormone refractory prostate cancer patients in Japan. Urology. 2009;73(5):1104-9. [pmid: 19394511].
Ishikawa H, Tsuji H, Kamada T, et al. Risk factors of late rectal bleeding after carbon ion therapy for prostate cancer. Int J Radiat Oncol Biol Phys. 2006;66(4):1084-91. [pmid: 16979840].
Ishikawa H, Tsuji H, Kamada T, et al. Adverse effects of androgen deprivation therapy on persistent genitourinary complications after carbon ion radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. 2008;72(1):78-84. [pmid: 18456419].
Ishikawa H, Tsuji H, Kamada T, et al. Carbon ion radiation therapy for prostate cancer: results of a prospective phase II study. Radiother Oncol. 2006;81(1):57-64. [pmid: 16971008].
Ishiyama H, Kitano M, Satoh T, et al. Genitourinary toxicity after high-dose-rate (HDR) brachytherapy combined with hypofractionated external beam radiotherapy for localized prostate cancer: an analysis to determine the correlation between dose-volume histogram parameters in HDR brachytherapy and severity of toxicity. Int J Radiat Oncol Biol Phys. 2009;75(1):23-8. [pmid: 19243900].
Iversen P, Johansson JE, Lodding P, et al. Bicalutamide 150 mg in addition to standard care for patients with early non-metastatic prostate cancer: updated results from the Scandinavian Prostate Cancer Period Group-6 Study after a median follow-up period of 7.1 years. Scand J Urol Nephrol. 2006;40(6):441-52. [pmid: 17130095].
Iversen P, Tammela TL, Vaage S, et al. A randomised comparison of bicalutamide (“Casodex”) 150 mg versus placebo as immediate therapy either alone or as adjuvant to standard care for early non-metastatic prostate cancer: first report from the Scandinavian Prostatic Cancer Group Study No. 6. Eur Urol. 2002;42(3):204-11. [pmid: 12234503].
Izard MA, Haddad RL, Fogarty GB, et al. Six year experience of external beam radiotherapy, brachytherapy boost with a 1Ci (192)Ir source, and neoadjuvant hormonal manipulation for prostate cancer. Int J Radiat Oncol Biol Phys. 2006;66(1):38-47. [pmid: 16904516].
Jani AB, Gratzle J, Myers M. Impact of hormone therapy on acute radiotherapy toxicity in the treatment of prostate cancer. Prostate Cancer Prostatic Dis. 2005;8(3):224-8. [pmid: 15983626].
Jani AB, Kao J. Postprostatectomy adjuvant versus salvage radiotherapy: a complication-adjusted number-needed-to-treat analysis. Cancer. 2005;103(9):1833-42. [pmid: 15756656].
Jani AB, Su A, Correa D, Gratzle J. Comparison of late gastrointestinal and genitourinary toxicity of prostate cancer patients undergoing intensity-modulated versus conventional radiotherapy using localized fields. Prostate Cancer Prostatic Dis. 2007;10(1):82-6. [pmid: 16983394].
Jayadevappa R, Johnson JC, Chhatre S, et al. Ethnic variation in return to baseline values of patient-reported outcomes in older prostate cancer patients. Cancer. 2007;109(11):2229-38. [pmid: 17443664].
Jo Y, Hiratsuka J, Fujii T, et al. High-dose-rate iridium-192 afterloading therapy combined with external beam radiotherapy for T1c-T3bN0M0 prostate cancer. Urology. 2004;64(3):556-60. [pmid: 15351592].
Jo Y, Junichi H, Tomohiro F, et al. Radical prostatectomy versus high-dose rate brachytherapy for prostate cancer: effects on health-related quality of life. BJU Int. 2005;96(1):43-7. [pmid: 15963118].
Joseph KJ, Alvi R, Skarsgard D, et al. Analysis of health related quality of life (HRQoL) of patients with clinically localized prostate cancer, one year after treatment with external beam radiotherapy (EBRT) alone versus EBRT and high dose rate brachytherapy (HDRBT). Radiat Oncol. 2008;3:20. [pmid: 18627617].
Kälkner KM, Wahlgren T, Ryberg M, et al. Clinical outcome in patients with prostate cancer treated with external beam radiotherapy and high dose-rate iridium 192 brachytherapy boost: a 6-year follow-up. Acta Oncol. 2007;46(7):909-17. [pmid: 17917823].
Kannan V, Sathiyanarayanan VK, Sagde S, et al. Three dimensional conformal radiation therapy in prostate adenocarcinoma: survival and rectal toxicity. J Cancer Res Ther. 2005;1(1):34-7. [pmid: 17998623].
Kato T, Komiya A, Suzuki H, et al. Effect of androgen deprivation therapy on quality of life in Japanese men with prostate cancer. Int J Urol. 2007;14(5):416-21. [pmid: 17511724].
Kawakami S, Fukui I, Yonese J, et al. Antegrade radical retropubic prostatectomy with preliminary ligation of vascular pedicles in 614 consecutive patients. Jpn J Clin Oncol. 2007;37(7):528-33. [pmid: 17720739].
Kim-Sing C, Pickles T. Prostate Cohort Outcomes Initiative. Intervention after PSA failure: examination of intervention time and subsequent outcomes from a prospective patient database. Int J Radiat Oncol Biol Phys. 2004;60(2):463-9. [pmid: 15380580].
Kirschner-Hermanns R, Borchers H, Reineke T, et al. Fecal incontinence after radical perineal prostatectomy: a prospective study. Urology. 2005;65(2):337-42. [pmid: 15708049].
Kneebone A, Turner S, Berry M, et al. Australian prostate-specific antigen outcome and toxicity following radiation therapy for localized prostate cancer. Australas Radiol. 2003;47(4):422-7. [pmid: 14641196].
Koper PC, Heemsbergen WD, Hoogeman MS, et al. Impact of volume and location of irradiated rectum wall on rectal blood loss after radiotherapy of prostate cancer. Int J Radiat Oncol Biol Phys. 2004;58(4):1072-82. [pmid: 15001247].
Koper PC, Jansen P, van Putten W, et al. Gastro-intestinal and genitourinary morbidity after 3D conformal radiotherapy of prostate cancer: observations of a randomized trial. Radiother Oncol. 2004;73(1):1-9. [pmid: 15465140].
Korfage IJ, Essink-Bot ML, Janssens AC, et al. Anxiety and depression after prostate cancer diagnosis and treatment: 5-year follow-up. Br J Cancer. 2006;94(8):1093-8. [pmid: 16622434].
Korfage IJ, Essink-Bot ML, Borsboom GJ, et al. Five-year follow-up of health-related quality of life after primary treatment of localized prostate cancer. Int J Cancer. 2005;116(2):291-6. [pmid: 15800919].
Krupski T, Petroni GR, Bissonette EA, et al. Quality-of-life comparison of radical prostatectomy and interstitial brachytherapy in the treatment of clinically localized prostate cancer. Urology. 2000;55(5):736-42. [pmid: 10792092].
Krupski TL, Sonn G, Kwan L, et al. Ethnic variation in health-related quality of life among low-income men with prostate cancer. Ethn Dis. 2005;15(3):461-8. [pmid: 16108307].
Kuban D, Pollack A, Huang E, et al. Hazards of dose escalation in prostate cancer radiotherapy. Int J Radiat Oncol Biol Phys. 2003;57(5):1260-8. [pmid: 14630260].
Kübler HR, Tseng TY, Sun L, et al. Impact of nerve sparing technique on patient self-assessed outcomes after radical perineal prostatectomy. J Urol. 2007;178(2):488-92. [pmid: 17561133].
Kupelian PA, Thakkar VV, Khuntia D, et al. Hypofractionated intensity-modulated radiotherapy (70 Gy at 2.5 Gy per fraction) for localized prostate cancer: long-term outcomes. Int J Radiat Oncol Biol Phys. 2005;63(5):1463-8. [pmid: 16169683].
Kuwata Y, Muneuchi G, Igawa HH, et al. Dissociation of sexual function and sexual bother following autologous sural nerve grafting during radical prostatectomy. Int J Urol. 2007;14(6):510-4. [pmid: 17593095].
Labrie F, Candas B, Cusan L, et al. Screening decreases prostate cancer mortality: 11-year follow-up of the 1988 Quebec prospective randomized controlled trial. Prostate. 2004;59(3):311-8. [pmid: 15042607].
Lane TM, Ansell W, Farrugia D, et al. Long-term outcomes in patients with prostate cancer managed with intermittent androgen suppression. Urol Int. 2004;73(2):117-22. [pmid: 15331894].
Langenhuijsen JF, van Lin EN, Kiemeney LA, et al. Ultrasound-guided transrectal implantation of gold markers for prostate localization during external beam radiotherapy: complication rate and risk factors. Int J Radiat Oncol Biol Phys. 2007;69(3):671-6. [pmid: 17512133].
Latini DM, Hart SL, Knight SJ, et al. The relationship between anxiety and time to treatment for patients with prostate cancer on surveillance. J Urol. 2007;178(3 Pt 1):826-31. [pmid: 17632144].
Lee HM, Solan MJ, Lupinacci P, et al. Long-term outcome of patients with prostate cancer and pathologic seminal vesicle invasion (pT3b): effect of adjuvant radiotherapy. Urology. 2004;64(1):84-9. [pmid: 15245941].
Lee YH, Huang JK, Lu CM. The impact on sexual function after nerve sparing and non-nerve sparing radical retropubic prostatectomy. J Chin Med Assoc. 2003;66(1):13-8. [pmid: 12728969].
Lein M, Stibane I, Mansour R, et al. Complications, urinary continence, and oncologic outcome of 1000 laparoscopic transperitoneal radical prostatectomies: experience at the Charité Hospital Berlin, Campus Mitte. Eur Urol. 2006;50(6):1278-82. [pmid: 16846677].
Lesperance RN, Kjorstadt RJ, Halligan JB, Steele SR, et al. Colorectal complications of external beam radiation versus brachytherapy for prostate cancer. Am J Surg. 2008;195(5):616-20. [pmid: 18374892].
Levy ME, Perera S, van Londen GJ, et al. Physical function changes in prostate cancer patients on androgen deprivation therapy: a 2-year prospective study. Urology. 2008;71(4):735-9. [pmid: 18279933].
Lin C, Turner S, Mai T, et al. Late rectal and urinary toxicity from conformal, dose-escalated radiation therapy for prostate cancer: a prospective study of 402 patients. Australas Radiol. 2007;51(6):578-83. [pmid: 17958696].
Lin CC, Hsu CH, Hour TC, et al. Weekly paclitaxel and high-dose 5-fluorouracil plus leucovorin in hormone-refractory prostate cancer: in vitro combined effects and a phase II trial. Urol Oncol. 2007;25(3):207-13. [pmid: 17483017].
Lips IM, Dehnad H, van Gils CH, et al. High-dose intensity-modulated radiotherapy for prostate cancer using daily fiducial marker-based position verification: acute and late toxicity in 331 patients. Radiat Oncol. 2008;3:15. [pmid: 18495016].
Little DJ, Kuban DA, Levy LB, et al. Quality-of-life questionnaire results 2 and 3 years after radiotherapy for prostate cancer in a randomized dose-escalation study. Urology. 2003;62(4):707-13. [pmid: 14550448].
Liu M, Pickles T, Agranovich A, et al. Impact of neoadjuvant androgen ablation and other factors on late toxicity after external beam prostate radiotherapy. Int J Radiat Oncol Biol Phys. 2004;58(1):59-67. [pmid: 14697421].
Livi L, Paiar F, Banci-Buonamici F, et al. Localized prostate cancer treated with intensity-modulated radiotherapy. Tumori. 2006;92(3):197-201. [pmid: 16869235].
Livsey JE, Cowan RA, Wylie JP, et al. Hypofractionated conformal radiotherapy in carcinoma of the prostate: five-year outcome analysis. Int J Radiat Oncol Biol Phys. 2003;57(5):1254-9. [pmid: 14630259].
Long J, Fallick M, LaRock DR, et al. Preliminary outcomes following cryosurgical ablation of the prostate in patients with clinically localized prostate carcinoma. J Urol. 1998;159(2):477-84. [pmid: 9649266].
Madalinska JB, Essink-Bot ML, de Koning HJ, et al. Health-related quality-of-life effects of radical prostatectomy and primary radiotherapy for screen-detected or clinically diagnosed localized prostate cancer. J Clin Oncol. 2001;19(6):1619-28. [pmid: 11250990].
Maldonado-Valadez R, Teber D, Erdogru T, et al. The impact of neoadjuvant hormonal therapy on the outcome of laparoscopic radical prostatectomy: a matched pair analysis. J Urol. 2006;175(6):2092-6. [pmid: 16697810].
Marzi S, Saracino B, Petrongari MG, et al. Modeling of alpha/beta for late rectal toxicity from a randomized phase II study: conventional versus hypofractionated scheme for localized prostate cancer. J Exp Clin Cancer Res. 2009;28:117. [pmid: 19689825].
Masterson TA, Serio AM, Mulhall JP, et al. Modified technique for neurovascular bundle preservation during radical prostatectomy: association between technique and recovery of erectile function. BJU Int. 2008;101(10):1217-22. [pmid: 18279446].
McLeod DG, See WA, Klimberg I, et al. The bicalutamide 150 mg early prostate cancer program: findings of the North American trial at 7.7-year median followup. J Urol. 2006;176(1):75-80. [pmid: 16753373].
Mearini L, D’Urso L, Collura D, et al. Visually directed transrectal high intensity focused ultrasound for the treatment of prostate cancer: a preliminary report on the Italian experience. J Urol. 2009;181(1):105-11. [pmid: 19081465].
Medical Research Council Prostate Cancer Working Party Investigators Group. Immediate versus deferred treatment for advanced prostatic cancer: initial results of the Medical Research Council Trial. Br J Urol. 1997;79(2):235-46. [pmid: 9052476].
Messing EM, Manola J, Sarosdy M, et al. Immediate hormonal therapy compared with observation after radical prostatectomy and pelvic lymphadenectomy in men with node-positive prostate cancer. New Engl J Med. 1999;341(24):1781-8. [pmid: 10588962].
Miralbell R, Pampallona S, Rouzaud M, et al. External radiotherapy for prostate cancer with or without androgen deprivation: Geneva, 1991 to 2004. Swiss Med Wkly. 2009;139(35–36):511-7. [pmid: 19736590].
Namiki S, Ishidoya S, Kawamura S, et al. Quality of life among elderly men treated for prostate cancer with either radical prostatectomy or external beam radiation therapy. J Cancer Res Clin Oncol. 2010;136(3):379-86. [pmid: 19727818].
Namiki S, Saito S, Tochigi T, et al. Impact of hormonal therapy prior to radical prostatectomy on the recovery of quality of life. Int J Urol. 2005;12(2):173-81. [pmid: 15733112].
Namiki S, Saito S, Tochigi T, et al. Psychological distress in Japanese men with localized prostate cancer. Int J Urol. 2007;14(10):924-9. [pmid: 17880290].
Namiki S, Takegami M, Kakehi Y, et al. Analysis linking UCLA PCI with Expanded Prostate Cancer Index Composite: an evaluation of health related quality of life in Japanese men with localized prostate cancer. J Urol. 2007;178(2):473-7. [pmid: 17561164].
Namiki S, Tochigi T, Kuwahara M, et al. Health related quality of life in Japanese men after radical prostatectomy or radiation therapy for localized prostate cancer. Int J Urol. 2004;11(8):619-27. [pmid: 15285752].
Narayana V, Troyer S, Evans V, et al. Randomized trial of high- and low-source strength (125)I prostate seed implants. Int J Radiat Oncol Biol Phys. 2005;61(1):44-51. [pmid: 15629592].
Nelson JB, Love W, Chin JL, et al. Phase 3, randomized, controlled trial of atrasentan in patients with nonmetastatic, hormone-refractory prostate cancer. Cancer. 2008;113(9):2478-87. [pmid: 18785254].
Nguyen TD, Azria D, Brochon D, et al. Prostate cancer: what role for curative radiotherapy in elderly. Cancer Radiother. 2009;13(6–7):623-7. [French]. [pmid: 19695936].
Nickers P, Coppens L, de Leval J, et al. 192Ir low dose rate brachytherapy for boosting locally advanced prostate cancers after external beam radiotherapy: a phase II trial. Radiother Oncol. 2006;79(3):329-34. [pmid: 16780976].
Nieder AM, Porter MP, Soloway MS. Radiation therapy for prostate cancer increases subsequent risk of bladder and rectal cancer: a population based cohort study. J Urol. 2008;180(5):2005-9. [pmid: 18801517].
Nihei K, Ogino T, Ishikura S, et al. Phase II feasibility study of high-dose radiotherapy for prostate cancer using proton boost therapy: first clinical trial of proton beam therapy for prostate cancer in Japan. Jpn J Clin Oncol. 2005;35(12):745-52. [pmid: 16314345].
Nijkamp J, Pos FJ, Nuver TT, et al. Adaptive radiotherapy for prostate cancer using kilovoltage cone-beam computed tomography: first clinical results. Int J Radiat Oncol Biol Phys. 2008;70(1):75-82. [pmid: 17869445].
Noldus J, Michl U, Graefen M, et al. Patient-reported sexual function after nerve-sparing radical retropubic prostatectomy. Eur Urol. 2002;42(2):118-24. [pmid: 12160581].
Pai HH, Ludgate C, Pickles T, et al. Hemoglobin levels do not predict biochemical outcome for localized prostate cancer treated with neoadjuvant androgen-suppression therapy and external-beam radiotherapy. Int J Radiat Oncol Biol Phys. 2006;65(4):990-8. [pmid: 16682135].
Peeters ST, Heemsbergen WD, Koper PC, et al. Dose-response in radiotherapy for localized prostate cancer: results of the Dutch multicenter randomized phase III trial comparing 68 Gy of radiotherapy with 78 Gy. J Clin Oncol. 2006;24(13):1990-6. [pmid: 16648499].
Peeters ST, Hoogeman MS, Heemsbergen WD, et al. Volume and hormonal effects for acute side effects of rectum and bladder during conformal radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. 2005;63(4):1142-52. [pmid: 15939547].
Phan TP, Syed AM, Puthawala A, et al. High dose rate brachytherapy as a boost for the treatment of localized prostate cancer. J Urol. 2007;177(1):123-7. [pmid: 17162020].
Pilepich MV, Buzydlowski JW, John MJ, et al. Phase II trial of hormonal cytoreduction with megestrol and diethylstilbestrol in conjunction with radiotherapy for carcinoma of the prostate: outcome results of RTOG 83-07. Int J Radiat Oncol Biol Phys. 1995;32(1):175-80. [pmid: 7721614].
Pilepich MV, Caplan R, Byhardt RW, et al. Phase III trial of androgen suppression using goserelin in unfavorable-prognosis carcinoma of the prostate treated with definitive radiotherapy: report of Radiation Therapy Oncology Group protocol 85–31. J Clin Oncol. 1997;15(3):1013-21. [pmid: 9060541].
Pilepich MV, Winter K, John MJ, et al. Phase III Radiation Therapy Oncology Group (RTOG) trial 86-10 of androgen deprivation adjuvant to definitive radiotherapy in locally advanced carcinoma of the prostate. Int J Radiat Oncol Biol Phys. 2001;50(5):1243-52. [pmid: 11483335].
Pinkawa M, Piroth MD, Asadpour B, et al. Neoadjuvant hormonal therapy and external-beam radiotherapy versus external-beam irradiation alone for prostate cancer: a quality-of-life analysis. Strahlenther Onkol. 2009;185(2):101-8. [pmid: 19240996].
Poissonnier L, Murat FJ, Belot A, et al. Locally recurrent prostatic adenocarcinoma after exclusive radiotherapy: results of high intensity focused ultrasound. Prog Urol. 2008;18(4):223-9. [French]. [pmid: 18501302].
Pollack A, Zagars GK, Starkschall G, et al. Prostate cancer radiation dose response: results of the M.D. Anderson phase III randomized trial. Int J Radiat Oncol Biol Phys. 2002;53(5):1097-105. [pmid: 12128107].
Pommier P, Chabaud S, Lagrange JL, et al. Is there a role for pelvic irradiation in localized prostate adenocarcinoma? Preliminary results of GETUG-01. J Clin Oncol. 2007;25(34):5366-73. [pmid: 18048817].
Potosky AL, Knopf K, Clegg LX, et al. Quality-of-life outcomes after primary androgen deprivation therapy: results from the Prostate Cancer Outcomes Study. J Clin Oncol. 2001;19(17):3750-7. [pmid: 11533098].
Preston DM, Torréns JI, Harding P, et al. Androgen deprivation in men with prostate cancer is associated with an increased rate of bone loss. Prostate Cancer Prostatic Dis. 2002;5(4):304-10. [pmid: 12627216].
Rassweiler J, Seemann O, Schulze M, et al. Laparoscopic versus open radical prostatectomy: a comparative study at a single institution. J Urol. 2003;169(5):1689-93. [pmid: 12686809].
Robinson JW, Donnelly BJ, Siever JE, et al. A randomized trial of external beam radiotherapy versus cryoablation in patients with localized prostate cancer: quality of life outcomes. Cancer. 2009;115(20):4695-704. [pmid: 19691092].
Roumeguere T, Bollens R, Vanden Bossche M, et al. Radical prostatectomy: a prospective comparison of oncological and functional results between open and laparoscopic approaches. World J Urol. 2003;20(6):360-6. [pmid: 12682770].
Ryan CW, Huo D, Stallings JW, et al. Lifestyle factors and duration of androgen deprivation affect bone mineral density of patients with prostate cancer during first year of therapy. Urology. 2007;70(1):122-6. [pmid: 17656221].
Sakai H, Igawa T, Tsurusaki T, et al. Hot flashes during androgen deprivation therapy with luteinizing hormone-releasing hormone agonist combined with steroidal or nonsteroidal antiandrogen for prostate cancer. Urology. 2009;73(3):635-40. [pmid: 19038426].
Salminen E, Koskinen A, Backman H, Nurmi M, et al. Effect of adjuvant androgen deprivation on thyroid function tests in prostate cancer patients. Anticancer Drugs. 2004;15(4):351-6. [pmid: 15057139].
Salminen EK, Portin RI, Koskinen A, et al. Associations between serum testosterone fall and cognitive function in prostate cancer patients. Clin Cancer Res. 2004;10(22):7575-82. [pmid: 15569988].
Sathya JR, Davis IR, Julian JA, et al. Randomized trial comparing iridium implant plus external-beam radiation therapy with external-beam radiation therapy alone in node-negative locally advanced cancer of the prostate. J Clin Oncol. 2005;23(6):1192-9. [pmid: 15718316].
Schmidt JD, Gibbons RP, Murphy GP, Bartolucci A. Evaluation of adjuvant estramustine phosphate, cyclophosphamide and observation only for node-positive patients following radical prostatectomy and definitive irradiation. Prostate. 1996;28(1):51-7. [pmid: 8545281].
Schulman CC, Debruyne FM, Forster G, et al. 4-year follow-up results of a European prospective randomized study on neoadjuvant hormonal therapy prior to radical prostatectomy in T2-3N0M0 prostate cancer. Eur Urol. 2000;38(6):706-13. [pmid: 11111188].
Schwartz K, Bunner S, Bearer R, Severson RK. Complications from treatment for prostate carcinoma among men in the Detroit area. Cancer. 2002;95:82-9. [pmid: 12115320].
Segal RJ, Reid RD, Courneya KS, et al. Resistance exercise in men receiving androgen deprivation therapy for prostate cancer. J Clin Oncol. 2003;21(9):1653-9. [pmid: 12721238].
Seidenfeld J, Samson DJ, Hasselblad V, et al. Single-therapy androgen suppression in men with advanced prostate cancer: a systematic review and meta-analysis. Ann Intern Med. 2000;132(7):566-77. [pmid: 10744594].
Shahinian VB, Kuo YF, Freeman JL, Goodwin JS. Risk of fracture after androgen deprivation for prostate cancer. New Engl J Med. 2005;352(2):154-64. [pmid: 15647578].
Shahinian VB, Kuo YF, Freeman JL, Goodwin JS. Risk of the “androgen deprivation syndrome” in men receiving androgen deprivation for prostate cancer. Arch Intern Med. 2006;166(4):465-71. [pmid: 16505268].
Shinohara K, Rhee B, Presti JC Jr, Carroll PR. Cryosurgical ablation of prostate cancer: patterns of cancer recurrence. J Urol. 1997;158(6):2206-10. [pmid: 9366345].
Shipley WU, Verhey LJ, Munzenrider JE, et al. Advanced prostate cancer: the results of a randomized comparative trial of high dose irradiation boosting with conformal protons compared with conventional dose irradiation using photons alone. Int J Radiat Oncol Biol Phys. 1995;32(1):3-12. [pmid: 7721636].
Spry NA, Galvão DA, Davies R, et al. Long-term effects of intermittent androgen suppression on testosterone recovery and bone mineral density: results of a 33-month observational study. BJU Int. 2009;104(6):806-12. [pmid: 19281463].
Takizawa I, Hara N, Nishiyama T, et al. Oncological results, functional outcomes and health-related quality-of-life in men who received a radical prostatectomy or external beam radiation therapy for localized prostate cancer: a study on long-term patient outcome with risk stratification. Asian J Androl. 2009;11(3):283-90. [pmid: 19349948].
Thompson IM Jr, Tangen CM, Paradelo J, et al. Adjuvant radiotherapy for pathologically advanced prostate cancer: a randomized clinical trial. JAMA. 2006;296(19):2329-35. [pmid: 17105795].
Wake RW, Hollabaugh RS Jr, Bond KH. Cryosurgical ablation of the prostate for localized adenocarcinoma: a preliminary experience. J Urol. 1996;155(5):1663-6. [pmid: 8627849].
Widmark A, Fransson P, Tavelin B. Self-assessment questionnaire for evaluating urinary and intestinal late side effects after pelvic radiotherapy in patients with prostate cancer compared with an age-matched control population. Cancer. 1994;74(9):2520-32. [pmid: 7923010].
Wirth MP, See WA, McLeod DG, et al. Bicalutamide 150 mg in addition to standard care in patients with localized or locally advanced prostate cancer: results from the second analysis of the early prostate cancer program at median followup of 5.4 years. J Urol. 2004;172(5 Pt 1):1865-70. [pmid: 15540740].
Wyler SF, Ruszat R, Straumann U, et al. Short-, intermediate-, and long-term quality of life after laparoscopic radical prostatectomy—does the learning curve of LRP have a negative impact on patients’ quality of life?. Eur Urol. 2007;51(4):1004-14. [pmid: 17098352].

### Ineligible Intervention

Befort CA, Zelefsky MJ, Scardino PT, et al. A measure of health-related quality of life among patients with localized prostate cancer: results from ongoing scale development. Clin Prostate Cancer. 2005;4(2):100-8. [pmid: 16197610].
Castillo OA, Alston C, Sanchez-Salas R. Persistent vesicourethral anastomotic leak after laparoscopic radical prostatectomy: laparoscopic solution. Urology. 2009;73(1):124-6. [pmid: 18845321].
Chaussy C, Thüroff S. The status of high-intensity focused ultrasound in the treatment of localized prostate cancer and the impact of a combined resection. Curr Urol Rep. 2003;4(3):248-52. [pmid: 12756090].
Concato J, Wells CK, Horwitz RI, et al. The effectiveness of screening for prostate cancer: a nested case-control study. Arch Intern Med. 2006;166(1):38-43. [pmid: 16401808].
Dahn JR, Penedo FJ, Molton I, et al. Physical activity and sexual functioning after radiotherapy for prostate cancer: beneficial effects for patients undergoing external beam radiotherapy. Urology. 2005;65(5):953-8. [pmid: 15882730].
D’Amico AV, Chen MH, Roehl KA, Catalona WJ. Preoperative PSA velocity and the risk of death from prostate cancer after radical prostatectomy. New Engl J Med. 2004;351(2):125-35. [pmid: 15247353].
Daubenmier JJ, Weidner G, Marlin R, et al. Lifestyle and health-related quality of life of men with prostate cancer managed with active surveillance. Urology. 2006;67(1):125-30. [pmid: 16413347].
de Koning HJ, Liem MK, Baan CA, et al. Prostate cancer mortality reduction by screening: power and time frame with complete enrollment in the European Randomised Screening for Prostate Cancer (ERSPC) trial. Int J Cancer. 2002;98(2):268-73. [pmid: 11857418].
Deger S, Taymoorian K, Boehmer D, et al. Thermoradiotherapy using interstitial self-regulating thermoseeds: an intermediate analysis of a phase II trial. Eur Urol. 2004;45(5):574-9. [pmid: 15082198].
Elshaikh MA, Ulchaker JC, Reddy CA, et al. Prophylactic tamsulosin (Flomax) in patients undergoing prostate 125I brachytherapy for prostate carcinoma: final report of a double-blind placebo-controlled randomized study. Int J Radiat Oncol Biol Phys. 2005;62(1):164-9. [pmid: 15850917].
Fisher M. The endothelin-1 antagonist, atrasentan, improves time to progression and quality of life in hormone-refractory prostate cancer. Clin Prostate Cancer. 2002;1(2):79-80. [pmid: 15046697].
Fosså SD. A randomized phase II trial comparing weekly taxotere plus prednisolone versus prednisolone alone in androgen-independent prostate cancer. Front Radiat Ther Oncol. 2008;41:108-16. [pmid: 18544992].
Frattaroli J, Weidner G, Dnistrian AM, et al. Clinical events in prostate cancer lifestyle trial: results from two years of follow-up. Urology. 2008;72(6):1319-23. [pmid: 18602144].
Green HJ, Pakenham KI, Headley BC, et al. Altered cognitive function in men treated for prostate cancer with luteinizing hormone-releasing hormone analogues and cyproterone acetate: a randomized controlled trial. BJU Int. 2002;90(4):427-32. [pmid: 12175403].
Green HJ, Pakenham KI, Headley BC, et al. Quality of life compared during pharmacological treatments and clinical monitoring for non-localized prostate cancer: a randomized controlled trial. BJU Int. 2004;93(7):975-9. [pmid: 15142146].
Grubb RL 3rd, Pinsky PF, Greenlee RT, et al. Prostate cancer screening in the Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial: update on findings from the initial four rounds of screening in a randomized trial. BJU Int. 2008;102(11):1524-30. [pmid: 19035857].
Hoedemaeker RF, van der Kwast TH, Boer R, et al. Pathologic features of prostate cancer found at population-based screening with a four-year interval. J Natl Cancer Inst. 2001;93(15):1153-8. [pmid: 11481387].
Hugosson J, Carlsson S, Aus G, et al. Mortality results from the Göteborg randomised population-based prostate-cancer screening trial. Lancet Oncol. 2010;11(8):725-32. [pmid: 20598634].
Isbarn H, Jeldres C, Capitanio U, et al. Thirty-day mortality after transurethral resection of the prostate in patients treated with androgen deprivation therapy. J Endourol. 2009;23(8):1347-52. [pmid: 19591615].
Jani AB, Kao J, Heimann R, Hellman S. Hormone therapy and radiotherapy for early prostate cancer: a utility-adjusted number needed to treat (NNT) analysis. Int J Radiat Oncol Biol Phys. 2005;61(3):687-94. [pmid: 15708246].
Jani AB, Sokoloff M, Shalhav A, Stadler W. Androgen ablation adjuvant to postprostatectomy radiotherapy: complication-adjusted number needed to treat analysis. Urology. 2004;64(5):976-81. [pmid: 15533489].
Katz D, Koppie TM, Wu D, et al. Sociodemographic characteristics and health related quality of life in men attending prostate cancer support groups. J Urol. 2002;168(5):2092-6. [pmid: 12394716].
Kilgo MS, Howard MA, Kaplan G, et al. Evaluation of genitofemoral nerve donor site morbidity after radical prostatectomy. Ann Plast Surg. 2005;55(1):57-61. [pmid: 15985792].
Kjellman A, Akre O, Norming U, et al. 15-year followup of a population based prostate cancer screening study. J Urol. 2009;181(4):1615-21. [pmid: 19233435].
Kopec JA, Goel V, Bunting PS, et al. Screening with prostate specific antigen and metastatic prostate cancer risk: a population based case-control study. J Urol. 2005;174(2):495-9. [pmid: 16006879].
Labrie F, Candas B, Dupont A, et al. Screening decreases prostate cancer death: first analysis of the 1988 Quebec prospective randomized controlled trial. Prostate. 1999;38(2):83-91. [pmid: 9973093].
Lertakyamanee J, Ruksamanee EO, Tantiwong A, et al. The risk and effectiveness of transurethral resection of prostate. J Med Assoc Thai. 2002;85(12):1288-95. [pmid: 12678166].
Lindner U, Weersink RA, Haider MA, et al. Image guided photothermal focal therapy for localized prostate cancer: phase I trial. J Urol. 2009;182(4):1371-7. [pmid: 19683262].
Marcella SW, Rhoads GG, Carson JL, et al. Prostate-specific antigen screening and mortality from prostate cancer. J Gen Intern Med. 2008;23(3):248-53. [pmid: 18172740].
Moore CM, Nathan TR, Lees WR, et al. Photodynamic therapy using meso tetra hydroxy phenyl chlorin (mTHPC) in early prostate cancer. Lasers Surg Med. 2006;38(5):356-63. [pmid: 16392142].
Nguyen PL, Chen MH, D’Amico AV, et al. Magnetic resonance image-guided salvage brachytherapy after radiation in select men who initially presented with favorable-risk prostate cancer: a prospective phase 2 study. Cancer. 2007;110(7):1485-92. [pmid: 17701957].
O’Neill L, Armstrong J, Buckney S, et al. A phase II trial for the optimisation of treatment position in the radiation therapy of prostate cancer. Radiother Oncol. 2008;88(1):61-6. [pmid: 18453021].
Pinkawa M, Fischedick K, Treusacher P, et al. Dose-volume impact in high-dose-rate iridium-192 brachytherapy as a boost to external beam radiotherapy for localized prostate cancer—a phase II study. Radiother Oncol. 2006;78(1):41-6. [pmid: 16271785].
Pollack A, Zagars GK, Antolak JA, et al. Prostate biopsy status and PSA nadir level as early surrogates for treatment failure: analysis of a prostate cancer randomized radiation dose escalation trial. Int J Radiat Oncol Biol Phys. 2002;54(3):677-85. [pmid: 12377318].
Postma R, Roobol M, Schröder FH, van der Kwast TH. Potentially advanced malignancies detected by screening for prostate carcinoma after an interval of 4 years. Cancer. 2004;100(5):968-75. [pmid: 14983492].
Postma R, Schröder FH, van Leenders GJ, et al. Cancer detection and cancer characteristics in the European Randomized Study of Screening for Prostate Cancer (ERSPC)—section Rotterdam: a comparison of two rounds of screening. Eur Urol. 2007;52(1):89-97. [pmid: 17257742].
Raaijmakers R, Kirkels WJ, Roobol MJ, et al. Complication rates and risk factors of 5802 transrectal ultrasound-guided sextant biopsies of the prostate within a population-based screening program. Urology. 2002;60(5):826-30. [pmid: 12429309].
Saad F, Sabbagh R, McCormack M, Péloquin F. A prospective randomized trial comparing lidocaine and lubricating gel on pain level in patients undergoing transrectal ultrasound prostate biopsy. Can J Urol. 2002;9(4):1592-4. [pmid: 12243656].
Sabbagh R, McCormack M, Péloquin F, et al. A prospective randomized trial of 1-day versus 3-day antibiotic prophylaxis for transrectal ultrasound guided prostate biopsy. Can J Urol. 2004;11(2):2216-9. [pmid: 15182413].
Saltzstein D, Sieber P, Morris T, Gallo J. Prevention and management of bicalutamide-induced gynecomastia and breast pain: randomized endocrinologic and clinical studies with tamoxifen and anastrozole. Prostate Cancer Prostatic Dis. 2005;8(1):75-83. [pmid: 15685254].
Sandblom G, Varenhorst E, Löfman O, et al. Clinical consequences of screening for prostate cancer: 15 years follow-up of a randomised controlled trial in Sweden. Eur Urol. 2004;46(6):717-24. [pmid: 15548438].
Schover LR, Fouladi RT, Warneke CL, et al. The use of treatments for erectile dysfunction among survivors of prostate carcinoma. Cancer. 2002;95(11):2397-407. [pmid: 12436448].
Schröder FH, Kranse R, Rietbergen J, et al. The European Randomized Study of Screening for Prostate Cancer (ERSPC): an update. Eur Urol. 1999;35(5–6):539-43. [pmid: 10408951].
Scura KW, Budin W, Garfing E. Telephone social support and education for adaptation to prostate cancer: a pilot study. Oncol Nurs Forum. 2004;31(2):335-8. [pmid: 15017450].
Sharpley CF, Christie DR. An analysis of the psychometric profile and frequency of anxiety and depression in Australian men with prostate cancer. Psychooncology. 2007;16(7):660-7. [pmid: 17086572].
Smith DS, Catalona WJ. The nature of prostate cancer detected through prostate specific antigen based screening. J Urol. 1994;152(5 Pt 2):1732-6. [pmid: 7523720].
Smith DS, Catalona WJ. Rate of change in serum prostate specific antigen levels as a method for prostate cancer detection. J Urol. 1994;152(4):1163-7. [pmid: 7520949].
Weinmann S, Richert-Boe K, Glass AG, Weiss NS. Prostate cancer screening and mortality: a case-control study (United States). Cancer Causes Control. 2004;15(2):133-8. [pmid: 15017125].
Weinmann S, Richert-Boe KE, Van Den Eeden SK, et al. Screening by prostate-specific antigen and digital rectal examination in relation to prostate cancer mortality: a case-control study. Epidemiology. 2005;16(3):367-76. [pmid: 15824554].

### Ineligible Outcome

Aaltomaa SH, Kataja VV, Lahtinen T, et al. Eight years experience of local prostate cancer treatment with permanent I125 seed brachytherapy: morbidity and outcome results. Radiother Oncol. 2009;91(2):213-6. [pmid: 19167119].
Adolfsson J, Tribukait B, Levitt S. The 20-Yr outcome in patients with well- or moderately differentiated clinically localized prostate cancer diagnosed in the pre-PSA era: the prognostic value of tumour ploidy and comorbidity. Eur Urol. 2007;52(4):1028-35. [pmid: 17467883].
Agalliu I, Weiss N, Lin DW, Stanford JL. Prostate cancer mortality in relation to screening by prostate- specific antigen testing and digital rectal examination: a population-based study in middle-aged men. Cancer Causes Control. 2007;18(9):931-7. [pmid: 17641982].
Albertsen PC, Fryback DG, Storer BE, et al. Long-term survival among men with conservatively treated localized prostate cancer. JAMA. 1995;274(8):626-31. [pmid: 7637143].
Albertsen PC, Hanley JA, Gleason DF, Barry MJ. Competing risk analysis of men aged 55 to 74 years at diagnosis managed conservatively for clinically localized prostate cancer. JAMA. 1998;280(11):975-80. [pmid: 9749479].
Alibhai SM, Gogov S. Radical prostatectomy for early prostate cancer improves long term survival. Cancer Treat Rev. 2005;31(8):640-3. [pmid: 16289577].
Allen ZA, Merrick GS, Butler WM, et al. Detailed urethral dosimetry in the evaluation of prostate brachytherapy-related urinary morbidity. Int J Radiat Oncol Biol Phys. 2005;62(4):981-7. [pmid: 15989998].
Antonarakis ES, Blackford AL, Garrett-Mayer E, Eisenberger MA. Survival in men with nonmetastatic prostate cancer treated with hormone therapy: a quantitative systematic review. J Clin Oncol. 2007;25(31):4998-5008. [pmid: 17971600].
Battermann JJ, Boon TA, Moerland MA. Results of permanent prostate brachytherapy, 13 years of experience at a single institution. Radiother Oncol. 2004;71(1):23-8. [pmid: 15066292].
Beard C, Schultz D, Loffredo M, et al. Perineural invasion associated with increased cancer-specific mortality after external beam radiation therapy for men with low- and intermediate-risk prostate cancer. Int J Radiat Oncol Biol Phys. 2006;66(2):403-7. [pmid: 16765530].
Bellizzi KM, Latini DM, Cowan JE, et al. Fear of recurrence, symptom burden, and health-related quality of life in men with prostate cancer. Urology. 2008;72(6):1269-73. [pmid: 18342930].
Beyer DC, McKeough T, Thomas T. Impact of short course hormonal therapy on overall and cancer specific survival after permanent prostate brachytherapy. Int J Radiat Oncol Biol Phys. 2005;61(5):1299-305. [pmid: 15817331].
Beyer DC, Thomas T, Hilbe J, Swenson V. Relative influence of Gleason score and pretreatment PSA in predicting survival following brachytherapy for prostate cancer. Brachytherapy. 2003;2(2):77-84. [pmid: 15062144].
Bhayani SB, Pavlovich CP, Hsu TS, et al. Prospective comparison of short-term convalescence: laparoscopic radical prostatectomy versus open radical retropubic prostatectomy. Urology. 2003;61(3):612-6. [pmid: 12639657].
Bianco FJ Jr, Scardino PT, Eastham JA. Radical prostatectomy: long-term cancer control and recovery of sexual and urinary function (“trifecta”). Urology. 2005;66(5 Suppl):83-94. [pmid: 16194712].
Bittner N, Merrick GS, Galbreath RW, et al. Primary causes of death after permanent prostate brachytherapy. Int J Radiat Oncol Biol Phys. 2008;72(2):433-40. [pmid: 18448268].
Bittner N, Merrick GS, Wallner KE, et al. The impact of acute urinary morbidity on late urinary function after permanent prostate brachytherapy. Brachytherapy. 2007;6(4):258-66. [pmid: 17991623].
Boxer RS, Kenny AM, Dowsett R, Taxel P. The effect of 6 months of androgen deprivation therapy on muscle and fat mass in older men with localized prostate cancer. Aging Male. 2005;8(3–4):207-12. [pmid: 16390748].
Bradley CJ, Oberst K, Schenk M. Absenteeism from work: the experience of employed breast and prostate cancer patients in the months following diagnosis. Psychooncology. 2006;15(8):739-47. [pmid: 16374893].
Caire AA, Sun L, Polascik TJ, et al. Obese African-Americans with prostate cancer (T1c and a prostate- specific antigen, PSA, level of <10 ng/mL) have higher-risk pathological features and a greater risk of PSA recurrence than non-African-Americans. BJU Int. 2010;106(8):1157-60. [pmid: 20367635].
Cesaretti JA, Stock RG, Atencio DP, et al. A genetically determined dose-volume histogram predicts for rectal bleeding among patients treated with prostate brachytherapy. Int J Radiat Oncol Biol Phys. 2007;68(5):1410-6. [pmid: 17490827].
Cesaretti JA, Stock RG, Lehrer S, et al. ATM sequence variants are predictive of adverse radiotherapy response among patients treated for prostate cancer. Int J Radiat Oncol Biol Phys. 2005;61(1):196-202. [pmid: 15629612].
Cheetham P, Truesdale M, Chaudhury S, et al. Long-term cancer-specific and overall survival for men followed more than 10 years after primary and salvage cryoablation of the prostate. J Endourol. 2010;24(7):1123-9. [pmid: 20575687].
Cheung MR, Tucker SL, Dong L, et al. Investigation of bladder dose and volume factors influencing late urinary toxicity after external beam radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. 2007;67(4):1059-65. [pmid: 17241755].
Cheung R, Tucker SL, Lee AK, et al. Dose-response characteristics of low- and intermediate-risk prostate cancer treated with external beam radiotherapy. Int J Radiat Oncol Biol Phys. 2005;61(4):993-1002. [pmid: 15752878].
Cheung R, Tucker SL, Ye JS, et al. Characterization of rectal normal tissue complication probability after high-dose external beam radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. 2004;58(5):1513-9. [pmid: 15050331].
Choe KS, Jani AB, Liauw SL. External beam radiotherapy for prostate cancer patients on anticoagulation therapy: how significant is the bleeding toxicity?. Int J Radiat Oncol Biol Phys. 2010;76(3):755-60. [pmid: 19464123].
Choo R, Chander S, Danjoux C, et al. How are hemoglobin levels affected by androgen deprivation in non-metastatic prostate cancer patients?. Can J Urol. 2005;12(1):2547-52. [pmid: 15777493].
Ciezki JP, Klein EA, Angermeier K, et al. A retrospective comparison of androgen deprivation (AD) vs. no AD among low-risk and intermediate-risk prostate cancer patients treated with brachytherapy, external beam radiotherapy, or radical prostatectomy. Int J Radiat Oncol Biol Phys. 2004;60(5):1347-50. [pmid: 15590163].
Coakley FV, Eberhardt S, Kattan MW, et al. Urinary continence after radical retropubic prostatectomy: relationship with membranous urethral length on preoperative endorectal magnetic resonance imaging. J Urol. 2002;168(3):1032-5. [pmid: 12187216].
Cooperberg MR, Koppie TM, Lubeck DP, et al. How potent is potent? Evaluation of sexual function and bother in men who report potency after treatment for prostate cancer: data from CaPSURE. Urology. 2003;61(1):190-6. [pmid: 12559294].
Corn BW, Winter K, Pilepich MV. Does androgen suppression enhance the efficacy of postoperative irradiation? A secondary analysis of RTOG 85-31. Urology. 1999;54(3):495-502. [pmid: 10475361].
Cosset JM, Flam T, Thiounn N, et al. Selecting patients for exclusive permanent implant prostate brachytherapy: the experience of the Paris Institut Curie/Cochin Hospital/Necker Hospital group on 809 patients. Int J Radiat Oncol Biol Phys. 2008;71(4):1042-8. [pmid: 18339488].
Crawford ED, Sartor O, Chu F, et al. A 12-month clinical study of LA-2585 (45.0 mg): a new 6-month subcutaneous delivery system for leuprolide acetate for the treatment of prostate cancer. J Urol. 2006;175(2):533-6. [pmid: 16406989].
Crook J, Ludgate C, Malone S, et al. Final report of multicenter Canadian phase III randomized trial of 3 versus 8 months of neoadjuvant androgen deprivation therapy before conventional-dose radiotherapy for clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. 2009;73(2):327-33. [pmid: 18707821].
Dall’Oglio MF, Crippa A, Antunes AA, et al. Survival of patients with prostate cancer and normal PSA levels treated by radical prostatectomy. Int Braz J Urol. 2005;31(3):222-7. [pmid: 15992424].
D’Ambrosio DJ, Li T, Horwitz EM, et al. Does treatment duration affect outcome after radiotherapy for prostate cancer?. Int J Radiat Oncol Biol Phys. 2008;72(5):1402-7. [pmid: 18472368].
D’Amico AV, Chen MH, Renshaw AA, et al. Risk of prostate cancer recurrence in men treated with radiation alone or in conjunction with combined or less than combined androgen suppression therapy. J Clin Oncol. 2008;26(18):2979-83. [pmid: 18565884].
D’Amico AV, Chen MH, Renshaw AA, et al. Androgen suppression and radiation vs radiation alone for prostate cancer: a randomized trial. JAMA. 2008;299(3):289-95. [pmid: 18212313].
D’Amico AV, Chen MH, Renshaw AA, et al. Interval to testosterone recovery after hormonal therapy for prostate cancer and risk of death. Int J Radiat Oncol Biol Phys. 2009;75(1):10-5. [pmid: 19395184].
D’Amico AV, Chen MH, Renshaw AA, et al. Causes of death in men undergoing androgen suppression therapy for newly diagnosed localized or recurrent prostate cancer. Cancer. 2008;113(12):3290-7. [pmid: 18980297].
D’Amico AV, Cote K, Loffredo M, et al. Advanced age at diagnosis is an independent predictor of time to death from prostate carcinoma for patients undergoing external beam radiation therapy for clinically localized prostate carcinoma. Cancer. 2003;97(1):56-62. [pmid: 12491505].
D’Amico AV, Cote K, Loffredo M, et al. Pretreatment predictors of time to cancer specific death after prostate specific antigen failure. J Urol. 2003;169(4):1320-4. [pmid: 12629352].
D’Amico AV, Denham JW, Bolla M, et al. Short- vs long-term androgen suppression plus external beam radiation therapy and survival in men of advanced age with node-negative high-risk adenocarcinoma of the prostate. Cancer. 2007;109(10):2004-10. [pmid: 17397033].
D’Amico AV, Loffredo M, Renshaw AA, et al. Six-month androgen suppression plus radiation therapy compared with radiation therapy alone for men with prostate cancer and a rapidly increasing pretreatment prostate-specific antigen level. J Clin Oncol. 2006;24(25):4190-5. [pmid: 16943536].
D’Amico AV, Moul J, Carroll PR, et al. Prostate specific antigen doubling time as a surrogate end point for prostate cancer specific mortality following radical prostatectomy or radiation therapy. J Urol. 2004;172(5 Pt 2):S42-6. [pmid: 15535442].
Davis M, Sofer M, Gomez-Marin O, et al. The use of cell salvage during radical retropubic prostatectomy: does it influence cancer recurrence?. BJU Int. 2003;91(6):474-6. [pmid: 12656896].
Descazeaud A, Debré B, Flam TA. Age difference between patient and partner is a predictive factor of potency rate following radical prostatectomy. J Urol. 2006;176(6 Pt 1):2594-8. [pmid: 17085166].
DiBlasio CJ, Malcolm JB, Hammett J, et al. Survival outcomes in men receiving androgen-deprivation therapy as primary or salvage treatment for localized or advanced prostate cancer: 20-year single-centre experience. BJU Int. 2009;104(9):1208-14. [pmid: 19388987].
Diefenbach MA, Mohamed NE. Regret of treatment decision and its association with disease-specific quality of life following prostate cancer treatment. Cancer Invest. 2007;25(6):449-57. [pmid: 17882657].
Dosoretz AM, Chen MH, Salenius SA, et al. Mortality in men with localized prostate cancer treated with brachytherapy with or without neoadjuvant hormone therapy. Cancer. 2010;116(4):837-42. [pmid: 20052734].
Dunsmuir WD, McFarlane JP, Tan A, et al. Gyrus bipolar electrovaporization vs transurethral resection of the prostate: a randomized prospective single-blind trial with 1 y follow-up. Prostate Cancer Prostatic Dis. 2003;6(2):182-6. [pmid: 12806380].
Eade TN, Hanlon AL, Horwitz EM, et al. What dose of external-beam radiation is high enough for prostate cancer?. Int J Radiat Oncol Biol Phys. 2007;68(3):682-9. [pmid: 17398026].
Eapen L, Kayser C, Deshaies Y, et al. Correlating the degree of needle trauma during prostate brachytherapy and the development of acute urinary toxicity. Int J Radiat Oncol Biol Phys. 2004;59(5):1392-4. [pmid: 15275724].
Efstathiou JA, Bae K, Shipley WU, et al. Obesity and mortality in men with locally advanced prostate cancer: analysis of RTOG 85-31. Cancer. 2007;110(12):2691-9. [pmid: 17999404].
Efstathiou JA, Chen MH, Renshaw AA, et al. Influence of body mass index on prostate-specific antigen failure after androgen suppression and radiation therapy for localized prostate cancer. Cancer. 2007;109(8):1493-8. [pmid: 17340594].
Eller LS, Lev EL, Gejerman G, et al. Prospective study of quality of life of patients receiving treatment for prostate cancer. Nurs Res. 2006;55(2 Suppl):S28-36. [pmid: 16601630].
Ellis DS, Manny TB Jr, Rewcastle JC. Cryoablation as primary treatment for localized prostate cancer followed by penile rehabilitation. Urology. 2007;69(2):306-10. [pmid: 17320669].
Ellis RJ, Vertocnik A, Kim E, et al. Four-year biochemical outcome after radioimmunoguided transperineal brachytherapy for patients with prostate adenocarcinoma. Int J Radiat Oncol Biol Phys. 2003;57(2):362-70. [pmid: 12957246].
Fang LC, Dattoli M, Taira A, et al. Prostatic acid phosphatase adversely affects cause-specific survival in patients with intermediate to high-risk prostate cancer treated with brachytherapy. Urology. 2008;71(1):146-50. [pmid: 18242384].
Fosså SD, Woehre H, Kurth KH, et al. Influence of urological morbidity on quality of life in patients with prostate cancer. Eur Urol. 1997;31(Suppl 3):3-8.
Froehner M, Koch R, Litz R, et al. Preoperative cardiopulmonary risk assessment as predictor of early noncancer and overall mortality after radical prostatectomy. Urology. 2003;61(3):596-600. [pmid: 12639654].
Froehner M, Koch R, Litz RJ, et al. Interaction between age and comorbidity as predictors of mortality after radical prostatectomy. J Urol. 2008;179(5):1823-9. [pmid: 18355873].
Froehner M, Koch R, Litz RJ, et al. Detailed analysis of Charlson comorbidity score as predictor of mortality after radical prostatectomy. Urology. 2008;72(6):1252-7. [pmid: 18723211].
Froehner M, Koch R, Litz RJ, Wirth MP. Nomogram underestimates 10-year survival in healthy men selected for radical prostatectomy at age 70 years or older. Urology. 2009;73(3):610-3. [pmid: 19167030].
Gerber GS, Thisted RA, Scardino PT, et al. Results of radical prostatectomy in men with clinically localized prostate cancer: multi-institutional pooled analysis. JAMA. 1996;276(8):615-9. [pmid: 8773633].
Gillessen S, Templeton A, Marra G, et al. Risk of colorectal cancer in men on long-term androgen deprivation therapy for prostate cancer. J Natl Cancer Inst. 2010;102(23):1760-70. [pmid: 21068432].
Godley PA, Schenck AP, Amamoo M, et al. Racial differences in mortality among Medicare recipients after treatment for localized prostate cancer. J Natl Cancer Inst. 2003;95(22):1702-10. [pmid: 14625261].
Graff JN, Mori M, Li H, et al. Predictors of overall and cancer-free survival of patients with localized prostate cancer treated with primary androgen suppression therapy: results from the Prostate Cancer Outcomes Study. J Urol. 2007;177(4):1307-12. [pmid: 17382720].
Granfors T, Modig H, Damber JE, Tomic R. Combined orchiectomy and external radiotherapy versus radiotherapy alone for nonmetastatic prostate cancer with or without pelvic lymph node involvement: a prospective randomized study. J Urol. 1998;159(6):2030-4. [pmid: 9598512].
Gulley JL, Figg WD, Steinberg SM, et al. A prospective analysis of the time to normalization of serum androgens following 6 months of androgen deprivation therapy in patients on a randomized phase III clinical trial using limited hormonal therapy. J Urol. 2005;173(5):1567-71. [pmid: 15821487].
Gürdal M, Tekin A, Yücebaş E, Sengör F. Nd:YAG laser ablation plus transurethral resection for large prostates in high-risk patients. Urology. 2003;62(5):914-7. [pmid: 14624919].
Hachiya T, Okada Y, Kawata N, et al. Long-term survival following radical prostatectomy in Japanese men with clinically localized prostate cancer: a single institutional study. Int J Urol. 2004;11(10):862-9. [pmid: 15479291].
Hadley J, Yabroff HR, Barrett MJ, et al. Comparative effectiveness of prostate cancer treatments: evaluating statistical adjustments for confounding in observational data. J Natl Cancer Inst. 2010;102(23):1780-93. [pmid: 20944078].
Haliloglu A, Baltaci S, Yaman O. Penile length changes in men treated with androgen suppression plus radiation therapy for local or locally advanced prostate cancer. J Urol. 2007;177(1):128-30. [pmid: 17162022].
Hardie C, Parker C, Norman A, et al. Early outcomes of active surveillance for localized prostate cancer. BJU Int. 2005;95(7):956-60. [pmid: 15839912].
Hille A, Töws N, Schmidberger H, Hess CF. A prospective three-dimensional analysis about the impact of differences in the clinical target volume in prostate cancer irradiation on normal-tissue exposure: a potential for increasing the benefit/risk ratio. Strahlenther Onkol. 2005;181(12):789-95. [pmid: 16362789].
Hinnen KA, Battermann JJ, van Roermund JG, et al. Long-term biochemical and survival outcome of 921 patients treated with I-125 permanent prostate brachytherapy. Int J Radiat Oncol Biol Phys. 2010;76(5):1433-8. [pmid: 19540075].
Homma Y, Akaza H, Okada K, et al. Radical prostatectomy and adjuvant endocrine therapy for prostate cancer with or without preoperative androgen deprivation: five-year results. Int J Urol. 2004;11(5):295-303. [pmid: 15147545].
Horwitz EM, Levy LB, Thames HD, et al. Biochemical and clinical significance of the posttreatment prostate-specific antigen bounce for prostate cancer patients treated with external beam radiation therapy alone: a multiinstitutional pooled analysis. Cancer. 2006;107(7):1496-502. [pmid: 16944536].
Howard DL, Taylor YJ, Ross LE. Differences in lower urinary tract symptoms, treatment and mortality among African-American and white elderly men. JAMA. 2008;100(10):1146-52.
Hu JC, Kwan L, Saigal CS, Litwin MS. Regret in men treated for localized prostate cancer. J Urol. 2003;169(6):2279-83. [pmid: 12771770].
Hu K, Wallner K. Clinical course of rectal bleeding following I-125 prostate brachytherapy. Int J Radiat Oncol Biol Phys. 1998;41(2):263-5. [pmid: 9607339].
Huang G, Lepor H. Factors predisposing to the development of anastomotic strictures in a single- surgeon series of radical retropubic prostatectomies. BJU Int. 2006;97(2):255-8. [pmid: 16430623].
Ilic D, O’Connor D, Green S, Wilt T. Screening for prostate cancer. Cochrane Database Syst Rev. 2006;3:CD004720. [pmid: 16856057].
Jeldres C, Suardi N, Walz J, et al. Poor overall survival in septa- and octogenarian patients after radical prostatectomy and radiotherapy for prostate cancer: a population-based study of 6183 men. Eur Urol. 2008;54(1):107-16. [pmid: 17996358].
Jenkins R, Schover LR, Fouladi RT, et al. Sexuality and health-related quality of life after prostate cancer in African-American and white men treated for localized disease. J Sex Marital Ther. 2004;30(2):79-93. [pmid: 14742098].
Joseph J, Al-Qaisieh B, Ash D, et al. Prostate-specific antigen relapse-free survival in patients with localized prostate cancer treated by brachytherapy. BJU Int. 2004;94(9):1235-8. [pmid: 15610096].
Kawakami J, Cowan JE, Elkin EP, et al. Androgen-deprivation therapy as primary treatment for localized prostate cancer: data from Cancer of the Prostate Strategic Urologic Research Endeavor (CaPSURE). Cancer. 2006;106(8):1708-14. [pmid: 16544313].
Khatami A, Damber JE, Lodding P, et al. Does initial surveillance in early prostate cancer reduce the chance of cure by radical prostatectomy? A case control study. Scand J Urol Nephrol. 2003;37(3):213-7. [pmid: 12775279].
Khuntia D, Reddy CA, Mahadevan A, et al. Recurrence-free survival rates after external-beam radiotherapy for patients with clinical T1-T3 prostate carcinoma in the prostate-specific antigen era: what should we expect?. Cancer. 2004;100(6):1283-92. [pmid: 15022298].
Klotz L. Active surveillance with selective delayed intervention: using natural history to guide treatment in good risk prostate cancer. J Urol. 2004;172(5 Pt 2):S48-50. [pmid: 15535443].
Klotz L. Active surveillance for favorable-risk prostate cancer: what are the results and how safe is it?. Curr Urol Rep. 2007;8(5):341-4. [pmid: 17880830].
Klotz L, Zhang L, Lam A, et al. Clinical results of long-term follow-up of a large, active surveillance cohort with localized prostate cancer. J Clin Oncol. 2010;28(1):126-31. [pmid: 19917860].
Klotz LH, Goldenberg SL, Jewett M, et al. CUOG randomized trial of neoadjuvant androgen ablation before radical prostatectomy: 36-month post-treatment PSA results. Urology. 1999;53(4):757-63. [pmid: 10197852].
Klotz LH, Goldenberg SL, Jewett M, et al. Long-term followup of a randomized trial of 0 versus 3 months of neoadjuvant androgen ablation before radical prostatectomy. J Urol. 2003;170(3):791-4. [pmid: 12913699].
Knight SJ, Siston AK, Chmiel JS, et al. Ethnic variation in localized prostate cancer: a pilot study of preferences, optimism, and quality of life among black and white veterans. Clin Prostate Cancer. 2004;3(1):31-7. [pmid: 15279688].
Koupparis A, Ramsden A, Persad R. Cognitive effects of hormonal treatment for prostate cancer. BJU Int. 2004;93(7):915-6. [pmid: 15142135].
Kramer NM, Horwitz EM, Uzzo RG, et al. Matched-cohort analysis of patients with prostate cancer followed with observation or treated with three-dimensional conformal radiation therapy. BJU Int. 2004;94(1):59-62. [pmid: 15217432].
Lambert EH, Bolte K, Masson P, Katz AE. Focal cryosurgery: encouraging health outcomes for unifocal prostate cancer. Urology. 2007;69(6):1117-20. [pmid: 17572198].
Lee D. High androgen receptor levels are predictive of decreased survival in prostate cancer. Clin Prostate Cancer. 2003;2(1):13-4. [pmid: 15046676].
Lee D. Radical prostatectomy improves cancer-specific survival but not overall survival in early-stage prostate cancer. Clin Prostate Cancer. 2003;2(1):15-7. [pmid: 15046677].
Lee HM, Hong JH, Choi HY. High-intensity focused ultrasound therapy for clinically localized prostate cancer. Prostate Cancer Prostatic Dis. 2006;9(4):439-43. [pmid: 16847468].
Levy DA. Correlation of thermocouple data with voiding function after prostate cryoablation. Urology. 2010;75(2):482-6. [pmid: 19854486].
Lu-Yao GL, Yao SL. Population-based study of long-term survival in patients with clinically localised prostate cancer. Lancet. 1997;349(9056):906-10. [pmid: 9093251].
Marr PL, Elkin EP, Arredondo SA, et al. Comorbidity and primary treatment for localized prostate cancer: data from CaPSURE. J Urol. 2006;175(4):1326-31. [pmid: 16515991].
Merrick GS, Butler WM, Wallner KE, et al. The impact of prostate volume and neoadjuvant androgen- deprivation therapy on urinary function following prostate brachytherapy. Cancer J. 2004;10(3):181-9. [pmid: 15285928].
Merrick GS, Butler WM, Wallner KE, et al. The importance of radiation doses to the penile bulb vs. crura in the development of postbrachytherapy erectile dysfunction. Int J Radiat Oncol Biol Phys. 2002;54(4):1055-62. [pmid: 12419431].
Moeremans K, Caekelbergh K, Annemans L. Cost-effectiveness analysis of bicalutamide (Casodex) for adjuvant treatment of early prostate cancer. Value Health. 2004;7(4):472-81. [pmid: 15449639].
Morris WJ, Keyes M, Palma D, et al. Population-based study of biochemical and survival outcomes after permanent 125I brachytherapy for low- and intermediate-risk prostate cancer. Urology. 2009;73(4):860-5. [pmid: 19168203].
O’Brien PC, Hamilton CS, Denham JW, et al. Spontaneous improvement in late rectal mucosal changes after radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. 2004;58(1):75-80. [pmid: 14697423].
Paulson DF. Impact of radical prostatectomy in the management of clinically localized disease. J Urol. 1994;152(5 Pt 2):1826-30. [pmid: 7523729].
Paulson DF, Lin GH, Hinshaw W, Stephani S. Radical surgery versus radiotherapy for adenocarcinoma of the prostate. J Urol. 1982;128(3):502-4. [pmid: 6811766].
Philip J, McCabe JE, Roy SD, et al. Site of local anaesthesia in transrectal ultrasonography-guided 12- core prostate biopsy: does it make a difference?. BJU Int. 2006;97(2):263-5. [pmid: 16430625].
Pinkawa M, Asadpour B, Gagel B, et al. Evaluation of source displacement and dose–volume changes after permanent prostate brachytherapy with stranded seeds. Radiother Oncol. 2007;84(2):190-6. [pmid: 17706306].
Pinkawa M, Gagel B, Asadpour B, et al. Seed displacements after permanent brachytherapy for prostate cancer in dependence on the prostate level. Strahlenther Onkol. 2008;184(10):520-5. [pmid: 19016041].
Potters L, Klein EA, Kattan MW, et al. Monotherapy for stage T1-T2 prostate cancer: radical prostatectomy, external beam radiotherapy, or permanent seed implantation. Radiother Oncol. 2004;71(1):29-33. [pmid: 15066293].
Pound CR, Partin AW, Eisenberger MA, et al. Natural history of progression after PSA elevation following radical prostatectomy. JAMA. 1999;281(17):1591-7. [pmid: 10235151].
Roberts RO, Bergstralh EJ, Katusic SK, et al. Decline in prostate cancer mortality from 1980 to 1997, and an update on incidence trends in Olmsted County, Minnesota. J Urol. 1999;161(2):529-33. [pmid: 9915441].
Roemeling S, Roobol MJ, de Vries SH, et al. Active surveillance for prostate cancers detected in three subsequent rounds of a screening trial: characteristics, PSA doubling times, and outcome. Eur Urol. 2007;51(5):1244-50. [pmid: 17161520].
Roemeling S, Roobol MJ, Postma R, et al. Management and survival of screen-detected prostate cancer patients who might have been suitable for active surveillance. Eur Urol. 2006;50(3):475-82. [pmid: 16713065].
Rogers CG, Trock B, Walsh PC. Preservation of accessory pudendal arteries druing radical retropubic prostatectomy: surgical technique and results. Urology. 2004;64(1):148-51. [pmid: 15245954].
Schellhammer PF, Moriarty R, Bostwick D, Kuban D. Fifteen-year minimum follow-up of a prostate brachytherapy series: comparing the past with the present. Urology. 2000;56(3):436-9. [pmid: 10962309].
Schover LR, Fouladi RT, Warneke CL, et al. Seeking help for erectile dysfunction after treatment for prostate cancer. Arch Sex Behav. 2004;33(5):443-54. [pmid: 15305115].
Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias: dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
Schwartz K, Powell IJ, Underwood W 3rd, et al. Interplay of race, socioeconomic status, and treatment on survival of patients with prostate cancer. Urology. 2009;74(6):1296-302. [pmid: 19962532].
Sculpher M, Bryan S, Fry P, et al. Patients’ preferences for the management of non-metastatic prostate cancer: discrete choice experiment. BMJ. 2004;328(7436):382. [pmid: 14751919].
Soloway MS, Pareek K, Sharifi R, et al. Neoadjuvant androgen ablation before radical prostatectomy in cT2bNxMo prostate cancer: 5-year results. J Urol. 2002;167(1):112-6. [pmid: 11743286].
Strum SB, McDermed JE, Scholz MC, et al. Anaemia associated with androgen deprivation in patients with prostate cancer receiving combined hormone blockade. Br J Urol. 1997;79(6):933-41. [pmid: 9202563].
Uchida T, Illing RO, Cathcart PJ, Emberton M. The effect of neoadjuvant androgen suppression on prostate cancer-related outcomes after high-intensity focused ultrasound therapy. BJU Int. 2006;98(4):770-2. [pmid: 16879448].
Wagner AA, Varkarakis IM, Link RE, et al. Comparison of surgical performance during laparoscopic radical prostatectomy of two robotic camera holders, EndoAssist and AESOP: a pilot study. Urology. 2006;68(1):70-4. [pmid: 16844449].
Wallner K, Merrick G, True L, et al. 20 Gy versus 44 Gy supplemental beam radiation with Pd-103 prostate brachytherapy: preliminary biochemical outcomes from a prospective randomized multi- center trial. Radiother Oncol. 2005;75(3):307-10. [pmid: 16086912].
Wallner K, Merrick G, True L, et al. 125I versus 103Pd for low-risk prostate cancer: preliminary PSA outcomes from a prospective randomized multicenter trial. Int J Radiat Oncol Biol Phys. 2003;57(5):1297-303. [pmid: 14630265].
Wolters T, Roobol MJ, Steyerberg EW, et al. The effect of study arm on prostate cancer treatment in the large screening trial ERSPC. Int J Cancer. 2009;126(10):2387-93. [pmid: 19739124].

### Ineligible Study Design for Key Question

Berndtsson I, Lennernäs B, Hultén L. Anorectal function after modern conformal radiation therapy for prostate cancer: a pilot study. Tech Coloproctol. 2002;6(2):101-4. [pmid: 12402055].
Caffo O, Fellin G, Bolner A, et al. Prospective evaluation of quality of life after interstitial brachytherapy for localized prostate cancer. Int J Radiat Oncol Biol Phys. 2006;66(1):31-7. [pmid: 16765529].
Castillo OA, Bodden E, Vitagliano G. Management of rectal injury during laparoscopic radical prostatectomy. Int Braz J Urol. 2006;32(4):428-33. [pmid: 16953909].
Ciatto S, Zappa M, Villers A, et al. Contamination by opportunistic screening in the European Randomized Study of Prostate Cancer Screening. BJU Int. 2003;92(Suppl 2):97-100. [pmid: 14983964].
De Cicco L, Vavassori A, Cattani F, et al. Salvage high dose rate brachytherapy after primary external beam irradiation in localized prostate cancer: a case report. Tumori. 2009;95(4):553-6. [pmid: 19856677].
Erickson BA, Meeks JJ, Roehl KA, et al. Bladder neck contracture after retropubic radical prostatectomy: incidence and risk factors from a large single-surgeon experience. BJU Int. 2009;104(11):1615-9. [pmid: 19583720].
Fransson P. Patient-reported lower urinary tract symptoms, urinary incontinence, and quality of life after external beam radiotherapy for localized prostate cancer—15 years’ follow-up: a comparison with age-matched controls. Acta Oncol. 2008;47(5):852-61. [pmid: 17899451].
Fransson P, Widmark A. Self-assessed sexual function after pelvic irradiation for prostate carcinoma: comparison with an age-matched control group. Cancer. 1996;78(5):1066-78. [pmid: 8780545].
Fransson P, Widmark A. 15-year prospective follow-up of patient-reported outcomes of late bowel toxicity after external beam radiotherapy for localized prostate cancer: a comparison with age- matched controls. Acta Oncol. 2007;46(4):517-24. [pmid: 17497319].
Ghadjar P, Keller T, Rentsch CA, et al. Toxicity and early treatment outcomes in low- and intermediate- risk prostate cancer managed by high-dose-rate brachytherapy as a monotherapy. Brachytherapy. 2009;8(1):45-51. [pmid: 19038584].
Giesler RB, Given B, Given CW, et al. Improving the quality of life of patients with prostate carcinoma: a randomized trial testing the efficacy of a nurse-driven intervention. Cancer. 2005;104(4):752-62. [pmid: 15986401].
Hashine K, Kusuhara Y, Miura N, et al. Health-related quality of life using SF-8 and EPIC questionnaires after treatment with radical retropubic prostatectomy and permanent prostate brachytherapy. Jpn J Clin Oncol. 2009;39(8):502-8. [pmid: 19477898].
Hollenbeck BK, Wei JT, Sanda MG, et al. Neoadjuvant hormonal therapy impairs sexual outcome among younger men who undergo external beam radiotherapy for localized prostate cancer. Urology. 2004;63(5):946-50. [pmid: 15134986].
Huyghe E, Delannes M, Wagner F, et al. Ejaculatory function after permanent 125I prostate brachytherapy for localized prostate cancer. Int J Radiat Oncol Biol Phys. 2009;74(1):126-32. [pmid: 19362236].
Jenkins VA, Bloomfield DJ, Shilling VM, Edginton TL. Does neoadjuvant hormone therapy for early prostate cancer affect cognition? Results from a pilot study. BJU Int. 2005;96(1):48-53. [pmid: 15963119].
Joly F, Alibhai SM, Galica J, et al. Impact of androgen deprivation therapy on physical and cognitive function, as well as quality of life of patients with nonmetastatic prostate cancer. J Urol. 2006;176(6 Pt 1):2443-7. [pmid: 17085125].
Korfage IJ, de Koning HJ, Habbema JD, et al. Side-effects of treatment for localized prostate cancer: are they valued differently by patients and healthy controls?. BJU Int. 2007;99(4):801-6. [pmid: 17233804].
Korfage IJ, Essink-Bot ML, Madalinska JB, et al. Measuring disease specific quality of life in localized prostate cancer: the Dutch experience. Qual Life Res. 2003;12(4):459-64. [pmid: 12797718].
Linden RA, Weiner PR, Gomella LG, et al. Technique of outpatient placement of intraprostatic fiducial markers before external beam radiotherapy. Urology. 2009;73(4):881-6. [pmid: 19193411].
Liu B, Lerma FA, Patel S, et al. Dosimetric effects of the prone and supine positions on image guided localized prostate cancer radiotherapy. Radiother Oncol. 2008;88(1):67-76. [pmid: 18207595].
Lu-Yao GL, McLerran D, Wasson J, Wennberg JE. An assessment of radical prostatectomy: time trends, geographic variation, and outcomes. JAMA. 1993;269(20):2633-6. [pmid: 8487445].
Maestroni U, Ziveri M, Azzolini N, et al. High intensity focused ultrasound (HIFU): a useful alternative choice in prostate cancer treatment—preliminary results. Acta Biomed. 2008;79(3):211-6. [pmid: 19260381].
Marguet C, Raj GV, Brashears JH, et al. Rectourethral fistula after combination radiotherapy for prostate cancer. Urology. 2007;69(5):898-901. [pmid: 17482930].
Matzinger O, Poortmans P, Giraud JY, et al. Quality assurance in the 22991 EORTC ROG trial in localized prostate cancer: dummy run and individual case review. Radiother Oncol. 2009;90(3):285-90. [pmid: 19038468].
Michalski JM, Bae K, Roach M, et al. Long-term toxicity following 3D conformal radiation therapy for prostate cancer from the RTOG 9406 phase I/II dose escalation study. Int J Radiat Oncol Biol Phys. 2010;76(1):14-22. [pmid: 19577865].
Namiki S, Kwan L, Kagawa-Singer M, et al. Urinary quality of life after prostatectomy or radiation for localized prostate cancer: a prospective longitudinal cross-cultural study between Japanese and U.S. men. Urology. 2008;71(6):1103-8. [pmid: 18407337].
Namiki S, Kwan L, Kagawa-Singer M, et al. Distress and social dysfunction following prostate cancer treatment: a longitudinal cross-cultural comparison of Japanese and American men. Prostate Cancer Prostatic Dis. 2009;12(1):67-71. [pmid: 18392046].
Nandipati KC, Raina R, Agarwal A, Zippe CD. Nerve-sparing surgery significantly affects long-term continence after radical prostatectomy. Urology. 2007;70(6):1127-30. [pmid: 18158032].
Newton F, Burney S, Frydenberg M, et al. Assessing mood and general health-related quality of life among men treated in Australia for localized prostate cancer. Int J Urol. 2007;14(4):311-6. [pmid: 17470160].
Newton FJ, Burney S, Millar JL, et al. Disease-specific quality of life among patients with localized prostate cancer: an Australian perspective. BJU Int. 2006;97(6):1179-83. [pmid: 16686708].
Nichol A, Chung P, Lockwood G, et al. A phase II study of localized prostate cancer treated to 75.6 Gy with 3D conformal radiotherapy. Radiother Oncol. 2005;76(1):11-7. [pmid: 15990187].
Nobes JP, Wells IG, Khaksar SJ, et al. Biochemical relapse-free survival in 400 patients treated with I- 125 prostate brachytherapy: the Guildford experience. Prostate Cancer Prostatic Dis. 2009;12(1):61-6. [pmid: 18427571].
Ogawa K, Nakamura K, Onishi H, et al. Influence of age on the pattern and outcome of external beam radiotherapy for clinically localized prostate cancer. Anticancer Res. 2006;26(2B):1319-25. [pmid: 16619540].
Ohashi T, Yorozu A, Toya K, et al. Acute urinary morbidity following I-125 prostate brachytherapy. Int J Clin Oncol. 2005;10(4):262-8. [pmid: 16136372].
Olschewski T, Kröpfl D, Seegenschmiedt MH. Endourethral brachytherapy for prevention of recurrent urethral stricture following internal urethrotomy: first clinical experiences and results. Int J Radiat Oncol Biol Phys. 2003;57(5):1400-4. [pmid: 14630279].
Orio PF 3rd, Merrick GS, Allen ZA, et al. External beam radiation results in minimal changes in post void residual urine volumes during the treatment of clinically localized prostate cancer. Radiat Oncol. 2009;4:26. [pmid: 19624852].
Pisansky TM. External-beam radiotherapy for localized prostate cancer. New Engl J Med. 2006;355(15):1583-91. [pmid: 17035651].
Salminen E, Portin R, Korpela J, et al. Androgen deprivation and cognition in prostate cancer. Br J Cancer. 2003;89(6):971-6. [pmid: 12966411].
Shahinian VB, Kuo YF, Freeman JL, Goodwin JS. Determinants of androgen deprivation therapy use for prostate cancer: role of the urologist. J Natl Cancer Inst. 2006;98(12):839-45. [pmid: 16788157].
Talcott JA, Clark JA, Manola J, Mitchell SP. Bringing prostate cancer quality of life research back to the bedside: translating numbers into a format that patients can understand. J Urol. 2006;176(4 Pt 1):1558-63. [pmid: 16952681].

### Ineligible Publication Type

Abou-Elela A, Reyad I, Morsy A, et al. Continence after radical prostatectomy with bladder neck preservation. Eur J Surg Oncol. 2007;33(1):96-101. [pmid: 17123772].
Acher PL, Hodgson DJ, Murphy DG, Cahill DJ. High-intensity focused ultrasound for treating prostate cancer. BJU Int. 2007;99(1):28-32. [pmid: 17034499].
Albertsen PC. Clinical and physical determinants for toxicity of 125-I seed prostate brachytherapy. J Urol. 2005;174(5):1969-70.
Alibhai SM, Gogov S, Allibhai Z. Long-term side effects of androgen deprivation therapy in men with non-metastatic prostate cancer: a systematic literature review. Crit Rev Oncol Hematol. 2006;60(3):201-15. [pmid: 16860998].
Alivizatos G, Skolarikos A. Incontinence and erectile dysfunction following radical prostatectomy: a review. Sci World J. 2005;5:747-58.
Bariol S, Tolley D. Training and mentoring in urology: the “LAP” generation. BJU Int. 2004;93(7):913-4. [pmid: 15142133].
Beydoun HA, Mohan R, Beydoun MA, et al. Development of a scale to assess patient misperceptions about treatment choices for localized prostate cancer. BJU Int. 2010;106(3):334-41. [pmid: 20151969].
Bosch X. Radiotherapy versus surgery for prostate cancer. Lancet Oncol. 2005;6(5):263. [pmid: 15889497].
Brundage M, Lukka H, Crook J, et al. The use of conformal radiotherapy and the selection of radiation dose in T1 or T2 low or intermediate risk prostate cancer: a systematic review. Radiother Oncol. 2002;64(3):239-50. [pmid: 12242112].
Burnett AL, Aus G, Canby-Hagino ED, et al. Erectile function outcome reporting after clinically localized prostate cancer treatment. J Urol. 2007;178(2):597-601. [pmid: 17570435].
Chen QS, Blair HF. Accurate and efficient detection of pulmonary seed embolization in prostate iodine-125 permanent brachytherapy with a collimated gamma scintillation survey meter. Med Phys. 2003;30(5):785-90. [pmid: 12772985].
Cooperberg MR, Broering JM, Litwin MS, et al. The contemporary management of prostate cancer in the United States: lessons from the Cancer of the Prostate Strategic Urologic Research Endeavor (CapSURE), a national disease registry. J Urol. 2004;171(4):1393-401. [pmid: 15017184].
Copeland LA, Elshaikh MA, Jackson J, et al. Impact of brachytherapy on regional, racial, marital status, and age-related patterns of definitive treatment for clinically localized prostate carcinoma. Cancer. 2005;104(7):1372-80. [pmid: 16118801].
Cozzi P. Improving cancer control and recovery of potency after radical prostatectomy: nerve sparing versus nerve resection with grafting. ANZ J Surg. 2008;78(10):834-5. [pmid: 18959630].
D’Ambrosio DJ, Pollack A, Harris EE, et al. Assessment of external beam radiation technology for dose escalation and normal tissue protection in the treatment of prostate cancer. Int J Radiat Oncol Biol Phys. 2008;70(3):671-7. [pmid: 18262085].
De Koning HJ, Blom J, Merkelbach JW, et al. Determining the cause of death in randomized screening trial(s) for prostate cancer. BJU Int. 2003;92(Suppl 2):71-8. [pmid: 14983960].
De Koning HJ, Hakulinen T, Moss SM, et al. Monitoring the ERSPC trial. BJU Int. 2003;92(Suppl 2):112-4. [pmid: 14983967].
de Reijke TM, Laguna MP. Long-term complications of brachytherapy in local prostate cancer. BJU Int. 2003;92(8):869-73. [pmid: 14616437].
Doust J, Miller E, Duchesne G, et al. A systematic review of brachytherapy: is it an effective and safe treatment for localised prostate cancer?. Aust Fam Physician. 2004;33(7):525-9. [pmid: 15301172].
Eastham JA, Kelly WK, Grossfeld GD, et al. Cancer and Leukemia Group B (CALGB) 90203: a randomized phase 3 study of radical prostatectomy alone versus estramustine and docetaxel before radical prostatectomy for patients with high-risk localized disease. Urology. 2003;62(1):55-62. [pmid: 14747042].
Eden CG. Editorial comment on: Randomized phase II trial evaluation of erectile function after attempted unilateral cavernous nerve-sparing retropubic radical prostatectomy with versus without unilateral sural nerve grafting for clinically localized prostate cancer. Eur Urol. 2009;55(5):1143. [pmid: 18783871].
Efficace F, Bottomley A, van Andel G. Health related quality of life in prostate carcinoma patients: a systematic review of randomized controlled trials. Cancer. 2003;97(2):377-88. [pmid: 12518362].
El-Hakim A, Leung RA, Tewari A. Robotic prostatectomy: a pooled analysis of published literature. Exp Rev Anticancer Ther. 2006;6(1):11-20.
El-Hakim A, Tewari A. Robotic prostatectomy: a review. Medscape Gen Med. 2004;6(4):20.
Elliott K, Wallner K, Merrick G, Herstein P. Medical malpractice of prostate brachytherapy. Brachytherapy. 2004;3(4):231-6. [pmid: 15607155].
Gervaz PA, Wexner SD, Pemberton JH. Pelvic radiation and anorectal function: introducing the concept of sphincter-preserving radiation therapy. J Am Coll Surg. 2002;195(3):387-94. [pmid: 12229948].
Gillatt D. Antiandrogen treatments in locally advanced prostate cancer: are they all the same?. J Cancer Res Clin Oncol. 2006;132(Suppl 1):S17-26. [pmid: 16845534].
Gray RE, Wassersug RJ, Sinding C, et al. The experiences of men receiving androgen deprivation treatment for prostate cancer: a qualitative study. Can J Urol. 2005;12(4):2755-63. [pmid: 16197599].
Grönberg H. Prostate cancer epidemiology. Lancet. 2003;361(9360):859-64. [pmid: 12642065].
Gutman S, Merrick GS, Butler WM, et al. Severity categories of the International Prostate Symptom Score before, and urinary morbidity after, permanent prostate brachytherapy. BJU Int. 2006;97(1):62-8. [pmid: 16336330].
Hakimian P, Blute M Jr, Kashanian J, et al. Metabolic and cardiovascular effects of androgen deprivation therapy. BJU Int. 2008;102(11):1509-14. [pmid: 18727614].
Hammadeh MY, Philp T. Transurethral electrovaporization of the prostate (TUVP) is effective, safe and durable. Prostate Cancer Prostatic Dis. 2003;6(2):121-6. [pmid: 12806369].
Hede K. Radioactive seed implants may rival surgery for low-risk prostate cancer patients. J Natl Cancer Inst. 2007;99(20):1507-9. [pmid: 17925531].
Hegarty J, Beirne PV, Walsh E, et al. Radical prostatectomy versus watchful waiting for prostate cancer. Cochrane Database Syst Rev. 2010;(11):CD006590. [pmid: 21069689].
Henderson A, Andreyev HJ, Stephens R, Dearnaley D. Patient and physician reporting of symptoms and health-related quality of life in trials of treatment for early prostate cancer: considerations for future studies. Clin Oncol. 2006;18(10):735-43.
Henderson A, Laing RW, Langley SE. Quality of life following treatment for early prostate cancer: does low dose rate (LDR) brachytherapy offer a better outcome? A review. Eur Urol. 2004;45(2):134-41. [pmid: 14733996].
Heysek RV. Modern brachytherapy for treatment of prostate cancer. Cancer Control. 2007;14(3):238-43. [pmid: 17615529].
Hoffmann P, Schulman C. Complications of androgen-deprivation therapy in prostate cancer: the other side of the coin. BJU Int. 2009;103(8):1020-3. [pmid: 19348058].
Holzbeierlein JM. What effect does androgen suppression therapy have on frequency and timing of fatal myocardial infarctions?. Nat Clin Pract Oncol. 2008;5(2):74-5. [pmid: 17971802].
Horwich A, Parker CC, Huddart RA, Dearnaley DP. Management of early prostate cancer. Ann Oncol. 2002;13(Suppl 4):83-7. [pmid: 12401671].
Hsing AW, Chokkalingam AP. Prostate cancer epidemiology. Front Biosci. 2006;11:1388-413. [pmid: 16368524].
Hummel S, Paisley S, Morgan A, et al. Clinical and cost-effectiveness of new and emerging technologies for early localised prostate cancer: a systematic review. Health Tech Assess. 2003;7(33):1-157.
Israeli RS, Ryan CW, Jung LL. Managing bone loss in men with locally advanced prostate cancer receiving androgen deprivation therapy. J Urol. 2008;179(2):414-23. [pmid: 18076933].
Janoff DM, Parra RO. Contemporary appraisal of radical perineal prostatectomy. J Urol. 2005;173(6):1863-70. [pmid: 15879765].
Jereczek-Fossa BA, Curigliano G, Orecchia R. Systemic therapies for non-metastatic prostate cancer: review of the literature. Onkologie. 2009;32(6):359-63. [pmid: 19521126].
Kattan MW. Measuring hot flashes in men treated with hormone ablation therapy: an unmet need. Urol Nurs. 2006;26(1):13-8. [pmid: 16562382].
Katz A. Quality of life for men with prostate cancer. Cancer Nurs. 2007;30(4):302-8. [pmid: 17666980].
Keller H, Schmeller N, Janetschek G. Urinary continence after retropubic, perineal, and laparascopic radical prostatectomy: prospective comparative study. Eur Urol. 2005;(Suppl 4):103. [pmid: 16314031].
Klotz L. Active surveillance with selective delayed intervention is the way to manage “good-risk” prostate cancer. Nat Clin Pract Urol. 2005;2(3):136-42. [pmid: 16474710].
Komuro Y, Watanabe T, Nagawa H. Multiple confluent telangiectatic lesions following radiation treatment for prostate cancer. Endoscopy. 2004;36(3):252. [pmid: 14986233].
Korfage IJ, Hak T, de Koning HJ, Essink-Bot ML. Patients’ perceptions of the side-effects of prostate cancer treatment: a qualitative interview study. Soc Sci Med. 2006;63(4):911-9. [pmid: 16798130].
Labrie F. Medical castration with LHRH agonists: 25 years later with major benefits achieved on survival in prostate cancer. J Androl. 2004;25(3):305-13. [pmid: 15064303].
Langley SE, Laing RW. Iodine seed prostate brachytherapy: an alternative first-line choice for early prostate cancer. Prostate Cancer Prostatic Dis. 2004;7(3):201-7. [pmid: 15184864].
Lee F, Bahn DK, McHugh TA, et al. US-guided percutaneous cryoablation of prostate cancer. Radiology. 1994;192:769-76. [pmid: 8058945].
Lennernäs B, Edgren M, Häggman M, et al. Postoperative radiotherapy after prostatectomy: a review. Scand J Urol Nephrol. 2003;37(1):10-5. [pmid: 12745736].
Lubeck DP, Grossfeld GD, Carroll PR. The effect of androgen deprivation therapy on health-related quality of life in men with prostate cancer. Urology. 2001;58(2 Suppl 1):94-100. [pmid: 11502459].
Merrick GS, Wallner KE, Butler WM, Blasko JC. Permanent prostate brachytherapy: is supplemental external-beam radiation therapy necessary?. Oncology. 2006;20(5):514-22. [pmid: 16739748].
Miller AB, Yurgalevitch S, Weissfeld JL. Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial Project Team. Death review process in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control Clin Trials. 2000;21(6 Suppl):400S-406S. [pmid: 11189691].
Miller NL, Theodorescu D. Health-related quality of life after prostate brachytherapy. BJU Int. 2004;94(4):487-91. [pmid: 15329098].
Moon TD, Brawer MK, Wilt TJ. Prostate Intervention Versus Observation Trial (PIVOT): a randomized trial comparing radical prostatectomy with palliative expectant management for treatment of clinically localized prostate cancer. J Natl Cancer Inst. 1995;19(19):69-71.
Namiki S, Saito S, Satoh M, et al. Quality of life after radical prostatectomy in Japanese men: 2 year longitudinal study. Jpn J Clin Oncol. 2005;35(9):551-8. [pmid: 16141296].
Namiki S, Tochigi T, Kuwahara M, et al. Recovery of health related quality of life after radical prostatectomy in Japanese men: a longitudinal study. Int J Urol. 2004;11(9):742-9. [pmid: 15379938].
Namiki S, Tochigi T, Kuwahara M, et al. Health-related quality of life after radical prostatectomy in Japanese men with localized prostate cancer. Int J Urol. 2003;10(12):643-50. [pmid: 14633067].
Norlén BJ. Swedish randomized trial of radical prostatectomy versus watchful waiting. Can J Oncol. 1994;4(Suppl 1):38-40. [pmid: 8853488].
Polascik TJ, Mayes JM, Mouraviev V. From whole-gland to targeted cryoablation for the treatment of unilateral or focal prostate cancer. Oncology. 2008;22(8):900-6. [pmid: 18709901].
Pontones Moreno, Morera JL, Martínez JF, Vera Donoso CD, Jiménez Cruz JF. Cryosurgery in the management of prostate cancer. Actas Urol Esp. 2007;31(3):211-32. [Spanish]. [pmid: 17658150].
Rassweiler J, Hruza M, Teber D, Su LM. Laparoscopic and robotic assisted radical prostatectomy: critical analysis of the results. Eur Urol. 2006;49(4):612-24. [pmid: 16442210].
Rees J, Patel B, MacDonagh R, Persad R. Cryosurgery for prostate cancer. BJU Int. 2004;93(6):710-4. [pmid: 15049977].
Richie JP. Radical prostatectomy vs watchful waiting in early prostate cancer. BJU Int. 2005;96(7):951-2. [pmid: 16225504].
Robinson JW, Dufour MS, Fung TS. Erectile functioning of men treated for prostate carcinoma. Cancer. 1997;79(3):538-44. [pmid: 9028365].
Robinson JW, Moritz S, Fung T. Meta-analysis of rates of erectile function after treatment of localized prostate carcinoma. Int J Radiat Oncol Biol Phys. 2002;54(4):1063-8. [pmid: 12419432].
Rolland E, Bitker MO, Richard F. Radiation-induced tumours after irradiation for localized prostate cancer: review and proposals for long-term follow-up. Prog Urol. 2007;17(7):1302-4. [French]. [pmid: 18271410].
Seidenfeld J, Samson DJ, Aronson N, et al. Relative effectiveness and cost-effectiveness of methods of androgen suppression in the treatment of advanced prostate cancer. Evid Rep Technol Assess. 1999;4(4):1-246.
Siemens DR. Radical prostatectomy or watchful waiting in early prostate cancer?. Can Med Assoc J. 2003;168(1):67. [pmid: 12515790].
Sosa RE, Martin T, et al. Cryosurgical treatment of prostate cancer: a multicenter review of complication. J Urol. 1996;155(Suppl 5):361A. [pmid: 7490887].
Stanford JL, Stephenson RA, Coyle LM, et al. Prostate Cancer Trends, 1973–1995. NIH Publication No. 99-4543. Bethesda, MD. National Cancer Institute. 1999.
Stark JR, Mucci L, Rothman KJ, Adami HO. Screening for prostate cancer remains controversial. BMJ. 2009;339:b3601. [pmid: 19778971].
Talcott JA. How could getting screened for prostate cancer hurt you?. Urol Oncol. 2005;23(5):374-5. [pmid: 16144676].
Tooher R, Swindle P, Woo H, et al. Laparoscopic radical prostatectomy for localized prostate cancer: a systematic review of comparative studies. J Urol. 2006;175(6):2011-7. [pmid: 16697787].
Touijer K, Guillonneau B. Laparoscopic radical prostatectomy: a critical analysis of surgical quality. Eur Urol. 2006;49(4):625-32. [pmid: 16488072].
Turini M, Redaelli A, Gramegna P, Radice D. Quality of life and economic considerations in the management of prostate cancer. Pharmacoeconomics. 2003;21(8):527-41. [pmid: 12751912].
Twombly R. Preventive Services Task Force recommends against PSA screening after age 75. J Natl Cancer Inst. 2008;100(22):1571-3. [pmid: 19001606].

### Not English-Language but Otherwise Relevant

Liu DY, Tang Q, Wang MW, et al. Prevention of incontinence after radical prostatectomy. Zhonghua Wai Ke Za Zhi. 2006;44(6):369-71. [Chinese]. [pmid: 16638343].
Livi L, Detti B, Meattini M, et al. Organ-confined prostate cancer: treatment with high doses of radioterapy (intensity modulated radiotherapy). Actas Urol Esp. 2007;31(6):611-6. [Spanish]. [pmid: 17896557].
Lu J, Chen ZY, Wang W, et al. Transrectal high-intensity focused ultrasound with the Sonablate 500 for the treatment of prostate cancer. Zhonghua Nan Ke Xue. 2007;13(11):1005-8. [Chinese]. [pmid: 18077913].
Ma LL, Hong K, Huang Y, et al. Improve recovery of urinary continence following laparoscopic radical prostatectomy: a clinical report of 51 cases. Zhonghua Wai Ke Za Zhi. 2008;46(24):1882-4. [Chinese]. [pmid: 19134376].
Mallet F, Wdowczyk D, Bruna A, et al. Feasibility and toxicity of a single fraction high-dose-rate brachytherapy followed by a course of EBRT for localized prostate cancer: a retrospective study—the Polyclinique Courlancy experience. Cancer Radiother. 2010;14(1):11-8. [French]. [pmid: 20005765].
Matzkin H, Mabjeesh N, Stenger A, et al. Brachytherapy combined with external beam radiation in localized prostate cancer. Harefuah. 2006;145(1):8-12. [Hebrew]. [pmid: 16450716].
Norkus D, Valuckas KP, Miller A, et al. A preliminary safety study of hypofractionated radiotherapy for local prostate cancer. Medicina (Kaunas). 2005;41(12):1035-41. [Lithuanian]. [pmid: 16401960].
Otsuki H, Sumitomo M, Umeda S, et al. Transurethral resection of prostate just following high intensity focused ultrasound in localized prostate cancer: trial for early removal of the urethral catheter. Hinyokika Kiyo. 2008;54(3):189-95. [Japanese]. [pmid: 18411774].
Pommier P, Delannes M, LeFloch O, et al. The French preliminary experience of the use of a seed- projector for exclusive iodine 125 prostate brachytherapy: feasibility and acute toxicity. Cancer Radiother. 2006;10(8):559-64. [French]. [pmid: 16959520].

### Duration Too Short (<12 Months Followup)

Gleave ME, Goldenberg SL, Chin JL, et al. Randomized comparative study of 3 versus 8-month neoadjuvant hormonal therapy before radical prostatectomy: biochemical and pathological effects. J Urol. 2001;166(2):500-6. [pmid: 11458055].

### Sample Size Too Small

Downs TM, Sadetsky N, Pasta DJ, et al. Health related quality of life patterns in patients treated with interstitial prostate brachytherapy for localized prostate cancer: data from CaPSURE. J Urol. 2003;170(5):1822-7. [pmid: 14532784].
Jani AB, Gratzle J, Correa D. Influence of intensity-modulated radiotherapy on acute genitourinary and gastrointestinal toxicity in the treatment of localized prostate cancer. Technol Cancer Res Treat. 2007;6(1):11-5. [pmid: 17241095].
Linares LA, Echols D. Amifostine and external beam radiation therapy and/or high-dose rate brachytherapy in the treatment of localized prostate carcinoma: preliminary results of a phase II trial. Semin Oncol. 2003;30(6 Suppl 18):58-62. [pmid: 14727241].
Mabjeesh NJ, Chen J, Stenger A, Matzkin H. Preimplant predictive factors of urinary retention after iodine 125 prostate brachytherapy. Urology. 2007;70(3):548-53. [pmid: 17905113].
Matzkin H, Keren-Paz G, Mabjeesh NJ, Chen J. Combination therapy-permanent interstitial brachytherapy and external beam radiotherapy for patients with localized prostate cancer. Acta Chir Iugosl. 2005;52(4):31-6. [pmid: 16673591].
Mavroidis P, al-Abany M, Helgason AR, et al. Dose-response relations for anal sphincter regarding fecal leakage and blood or phlegm in stools after radiotherapy for prostate cancer: radiobiological study of 65 consecutive patients. Strahlenther Onkol. 2005;181(5):293-306. [pmid: 15900425].
Merrick GS, Butler WM, Wallner KE, et al. Erectile function after prostate brachytherapy. Int J Radiat Oncol Biol Phys. 2005;62(2):437-47. [pmid: 15890585].
Merrick GS, Butler WM, Wallner KE, et al. Late rectal function after prostate brachytherapy. Int J Radiat Oncol Biol Phys. 2003;57(1):42-8. [pmid: 12909214].
Michalski JM, Winter K, Purdy JA, et al. Toxicity after three-dimensional radiotherapy for prostate cancer on RTOG 9406 dose level V. Int J Radiat Oncol Biol Phys. 2005;62(3):706-13. [pmid: 15936549].
Michalski JM, Winter K, Purdy JA, et al. Preliminary evaluation of low-grade toxicity with conformal radiation therapy for prostate cancer on RTOG 9406 dose levels I and II. Int J Radiat Oncol Biol Phys. 2003;56(1):192-8. [pmid: 12694838].
Mishra MV, Shirazi R, Barrett WL. Incidence and clinical course of hemorrhagic radiation proctitis after iodine-125 prostate brachytherapy. Clin Genitourin Cancer. 2007;5(6):397-400. [pmid: 17956713].
Morillo V, Guinot JL, Tortajada I, et al. Secondary effects and biochemical control in patients with early prostate cancer treated with (125)-I seeds. Clin Transl Oncol. 2008;10(6):359-66. [pmid: 18558583].
Muanza TM, Albert PS, Smith S, et al. Comparing measures of acute bowel toxicity in patients with prostate cancer treated with external beam radiation therapy. Int J Radiat Oncol Biol Phys. 2005;62(5):1316-21. [pmid: 16029787].
Muren LP, Karlsdottir A, Kvinnsland Y, et al. Testing the new ICRU 62 “planning organ at risk volume” concept for the rectum. Radiother Oncol. 2005;75(3):293-302. [pmid: 15878630].
Nakamura RA, Monti CR, Castilho LN, et al. Prognostic factors for late urinary toxicity grade 2–3 after conformal radiation therapy on patients with prostate cancer. Int Braz J Urol. 2007;33(5):652-9. [pmid: 17980062].
Neill M, Studer G, Le L, et al. The nature and extent of urinary morbidity in relation to prostate brachytherapy urethral dosimetry. Brachytherapy. 2007;6(3):173-9. [pmid: 17681239].
Nelson CJ, Deveci S, Stasi J, et al. Sexual bother following radical prostatectomy. J Sex Med. 2010;7(1 Pt 1):129-35. [pmid: 20104671].
Noguchi M, Noda S, Nakashima O, et al. Suspension technique improves rapid recovery of urinary continence following radical retropubic prostatectomy. Kurume Med J. 2004;51(3–4):245-51. [pmid: 15682831].
Ohashi T, Yorozu A, Toya K, et al. Predictive factors of acute urinary retention requiring catheterization following 125I prostate brachytherapy. Jpn J Clin Oncol. 2006;36(5):285-9. [pmid: 16698803].
Ohashi T, Yorozu A, Toya K, et al. Serial changes of international prostate symptom score following I-125 prostate brachytherapy. Int J Clin Oncol. 2006;11(4):320-5. [pmid: 16937307].
Ohashi T, Yorozu A, Toya K, et al. Rectal morbidity following I-125 prostate brachytherapy in relation to dosimetry. Jpn J Clin Oncol. 2007;37(2):121-6. [pmid: 17255159].
Pinkawa M, Fischedick K, Asadpour B, et al. Low-grade toxicity after conformal radiation therapy for prostate cancer: impact of bladder volume. Int J Radiat Oncol Biol Phys. 2006;64(3):835-41. [pmid: 16289911].
Pinkawa M, Fischedick K, Asadpour B, et al. Toxicity profile with a large prostate volume after external beam radiotherapy for localized prostate cancer. Int J Radiat Oncol Biol Phys. 2008;70(1):83-9. [pmid: 17855010].
Pinkawa M, Fischedick K, Asadpour B, et al. Health-related quality of life after permanent interstitial brachytherapy for prostate cancer: correlation with postimplant CT scan parameters. Strahlenther Onkol. 2006;182(11):660-5. [pmid: 17072524].
Pinkawa M, Piroth MD, Fischedick K, et al. Impact of the target volume (prostate alone vs. prostate with seminal vesicles) and fraction dose (1.8 Gy vs. 2.0 Gy) on quality of life changes after external-beam radiotherapy for prostate cancer. Strahlenther Onkol. 2009;185(11):724-30. [pmid: 19899005].
Pinkawa M, Piroth MD, Fischedick K, et al. Self-assessed bowel toxicity after external beam radiotherapy for prostate cancer: predictive factors on irritative symptoms, incontinence and rectal bleeding. Radiat Oncol. 2009;4:36. [pmid: 19772568].
Pollack A, Hanlon AL, Horwitz EM, et al. Dosimetry and preliminary acute toxicity in the first 100 men treated for prostate cancer on a randomized hypofractionation dose escalation trial. Int J Radiat Oncol Biol Phys. 2006;64(2):518-26. [pmid: 16242256].
Ponholzer A, Oismüller R, Somay C, et al. The effect on erectile function of 103 palladium implantation for localized prostate cancer. BJU Int. 2005;95(6):847-50. [pmid: 15794796].
Rapiti E, Fioretta G, Verkooijen HM, et al. Increased risk of colon cancer after external radiation therapy for prostate cancer. Int J Cancer. 2008;123(5):1141-5. [pmid: 18546265].
Remzi M, Klingler HC, Tinzl MV, et al. Morbidity of laparoscopic extraperitoneal versus transperitoneal radical prostatectomy verus open retropubic radical prostatectomy. Eur Urol. 2005;48(1):83-9. [pmid: 15967256].
Roach M 3rd, Weinberg V, McLaughlin PW, et al. Serum prostate-specific antigen and survival after external beam radiotherapy for carcinoma of the prostate. Urology. 2003;61(4):730-5. [pmid: 12670556].
Salomon L, Levrel O, Anastasiadis AG, et al. Outcome and complications of radical prostatectomy in patients with PSA <10 ng/mL: comparison between the retropubic, perineal and laparoscopic approach. Prostate Cancer Prostatic Dis. 2002;5(4):285-90. [pmid: 12627213].
Shikanov SA, Eng MK, Bernstein AJ, et al. Urinary and sexual quality of life 1 year following robotic assisted laparoscopic radical prostatectomy. J Urol. 2008;180(2):663-7. [pmid: 18554650].

### Tumor Stage Unclear or Not Reported (for >15% of Population)

Abe T, Shinohara N, Harabayashi T, et al. Postoperative inguinal hernia after radical prostatectomy for prostate cancer. Urology. 2007;69(2):326-9. [pmid: 17275071].
Adolfsson J, Helgason AR, Dickman P, Steineck G. Urinary and bowel symptoms in men with and without prostate cancer: results from an observational study in the Stockholm area. Eur Urol. 1998;33(1):11-6. [pmid: 9471035].
Alibhai SM, Duong-Hua M, Cheung AM, et al. Fracture types and risk factors in men with prostate cancer on androgen deprivation therapy: a matched cohort study of 19,079 men. J Urol. 2010;184(3):918-23. [pmid: 20643458].
Alibhai SM, Duong-Hua M, Sutradhar R, et al. Impact of androgen deprivation therapy on cardiovascular disease and diabetes. J Clin Oncol. 2009;27(21):3452-8. [pmid: 19506162].
Alibhai SM, Leach M, Tomlinson G. Examining the location and cause of death within 30 days of radical prostatectomy. BJU Int. 2005;95(4):541-4. [pmid: 15705076].
Alibhai SM, Leach M, Tomlinson G, et al. Rethinking 30-day mortality risk after radical prostatectomy. Urology. 2006;68(5):1057-60. [pmid: 17113897].
Alibhai SM, Leach M, Warde P. Major 30-day complications after radical radiotherapy: a population-based analysis and comparison with surgery. Cancer. 2009;115(2):293-302. [pmid: 19025976].
Almeida OP, Waterreus A, Spry N, et al. One year follow-up study of the association between chemical castration, sex hormones, beta-amyloid, memory and depression in men. Psychoneuroendocrinology. 2004;29(8):1071-81. [pmid: 15219659].
Anast JW, Sadetsky N, Pasta DJ, et al. The impact of obesity on health related quality of life before and after radical prostatectomy (data from CaPSURE). J Urol. 2005;173(4):1132-8. [pmid: 15758721].
Anderson JF, Swanson DA, Levy LB, et al. Urinary side effects and complications after permanent prostate brachytherapy: the MD Anderson Cancer Center experience. Urology. 2009;74(3):601-5. [pmid: 19589580].
Aoki M, Miki K, Sasaki H, et al. Evaluation of rectal bleeding factors associated with prostate brachytherapy. Jpn J Radiol. 2009;27(10):444-9. [pmid: 20035417].
Augustin H, Pummer K, Daghofer F, et al. Patient self-reporting questionnaire on urological morbidity and bother after radical retropubic prostatectomy. Eur Urol. 2002;42(2):112-7. [pmid: 12160580].
Barker J Jr, Wallner K, Merrick G. Gross hematuria after prostate brachytherapy. Urology. 2003;61(2):408-11. [pmid: 12597957].
Barnas JL, Pierpaoli S, Ladd P, et al. The prevalence and nature of orgasmic dysfunction after radical prostatectomy. BJU Int. 2004;94(4):603-5. [pmid: 15329121].
Bernat MM, Pasini J, Mareković Z. Changes in bone mineral density in patients with prostate cancer treated with androgen deprivation therapy. Coll Antropol. 2005;29(2):589-91. [pmid: 16417166].
Bhojani N, Capitanio U, Suardi N, et al. The rate of secondary malignancies after radical prostatectomy versus external beam radiation therapy for localized prostate cancer: a population-based study on 17,845 patients. Int J Radiat Oncol Biol Phys. 2010;76(2):342-8. [pmid: 20117287].
Blana A, Rogenhofer S, Ganzer R, et al. Morbidity associated with repeated transrectal high-intensity focused ultrasound treatment of localized prostate cancer. World J Urol. 2006;24(5):585-90. [pmid: 16850340].
Bruder JM, Ma JZ, Basler JW, Welch MD. Prevalence of osteopenia and osteoporosis by central and peripheral bone mineral density in men with prostate cancer during androgen-deprivation therapy. Urology. 2006;67(1):152-5. [pmid: 16413352].
Bues M, Holupka EJ, Meskell P, Kaplan ID. Effect of random seed placement error in permanent transperineal prostate seed implant. Radiother Oncol. 2006;79(1):70-4. [pmid: 16515813].
Challacombe BJ, Murphy DG, Zakri R, Cahill DJ. High-intensity focused ultrasound for localized prostate cancer: initial experience with a 2-year follow-up. BJU Int. 2009;104(2):200-4. [pmid: 19220245].
Chen QS, Blair HF. Thyroid uptake of 125iodine after prostate permanent brachytherapy. J Urol. 2004;172(5 Pt 1):1827-9. [pmid: 15540731].
Cherrier MM, Rose AL, Higano C. The effects of combined androgen blockade on cognitive function during the first cycle of intermittent androgen suppression in patients with prostate cancer. J Urol. 2003;170(5):1808-11. [pmid: 14532781].
Chu FM, Jayson M, Dineen MK, et al. A clinical study of 22.5 mg La-2550: a new subcutaneous depot delivery system for leuprolide acetate for the treatment of prostate cancer. J Urol. 2002;168(3):1199-203. [pmid: 12187267].
Cox R, Crawford ED. Complications of cryosurgical ablation of the prostate to treat localized adenocarcinoma of the prostate. Urology. 1995;45(6):932-5. [pmid: 7771025].
Cozzarini C, Fiorino C, Di Muzio N, et al. Significant reduction of acute toxicity following pelvic irradiation with helical tomotherapy in patients with localized prostate cancer. Radiother Oncol. 2007;84(2):164-70. [pmid: 17706308].
Dacal K, Sereika SM, Greenspan SL. Quality of life in prostate cancer patients taking androgen deprivation therapy. J Am Geriatr Soc. 2006;54(1):85-90. [pmid: 16420202].
Deger S, Boehmer D, Türk I, et al. Interstitial hyperthermia using self-regulating thermoseeds combined with conformal radiation therapy. Eur Urol. 2002;42(2):147-53. [pmid: 12160585].
Deng JH, Yang LP, Wang LS, Zhou DF. Effect of androgen deprivation therapy on bone mineral density in prostate cancer patients. Asian J Androl. 2004;6(1):75-7. [pmid: 15064839].
DiBlasio CJ, Hammett J, Malcom JB, et al. Prevalence and predictive factors for the development of de novo psychiatric illness in patients receiving androgen deprivation therapy for prostate cancer. Can J Urol. 2008;15(5):4249-56. [pmid: 18814813].
Efstathiou JA, Bae K, Shipley WU, et al. Cardiovascular mortality after androgen deprivation therapy for locally advanced prostate cancer: RTOG 85-31. J Clin Oncol. 2009;27(1):92-9. [pmid: 19047297].
Ellis DS. Cryosurgery as primary treatment for localized prostate cancer: a community hospital experience. Urology. 2002;60(2 Suppl 1):34-9. [pmid: 12206846].
Ellis RJ, Zhou H, Kaminsky DA, et al. Rectal morbidity after permanent prostate brachytherapy with dose escalation to biologic target volumes identified by SPECT/CT fusion. Brachytherapy. 2007;6(2):149-56. [pmid: 17434109].
Fellin G, Fiorino C, Rancati T, et al. Clinical and dosimetric predictors of late rectal toxicity after conformal radiation for localized prostate cancer: results of a large multicenter observational study. Radiother Oncol. 2009;93(2):197-202. [pmid: 19828205].
Ficarra V, Novara G, Artibani RW, et al. Retropubic, laparoscopic, and robot-assisted radical prostatectomy: a systematic review and cumulative analysis of comparative studies. Eur Urol. 2009;55(5):1037-63. [pmid: 19185977].
Ficarra V, Novara G, Galfano A, et al. Twelve-month self-reported quality of life after retropubic radical prostatectomy: a prospective study with Rand 36-Item Health Survey (Short Form-36). BJU Int. 2006;97(2):274-8. [pmid: 16430628].
Fiorino C, Fellin G, Rancati T, et al. Clinical and dosimetric predictors of late rectal syndrome after 3D- CRT for localized prostate cancer: preliminary results of a multicenter prospective study. Int J Radiat Oncol Biol Phys. 2008;70(4):1130-7. [pmid: 17881142].
Fowler FJ Jr, McNaughton Collins M, Walker Corkery E, et al. The impact of androgen deprivation on quality of life after radical prostatectomy for prostate carcinoma. Cancer. 2002;95(2):287-95. [pmid: 12124828].
Frank SJ, Pisters LL, Davis J, et al. An assessment of quality of life following radical prostatectomy, high dose external beam radiation therapy and brachytherapy iodine implantation as monotherapies for localized prostate cancer. J Urol. 2007;177(6):2151-6. [pmid: 17509305].
Galli S, Simonato A, Bozzola A, et al. Oncologic outcome and continence recovery after laparoscopic radical prostatectomy: 3 years’ follow-up in a “second generation center.”. Eur Urol. 2006;49(5):859-65. [pmid: 16519991].
Galvão DA, Taaffe DR, Spry N, et al. Reduced muscle strength and functional performance in men with prostate cancer undergoing androgen suppression: a comprehensive cross-sectional investigation. Prostate Cancer Prostatic Dis. 2009;12(2):198-203. [pmid: 18852703].
Ghaly M, Wallner K, Merrick G, et al. The effect of supplemental beam radiation on prostate brachytherapy-related morbidity: morbidity outcomes from two prospective randomized multicenter trials. Int J Radiat Oncol Biol Phys. 2003;55(5):1288-93. [pmid: 12654439].
Greenspan SL, Coates P, Sereika SM, et al. Bone loss after initiation of androgen deprivation therapy in patients with prostate cancer. J Clin Endocrinol Metab. 2005;90(12):6410-7. [pmid: 16189261].
Guay A, Seftel AD. Sexual foreplay incontinence in men with erectile dysfunction after radical prostatectomy: a clinical observation. Int J Impot Res. 2008;20(2):199-201. [pmid: 18200019].
Hammadeh MY, Madaan S, Hines J, Philp T. 5-year outcome of a prospective randomized trial to compare transurethral electrovaporization of the prostate and standard transurethral resection. Urology. 2003;61(6):1166-71. [pmid: 12809891].
Hanssen S, Norum J. Bladder and rectal toxicity of BeamCath application in radiotherapy of prostate cancer. Anticancer Res. 2008;28(5B):2865-8. [pmid: 19031926].
Harris MJ. Radical perineal prostatectomy: cost efficient, outcome effective, minimally invasive prostate cancer management. Eur Urol. 2003;44(3):303-8. [pmid: 12932927].
Helgason AR, Adolfsson J, Dickman P, et al. Waning sexual function—the most important disease-specific distress for patients with prostate cancer. Br J Cancer. 1996;73(11):1417-21. [pmid: 8645589].
Hodzic J, Jedrusik P, Reckwitz T, et al. Impact of preoperative antiandrogen medication and nerve-sparing surgery on the outcome of radical prostatectomy. Int Urol Nephrol. 2008;40(4):965-70. [pmid: 18401689].
Hoffelt SC, Wallner K, Merrick G. Epididymitis after prostate brachytherapy. Urology. 2004;63(2):293-6. [pmid: 14972474].
Hoffman RM, Barry MJ, Stanford JL, et al. Health outcomes in older men with localized prostate cancer: results from the Prostate Cancer Outcomes Study. Am J Med. 2006;119(5):418-25. [pmid: 16651054].
Hofmann T, Gaensheimer S, Buchner A, et al. An unrandomized prospective comparison of urinary continence, bowel symptoms and the need for further procedures in patients with and with no adjuvant radiation after radical prostatectomy. BJU Int. 2003;92(4):360-4. [pmid: 12930419].
Hollenbeck BK, Dunn RL, Wei JT, et al. Determinants of long-term sexual health outcome after radical prostatectomy measured by a validated instrument. J Urol. 2003;169(4):1453-7. [pmid: 12629382].
Hopfgarten T, Adolfsson J, Henningsohn L, et al. The choice between a therapy-induced long-term symptom and shortened survival due to prostate cancer. Eur Urol. 2006;50(2):280-9. [pmid: 16457946].
Hu JC, Gold KF, Pashos CL, et al. Role of surgeon volume in radical prostatectomy outcomes. J Clin Oncol. 2003;21(3):401-5. [pmid: 12560426].
Hu JC, Wang Q, Pashos CL, et al. Utilization and outcomes of minimally invasive radical prostatectomy. J Clin Oncol. 2008;26(14):2278-84. [pmid: 18467718].
Irani J, Celhay O, Hubert J, et al. Continuous versus six months a year maximal androgen blockade in the management of prostate cancer: a randomised study. Eur Urol. 2008;54(2):382-91. [pmid: 18339475].
Jones JS, Rewcastle JC, Donnelly BJ, et al. Whole gland primary prostate cryoablation: initial results from the cryo on-line data registry. J Urol. 2008;180(2):554-8. [pmid: 18550117].
Judge A, Evans S, Gunnell DJ, et al. Patient outcomes and length of hospital stay after radical prostatectomy for prostate cancer: analysis of hospital episodes statistics for England. BJU Int. 2007;100(5):1040-9. [pmid: 17784890].
Jung C, Cookson MS, Chang SS, et al. Toxicity following high-dose salvage radiotherapy after radical prostatectomy. BJU Int. 2007;99(3):529-33. [pmid: 17155969].
Kakehi Y, Takegami M, Suzukamo Y, et al. Health related quality of life in Japanese men with localized prostate cancer treated with current multiple modalities assessed by a newly developed Japanese version of the Expanded Prostate Cancer Index Composite. J Urol. 2007;177(5):1856-61. [pmid: 17437836].
Karakiewicz PI, Bhojani N, Neugut A, et al. The effect of comorbidity and socioeconomic status on sexual and urinary function and on general health-related quality of life in men treated with radical prostatectomy for localized prostate cancer. J Sex Med. 2008;5(4):919-27. [pmid: 18371045].
Karakiewicz PI, Tanguay S, Kattan MW, et al. Erectile and urinary dysfunction after radical prostatectomy for prostate cancer in Quebec: a population-based study of 2415 men. Eur Urol. 2004;46(2):188-94. [pmid: 15245812].
Katz G, Rodriguez R. Changes in continence and health-related quality of life after curative treatment and watchful waiting of prostate cancer. Urology. 2007;69(6):1157-60. [pmid: 17572206].
Katz R, Salomon L, Hoznek A, et al. Patient reported sexual function following laparoscopic radical prostatectomy. J Urol. 2002;168(5):2078-82. [pmid: 12394713].
Keating NL, O’Malley AJ, Freedland SJ, Smith MR. Diabetes and cardiovascular disease during androgen deprivation therapy: observational study of veterans with prostate cancer. J Natl Cancer Inst. 2010;102(1):39-46. [pmid: 19996060].
Korman HJ, Mulholland TL, Huang R. Preservation of fecal continence and bowel function after radical perineal and retropubic prostatectomy: a questionnaire-based outcomes study. Prostate Cancer Prostatic Dis. 2004;7(3):249-52. [pmid: 15249929].
Krahn M, Ritvo P, Irvine J, et al. Patient and community preferences for outcomes in prostate cancer: implications for clinical policy. Med Care. 2003;41(1):153-64. [pmid: 12544552].
Krupski TL, Smith MR, Lee WC, et al. Natural history of bone complications in men with prostate carcinoma initiating androgen deprivation therapy. Cancer. 2004;101(3):541-9. [pmid: 15274067].
Kupelian PA, Reddy CA, Carlson TP, Willoughby TR. Dose/volume relationship of late rectal bleeding after external beam radiotherapy for localized prostate cancer: absolute or relative rectal volume?. Cancer J. 2002;8(1):62-6. [pmid: 11895204].
Lage MJ, Barber BL, Markus RA. Association between androgen-deprivation therapy and incidence of diabetes among males with prostate cancer. Urology. 2007;70(6):1104-8. [pmid: 18158027].
Landis D, Wallner K, Locke J, et al. Late urinary function after prostate brachytherapy. Brachytherapy. 2002;1(1):21-6. [pmid: 15062183].
Lee H, McGovern K, Finklestein JS, Smith MR. Changes in bone mineral density and body composition during initial and long-term gonadotropin-releasing hormone agonist treatment for prostate carcinoma. Cancer. 2005;104(8):1633-7. [pmid: 16116596].
Lee HK, Adams MT, Shi Q, et al. Seed implant retention score predicts the risk of prolonged urinary retention after prostate brachytherapy. Int J Radiat Oncol Biol Phys. 2010;76(5):1445-9. [pmid: 19553032].
Levinson AW, Bagga HS, Pavlovich CP, et al. The impact of prostate size on urinary quality of life indexes following laparoscopic radical prostatectomy. J Urol. 2008;179(5):1818-22. [pmid: 18353375].
Liatsikos E, Mühlstädt S, Kallidonis P, et al. Performance and functional outcome of endoscopic extraperitoneal radical prostatectomy in relation to obesity: an assessment of 500 patients. BJU Int. 2008;102(6):718-22. [pmid: 18422768].
Livsey JE, Routledge J, Burns M, et al. Scoring of treatment-related late effects in prostate cancer. Radiother Oncol. 2002;65(2):109-21. [pmid: 12443807].
López AM, Pena MA, Hernández R, et al. Fracture risk in patients with prostate cancer on androgen deprivation therapy. Osteoporos Int. 2005;16(6):707-11. [pmid: 15714259].
McCammon KA, Kolm P, Main B, Schellhammer PF. Comparative quality-of-life analysis after radical prostatectomy or external beam radiation for localized prostate cancer. Urology. 1999;54(3):509-16. [pmid: 10475363].
Moinpour CM, Hayden KA, Unger JM, et al. Health-related quality of life results in pathologic stage C prostate cancer from a Southwest Oncology Group trial comparing radical prostatectomy alone with radical prostatectomy plus radiation therapy. J Clin Oncol. 2008;26(1):112-20. [pmid: 18165645].
Prezioso D, Bartoletti R, Cecchi M, et al. Quality of life evaluation by the EORTC QLQ-C30 questionnaire in patients treated with hormonal treatment in Italy: a QuABIOS Group study. Arch Ital Urol Androl. 2007;79(3):99-103. [pmid: 18041358].
Prezioso D, Pappagallo GL, Guazzoni G, et al. Hormonal treatment for prostate cancer in Italy: preliminary data from a survey of the QuABIOS Group. Arch Ital Urol Androl. 2006;78(1):15-9. [pmid: 16752882].
Rodgers JK, Sawhney R, Chaudhary U, Bissada NK. Quality of life in men with localized prostate cancer treated by radical prostatectomy or radiotherapy. Arch Androl. 2006;52(2):129-33. [pmid: 16443590].
Saigal CS, Gore JL, Krupski TL, et al. Androgen deprivation therapy increases cardiovascular morbidity in men with prostate cancer. Cancer. 2007;110(7):1493-500. [pmid: 17657815].
Smith MR. Changes in fat and lean body mass during androgen-deprivation therapy for prostate cancer. Urology. 2004;63(4):742-5. [pmid: 15072892].
Smith MR, Lee WC, Brandman J, et al. Gonadotropin-releasing hormone agonists and fracture risk: a claims-based cohort study of men with nonmetastatic prostate cancer. J Clin Oncol. 2005;23(31):7897-903. [pmid: 16258089].

### No Watchful Waiting Arm

Abdalla I, Ignacio L, Vaida F, et al. Evolution of toxicity after conformal radiotherapy for prostate cancer. Prostate Cancer Prostatic Dis. 2002;5(4):296-303. [pmid: 12627215].
Ahmed HU, Zacharakis E, Dudderidge T, et al. High-intensity-focused ultrasound in the treatment of primary prostate cancer: the first UK series. Br J Cancer. 2009;101(1):19-26. [pmid: 19513068].
Albers P, Schäfers S, Löhmer H, de Geeter P. Seminal vesicle-sparing perineal radical prostatectomy improves early functional results in patients with low-risk prostate cancer. BJU Int. 2007;100(5):1050-4. [pmid: 17760889].
Albert M, Tempany CM, Schultz D, et al. Late genitourinary and gastrointestinal toxicity after magnetic resonance image-guided prostate brachytherapy with or without neoadjuvant external beam radiation therapy. Cancer. 2003;98(5):949-54. [pmid: 12942561].
Ayyathurai R, Manoharan M, Nieder AM, et al. Factors affecting erectile function after radical retropubic prostatectomy: results from 1620 consecutive patients. BJU Int. 2008;101(7):833-6. [pmid: 18190627].
Badani KK, Kaul S, Menon M. Evolution of robotic radical prostatectomy: assessment after 2766 procedures. Cancer. 2007;110(9):1951-8. [pmid: 17893904].
Ball AJ, Gambill B, Fabrizio MD, et al. Prospective longitudinal comparative study of early health-related quality-of-life outcomes in patients undergoing surgical treatment for localized prostate cancer: a short-term evaluation of five approaches from a single institution. J Endourol. 2006;20(10):723-31. [pmid: 17094746].
Bergman J, Kwan L, Litwin MS. Improving decisions for men with prostate cancer: translational outcomes research. J Urol. 2010;183(6):2186-92. [pmid: 20399466].
Bergman J, Saigal CS, Kwan L, Litwin MS. Responsiveness of the University of California-Los Angeles Prostate Cancer Index. Urology. 2010;75(6):1418-23. [pmid: 19589573].
Bradley EB, Bissonette EA, Theodorescu D. Determinants of long-term quality of life and voiding function of patients treated with radical prostatectomy or permanent brachytherapy for prostate cancer. BJU Int. 2004;94(7):1003-9. [pmid: 15541117].
Breyer BN, Davis CB, Cowan JE, et al. Incidence of bladder neck contracture after robot-assisted laparoscopic and open radical prostatectomy. BJU Int. 2010;106(11):1734-8. [pmid: 20438567].
Buron C, Le Vu B, Cosset JM, et al. Brachytherapy versus prostatectomy in localized prostate cancer: results of a French multicenter prospective medico-economic study. Int J Radiat Oncol Biol Phys. 2007;67(3):812-22. [pmid: 17293235].
Cambria R, Jereczek-Fossa BA, Cattani F, et al. Evaluation of late rectal toxicity after conformal radiotherapy for prostate cancer: a comparison between dose-volume constraints and NTCP use. Strahlenther Onkol. 2009;185(6):384-9. [pmid: 19506822].
Castle EP, Atug F, Woods M, et al. Impact of body mass index on outcomes after robot assisted radical prostatectomy. World J Urol. 2008;26(1):91-5. [pmid: 17940773].
Chen AB, D’Amico AV, Neville BA, Earle CC. Patient and treatment factors associated with complications after prostate brachytherapy. J Clin Oncol. 2006;24(33):5298-304. [pmid: 17114664].
Chen MJ, Weltman E, Hanriot RM, et al. Intensity modulated radiotherapy for localized prostate cancer: rigid compliance to dose-volume constraints as a warranty of acceptable toxicity?. Radiat Oncol. 2007;2:6. [pmid: 17224072].
Chen QS, Blair HF. Accurate and efficient detection of pulmonary seed embolization in prostate iodine-125 permanent brachytherapy with a collimated gamma scintillation survey meter. Med Phys. 2003;30(5):785-90. [pmid: 12772985].
Chen RC, Clark JA, Talcott JA. Individualizing quality-of-life outcomes reporting: how localized prostate cancer treatments affect patients with different levels of baseline urinary, bowel, and sexual function. J Clin Oncol. 2009;27(24):3916-22. [pmid: 19620493].
Chun FK, Graefen M, Zacharias M, et al. Anatomic radical retropubic prostatectomy: long-term recurrence-free survival rates for localized prostate cancer. World J Urol. 2006;24(3):273-80. [pmid: 16506049].
Conti PD, Atallah AN, Arruda H, et al. Intermittent versus continuous androgen suppression for prostatic cancer. Cochrane Database Syst Rev. 2007;(4):CD005009. [pmid: 17943832].
Cooperberg MR, Vickers AJ, Broering JM, Carroll PR. Comparative risk-adjusted mortality outcomes after primary surgery, radiotherapy, or androgen-deprivation therapy for localized prostate cancer. Cancer. 2010;116(22):5226-34. [pmid: 20690197].
Corriveau J, Wallner K, Merrick G, et al. Morbidity effect of the time gap between supplemental beam radiation and Pd-103 prostate brachytherapy. Brachytherapy. 2003;2(2):108-13. [pmid: 15062149].
Dalkin BL, Christopher BA. Potent men undergoing radical prostatectomy: a prospective study measuring sexual health outcomes and the impact of erectile dysfunction treatments. Urol Oncol. 2008;26(3):281-5. [pmid: 18452820].
Dalkin BL, Christopher BA, Shawler D. Health related quality of life outcomes after radical prostatectomy: attention to study design and the patient-based importance of single-surgeon studies. Urol Oncol. 2006;24(1):28-32. [pmid: 16414489].
D’Amico AV, Chen MH, Renshaw AA, et al. Androgen suppression and radiation vs radiation alone for prostate cancer: a randomized trial. JAMA. 2008;299(3):289-95. [pmid: 18212313].
D’Amico AV, Cote K, Loffredo M, et al. Determinants of prostate cancer-specific survival after radiation therapy for patients with clinically localized prostate cancer. J Clin Oncol. 2002;20(23):4567-73. [pmid: 12454114].
D’Amico AV, Denham JW, Crook J, et al. Influence of androgen suppression therapy for prostate cancer on the frequency and timing of fatal myocardial infarctions. J Clin Oncol. 2007;25(17):2420-5. [pmid: 17557956].
D’Amico AV, Moran BJ, Braccioforte MH, et al. Risk of death from prostate cancer after brachytherapy alone or with radiation, androgen suppression therapy, or both in men with high-risk disease. J Clin Oncol. 2009;27(24):3923-8. [pmid: 19597029].
D’Amico AV, Moul J, Carroll PR, et al. Cancer-specific mortality after surgery or radiation for patients with clinically localized prostate cancer managed during the prostate-specific antigen era. J Clin Oncol. 2003;21(11):2163-72. [pmid: 12775742].
D’Amico AV, Renshaw AA, Sussman B, Chen MH. Pretreatment PSA velocity and risk of death from prostate cancer following external beam radiation therapy. JAMA. 2005;294(4):440-7. [pmid: 16046650].
Danjoux C, Gardner S, Fitch M. Prospective evaluation of fatigue during a course of curative radiotherapy for localised prostate cancer. Support Care Cancer. 2007;15(10):1169-76. [pmid: 17333296].
Davis JW, Chang DW, Chevray P, et al. Randomized phase II trial evaluation of erectile function after attempted unilateral cavernous nerve-sparing retropubic radical prostatectomy with versus without unilateral sural nerve grafting for clinically localized prostate cancer. Eur Urol. 2009;55(5):1135-43. [pmid: 18783876].
Deliveliotis C, Liakouras C, Delis A, et al. Prostate operations: long-term effects on sexual and urinary function and quality of life—comparison with an age-matched control population. Urol Res. 2004;32(4):283-9. [pmid: 15057494].
Deliveliotis C, Protogerou V, Alargof E, Varkarakis J. Radical prostatectomy: bladder neck preservation and puboprostatic ligament sparing: effects on continence and positive margins. Urology. 2002;60(5):855-8. [pmid: 12429315].
Descazeaud A, Zerbib M, Hofer MD, et al. Evolution of health-related quality of life two to seven years after retropubic radical prostatectomy: evaluation by UCLA Prostate Cancer Index. World J Urol. 2005;23(4):257-62. [pmid: 16136358].
Eade TN, Horwitz EM, Ruth K, et al. A comparison of acute and chronic toxicity for men with low-risk prostate cancer treated with intensity-modulated radiation therapy or (125)I permanent implant. Int J Radiat Oncol Biol Phys. 2008;71(2):338-45. [pmid: 18207665].
Ebara S, Katayama N, Tanimoto R, et al. Iodine-125 seed implantation (permanent brachytherapy) for clinically localized prostate cancer. Acta Med Okayama. 2008;62(1):9-13. [pmid: 18323866].
Ebara S, Manabe D, Kobayashi Y, et al. The efficacy of neoadjuvant androgen deprivation therapy as a prostate volume reduction before brachytherapy for clinically localized prostate cancer. Acta Med Okayama. 2007;61(6):335-40. [pmid: 18183078].
Eden CG, Chang CM, Gianduzzo T, Moon DA. The impact of obesity on laparoscopic radical prostatectomy. BJU Int. 2006;98(6):1279-82. [pmid: 16879436].
Egawa S, Arai Y, Kawakita M, et al. Surgical outcome of laparoscopic radical prostatectomy: summary of early multiinstitutional experience in Japan. Int J Clin Oncol. 2003;8(2):97-103. [pmid: 12720102].
Fan KH, Chen YC, Chuang CK, et al. Preliminary treatment results of intensity-modulated radiotherapy for prostate cancer. Chang Gung Med J. 2006;29(3):313-24. [pmid: 16924894].
Fan KH, Chen YC, Chuang CK, et al. Adjuvant androgen deprivation therapy loses its therapeutic benefit after premature termination: an experience of combined modality treatment on prostate cancer. Chang Gung Med J. 2009;32(5):526-34. [pmid: 19840510].
Fang FM, Wang YM, Wang CJ, et al. Comparison of the outcome and morbidity for localized or locally advanced prostate cancer treated by high-dose-rate brachytherapy plus external beam radiotherapy (EBRT) versus EBRT alone. Jpn J Clin Oncol. 2008;38(7):474-9. [pmid: 18621848].
Ferrer M, Suárez JF, Guedea F, et al. Health-related quality of life 2 years after treatment with radical prostatectomy, prostate brachytherapy, or external beam radiotherapy in patients with clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. 2008;72(2):421-32. [pmid: 18325680].
Ficarra V, Novara G, Fracalanza S, et al. A prospective, non-randomized trial comparing robot-assisted laparoscopic and retropubic radical prostatectomy in one European institution. BJU Int. 2009;104(4):534-9. [pmid: 19281468].
Fowler FJ Jr, Barry MJ, Lu-Yao G, et al. Outcomes of external-beam radiation therapy for prostate cancer: a study of Medicare beneficiaries in three Surveillance, Epidemiology, and End Results areas. J Clin Oncol. 1996;14(8):2258-65. [pmid: 8708715].
Fransson P, Lund JA, Damber JE, et al. Quality of life in patients with locally advanced prostate cancer given endocrine treatment with or without radiotherapy: 4-year follow-up of SPCG-7/SFUO-3, an open-label, randomised, phase III trial. Lancet Oncol. 2009;10(4):370-80. [pmid: 19286422].
Gontero P, Fontana F, Bagnasacco A, et al. Is there an optimal time for intracavernous prostaglandin E1 rehabilitation following nonnerve sparing radical prostatectomy? Results from a hemodynamic prospective study. J Urol. 2003;169(6):2166-9. [pmid: 12771740].
Gore JL, Kwan L, Lee SP, et al. Survivorship beyond convalescence: 48-month quality-of-life outcomes after treatment for localized prostate cancer. J Natl Cancer Inst. 2009;101(12):888-92. [pmid: 19509365].
Gould RS. Total cryosurgery of the prostate versus standard cryosurgery versus radical prostatectomy: comparison of early results and the role of transurethral resection in cryosurgery. J Urol. 1999;162:1653-7. [pmid: 10524891].
Guedea F, Ferrer M, Pera J, et al. Quality of life two years after radical prostatectomy, prostate brachytherapy or external beam radiotherapy for clinically localised prostate cancer: the Catalan Institute of Oncology/Bellvitge Hospital experience. Clin Transl Oncol. 2009;11(7):470-8. [pmid: 19574206].
Hashine K, Azuma K, Koizumi T, Sumiyoshi Y. Health-related quality of life and treatment outcomes for men with prostate cancer treated by combined external-beam radiotherapy and hormone therapy. Int J Clin Oncol. 2005;10(1):45-50. [pmid: 15729601].
Hashine K, Kusuhara Y, Miura N, et al. A prospective longitudinal study comparing a radical retropubic prostatectomy and permanent prostate brachytherapy regarding the health-related quality of life for localized prostate cancer. Jpn J Clin Oncol. 2008;38(7):480-5. [pmid: 18621847].
Herstein A, Wallner K, Merrick G, et al. I-125 versus Pd-103 for low-risk prostate cancer: long-term morbidity outcomes from a prospective randomized multicenter controlled trial. Cancer J. 2005;11(5):385-9. [pmid: 16259869].
Holmström B, Holmberg E, Egevad L, et al. Outcome of primary versus deferred radical prostatectomy in the National Prostate Cancer Register of Sweden Follow-Up Study. J Urol. 2010;184(4):1322-7. [pmid: 20723940].
Jayadevappa R, Chhatre S, Whittington R, et al. Health-related quality of life and satisfaction with care among older men treated for prostate cancer with either radical prostatectomy or external beam radiation therapy. BJU Int. 2006;97(5):955-62. [pmid: 16643477].
Karlsdóttir A, Johannessen DC, Muren LP, et al. Acute morbidity related to treatment volume during 3D-conformal radiation therapy for prostate cancer. Radiother Oncol. 2004;71(1):43-53. [pmid: 15066295].
Karlsdóttir A, Muren LP, Wentzel-Larsen T, Dahl O. Late gastrointestinal morbidity after three-dimensional conformal radiation therapy for prostate cancer fades with time in contrast to genitourinary morbidity. Int J Radiat Oncol Biol Phys. 2008;70(5):1478-86. [pmid: 18060703].
Keating NL, O’Malley AJ, Smith MR. Diabetes and cardiovascular disease during androgen deprivation therapy for prostate cancer. J Clin Oncol. 2006;24(27):4448-56. [pmid: 16983113].
Keiler L, Dobbins D, Kulasekere R, Einstein D. Tomotherapy for prostate adenocarcinoma: a report on acute toxicity. Radiother Oncol. 2007;84(2):171-6. [pmid: 17692975].
Klevecka V, Burmester L, Musch M, et al. Intraoperative and early postoperative complications of radical retropubic prostatectomy. Urol Int. 2007;79(3):217-25. [pmid: 17940353].
Kobuke M, Saika T, Nakanishi Y, et al. Prospective longitudinal comparative study of health-related quality of life in patients treated with radical prostatectomy or permanent brachytherapy for prostate cancer. Acta Med Okayama. 2009;63(3):129-35. [pmid: 19571899].
Krahn MD, Bremner KE, Tomlinson G, Naglie G. Utility and health-related quality of life in prostate cancer patients 12 months after radical prostatectomy or radiation therapy. Prostate Cancer Prostatic Dis. 2009;12(4):361-8. [pmid: 19901935].
Krupski T, Bissonette EA, Petroni GR, Theodorescu D. The impact of prostate volume following neoadjuvant androgen deprivation on quality of life and voiding symptoms in patients undergoing permanent prostate brachytherapy. Eur Urol. 2003;43(5):467-72. [pmid: 12705988].
Kundu SD, Roehl KA, Eggener SE, et al. Potency, continence and complications in 3,477 consecutive radical retropubic prostatectomies. J Urol. 2004;172(6 Pt 1):2227-31. [pmid: 15538237].
Kunos CA, Resnick MI, Kinsella TJ, Ellis RJ. Migration of implanted free radioactive seeds for adenocarcinoma of the prostate using a Mick applicator. Brachytherapy. 2004;3(2):71-7. [pmid: 15374538].
Lee CM, Lee RJ, Handrahan DL, Sause WT. Comparison of late rectal toxicity from conventional versus three-dimensional conformal radiotherapy for prostate cancer: analysis of clinical and dosimetric factors. Urology. 2005;65(1):114-9. [pmid: 15667875].
Lee WR, Hall MC, McQuellon RP, et al. A prospective quality-of-life study in men with clinically localized prostate carcinoma treated with radical prostatectomy, external beam radiotherapy, or interstitial brachytherapy. Int J Radiat Oncol Biol Phys. 2001;51(3):614-23. [pmid: 11597800].
Lev EL, Eller LS, Gejerman G, et al. Quality of life of men treated for localized prostate cancer: outcomes at 6 and 12 months. Support Care Cancer. 2009;17(5):509-17. [pmid: 18719947].
Lev EL, Eller LS, Gejerman G, et al. Quality of life of men treated with brachytherapies for prostate cancer. Health Qual Life Outcomes. 2004;2:28. [pmid: 15198803].
Liauw SL, Sylvester JE, Morris CG, et al. Second malignancies after prostate brachytherapy: incidence of bladder and colorectal cancers in patients with 15 years of potential follow-up. Int J Radiat Oncol Biol Phys. 2006;66(3):669-73. [pmid: 16887293].
Litwin MS, Flanders SC, Pasta DJ, et al. Sexual function and bother after radical prostatectomy or radiation for prostate cancer: multivariate quality-of-life analysis from CaPSURE. Urology. 1999;54(3):503-8. [pmid: 10475362].
Litwin MS, Gore JL, Kwan L, et al. Quality of life after surgery, external beam irradiation, or brachytherapy for early-stage prostate cancer. Cancer. 2007;109(11):2239-47. [pmid: 17455209].
Litwin MS, Sadetsky N, Pasta DJ, Lubeck DP. Bowel function and bother after treatment for early stage prostate cancer: a longitudinal quality of life analysis from CaPSURE. J Urol. 2004;172(2):515-9. [pmid: 15247718].
Lukka H, Hayter C, Julian JA, et al. Randomized trial comparing two fractionation schedules for patients with localized prostate cancer. J Clin Oncol. 2005;23(25):6132-8. [pmid: 16135479].
Martis G, Diana M, Ombres M, et al. Retropubic versus perineal radical prostatectomy in early prostate cancer: eight-year experience. J Surg Oncol. 2007;95(6):513-8. [pmid: 17226809].
Matzinger O, Duclos F, van den Bergh A, et al. Acute toxicity of curative radiotherapy for intermediate- and high-risk localised prostate cancer in the EORTC trial 22991. Eur J Cancer. 2009;45(16):2825-34. [pmid: 19682889].
Matzkin H, Kaver I, Stenger A, et al. Iodine-125 brachytherapy for localized prostate cancer and urinary morbidity: a prospective comparison of two seed implant methods-preplanning and intraoperative planning. Urology. 2003;62(3):497-502. [pmid: 12946754].
May M, Dorst M, May J, et al. Radical retropubic vs. radical perineal prostatectomy: a comparison of relative benefits in four urban hospitals. Urol Nurs. 2007;27(6):519-26. [pmid: 18217535].
Merrick GS, Butler WM, Wallner KE, et al. Monotherapeutic brachytherapy for clinically organ-confined prostate cancer. W V Med J. 2005;101(4):168-71. [pmid: 16296198].
Merrick GS, Butler WM, Wallner KE, et al. Rectal function following brachytherapy with or without supplemental external beam radiation: results of two prospective randomized trials. Brachytherapy. 2003;2(3):147-57. [pmid: 15062137].
Merrick GS, Butler WM, Wallner KE, et al. Prophylactic versus therapeutic alpha-blockers after permanent prostate brachytherapy. Urology. 2002;60(4):650-5. [pmid: 12385927].
Michalski JM, Winter K, Purdy JA, et al. Toxicity after three-dimensional radiotherapy for prostate cancer with RTOG 9406 dose level IV. Int J Radiat Oncol Biol Phys. 2004;58(3):735-42. [pmid: 14967428].
Miller DC, Sanda MG, Dunn RL, et al. Long-term outcomes among localized prostate cancer survivors: health-related quality-of-life changes after radical prostatectomy, external radiation, and brachytherapy. J Clin Oncol. 2005;23(12):2772-80. [pmid: 15837992].
Miller NL, Bissonette EA, Bahnson R, et al. Impact of a novel neoadjuvant and adjuvant hormone-deprivation approach on quality of life, voiding function, and sexual function after prostate brachytherapy. Cancer. 2003;97(5):1203-10. [pmid: 12599226].
Mols F, Stijns P, Dankaart B, et al. Health-related quality of life in I-125 prostate brachytherapy patients treated with and without volume-reducing hormone therapy: results of a short-term prospective study. J Endourol. 2009;23(1):153-9. [pmid: 19118465].
Mueller A, Wallner K, Merrick G, et al. Perirectal seeds as a risk factor for prostate brachytherapy-related rectal bleeding. Int J Radiat Oncol Biol Phys. 2004;59(4):1047-52. [pmid: 15234038].
Namiki S, Ishidoya S, Ito A, et al. Quality of life after radical prostatectomy in Japanese men: a 5-year follow up study. Int J Urol. 2009;16(1):75-81. [pmid: 19054169].
Namiki S, Ishidoya S, Ito A, et al. Five-year follow-up of health-related quality of life after intensity-modulated radiation therapy for prostate cancer. Jpn J Clin Oncol. 2009;39(11):732-8. [pmid: 19666904].
Namiki S, Ishidoya S, Tochigi T, et al. Health-related quality of life after intensity modulated radiation therapy for localized prostate cancer: comparison with conventional and conformal radiotherapy. Jpn J Clin Oncol. 2006;36(4):224-30. [pmid: 16537689].
Namiki S, Satoh T, Baba S, et al. Quality of life after brachytherapy or radical prostatectomy for localized prostate cancer: a prospective longitudinal study. Urology. 2006;68(6):1230-6. [pmid: 17141839].
Nobes JP, Khaksar SJ, Hawkins MA, et al. Novel prostate brachytherapy technique: improved dosimetric and clinical outcome. Radiother Oncol. 2008;88(1):121-6. [pmid: 18499289].
Noguchi M, Kakuma T, Suekane S, et al. A randomized clinical trial of suspension technique for improving early recovery of urinary continence after radical retropubic prostatectomy. BJU Int. 2008;102(8):958-63. [pmid: 18485031].
Norkus D, Miller A, Kurtinaitis J, et al. A randomized trial comparing hypofractionated and conventionally fractionated three-dimensional external-beam radiotherapy for localized prostate adenocarcinoma: a report on acute toxicity. Strahlenther Onkol. 2009;185(11):715-21. [pmid: 19899003].
Onal C, Topkan E, Efe E, et al. Comparison of rectal volume definition techniques and their influence on rectal toxicity in patients with prostate cancer treated with 3D conformal radiotherapy: a dose-volume analysis. Radiat Oncol. 2009;4:14. [pmid: 19432953].
Peeters ST, Heemsbergen WD, van Putten WL, et al. Acute and late complications after radiotherapy for prostate cancer: results of a multicenter randomized trial comparing 68 Gy to 78 Gy. Int J Radiat Oncol Biol Phys. 2005;61(4):1019-34. [pmid: 15752881].
Peeters ST, Lebesque JV, Heemsbergen WD, et al. Localized volume effects for late rectal and anal toxicity after radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. 2006;64(4):1151-61. [pmid: 16414208].
Peeters ST, Hoogeman MS, Heemsbergen WD, et al. Rectal bleeding, fecal incontinence, and high stool frequency after conformal radiotherapy for prostate cancer: normal tissue complication probability modeling. Int J Radiat Oncol Biol Phys. 2006;66(1):11-9. [pmid: 16757129].
Peeters ST, Hoogeman MS, Heemsbergen WD, et al. Volume and hormonal effects for acute side effects of rectum and bladder during conformal radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. 2005;63(4):1142-52. [pmid: 15939547].
Penson DF, McLerran D, Feng Z, et al. 5-year urinary and sexual outcomes after radical prostatectomy: results from the Prostate Cancer Outcomes Study. J Urol. 2005;173(5):1701-5. [pmid: 15821561].
Pickles T, Keyes M, Morris WJ. Brachytherapy or conformal external radiotherapy for prostate cancer: a single-institution matched-pair analysis. Int J Radiat Oncol Biol Phys. 2010;76(1):43-9. [pmid: 19570619].
Pinkawa M, Asadpour B, Piroth MD, et al. Health-related quality of life after permanent I-125 brachytherapy and conformal external beam radiotherapy for prostate cancer: a matched-pair comparison. Radiother Oncol. 2009;91(2):225-31. [pmid: 19081154].
Pinkawa M, Attieh C, Piroth MD, et al. Dose-escalation using intensity-modulated radiotherapy for prostate cancer: evaluation of the dose distribution with and without 18F-choline PET-CT detected simultaneous integrated boost. Radiother Oncol. 2009;93(2):213-9. [pmid: 19717197].
Pinkawa M, Fischedick K, Gagel B, et al. Association of neoadjuvant hormonal therapy with adverse health-related quality of life after permanent iodine-125 brachytherapy for localized prostate cancer. Urology. 2006;68(1):104-9. [pmid: 16806434].
Ponholzer A, Brössner C, Struhal G, et al. Lower urinary tract symptoms, urinary incontinence, sexual function and quality of life after radical prostatectomy and external beam radiation therapy: real life experience in Austria. World J Urol. 2006;24(3):325-30. [pmid: 16688458].
Potosky AL, Davis WW, Hoffman RM, et al. Five-year outcomes after prostatectomy or radiotherapy for prostate cancer: the Prostate Cancer Outcomes Study. J Natl Cancer Inst. 2004;96(18):1358-67. [pmid: 15367568].
Potosky AL, Legler J, Albertsen PC, et al. Health outcomes after prostatectomy or radiotherapy for prostate cancer: results from the Prostate Cancer Outcomes Study. J Natl Cancer Inst. 2000;92(19):1582-92. [pmid: 11018094].
Potters L, Morgenstern C, Calugaru E, et al. 12-year outcomes following permanent prostate brachytherapy in patients with clinically localized prostate cancer. J Urol. 2005;173(5):1562-6. [pmid: 15821486].
Poulakis V, Skriapas K, de Vries R, et al. Vesicourethral anastomosis during endoscopic extraperitoneal radical prostatectomy: a prospective comparison between the single-knot running and interrupted technique. Urology. 2006;68(6):1284-9. [pmid: 17141837].
Raben A, Rusthoven KE, Sarkar A, et al. Favorable toxicity and biochemical control using real-time inverse optimization technique for prostate brachytherapy. Brachytherapy. 2009;8(3):297-303. [pmid: 19213608].
Raina R, Pahalajani G, Agarwal A, Zippe C. Long-term effectiveness of luteinizing hormone-releasing hormone agonist or antiandrogen monotherapy in elderly men with localized prostate cancer (T1-2): a retrospective study. Asian J Androl. 2007;9(2):253-8. [pmid: 17334592].
Rassweiler J, Stolzenburg J, Sulser T, et al. Laparoscopic radical prostatectomy: the experience of the German Laparoscopic Working Group. Eur Urol. 2006;49(1):113-9. [pmid: 16337330].
Reis F, Netto NR Jr, Reinato JA, et al. The impact of prostatectomy and brachytherapy in patients with localized prostate cancer. Int Urol Nephrol. 2004;36(2):187-90. [pmid: 15368690].
Roeloffzen EM, Lips IM, van Gellekom MP, et al. Health-related quality of life up to six years after (125)I brachytherapy for early-stage prostate cancer. Int J Radiat Oncol Biol Phys. 2010;76(4):1054-60. [pmid: 20097486].
Salem N, Simonian-Sauve M, Rosello R, et al. Predictive factors of acute urinary morbidity after iodine-125 brachytherapy for localised prostate cancer: a phase 2 study. Radiother Oncol. 2003;66(2):159-65. [pmid: 12648787].
Sanda MG, Dunn RL, Michalski J, et al. Quality of life and satisfaction with outcome among prostate-cancer survivors. New Engl J Med. 2008;358(12):1250-61. [pmid: 18354103].
Sarosdy MF. Urinary and rectal complications of contemporary permanent transperineal brachytherapy for prostate carcinoma with or without external beam radiation therapy. Cancer. 2004;101(4):754-60. [pmid: 15305406].
Schafer JW, Welzel G, Trojan L, et al. Long-term health-related quality-of-life outcomes after permanent prostate brachytherapy. Onkologie. 2008;31(11):599-603. [pmid: 19145092].
Schover LR, Fouladi RT, Warneke CL, et al. Defining sexual outcomes after treatment for localized prostate carcinoma. Cancer. 2002;95(8):1773-85. [pmid: 12365027].
Shakespeare D, Mitchell DM, Carey BM, et al. Recto-urethral fistula following brachytherapy for localized prostate cancer. Colorectal Dis. 2007;9(4):328-31. [pmid: 17432984].
Slova D, Lepor H. The short-term and long-term effects of radical prostatectomy on lower urinary tract symptoms. J Urol. 2007;178(6):2397-400. [pmid: 17936841].
Soderdahl DW, Davis JW, Schellhammer PF, et al. Prospective longitudinal comparative study of health-related quality of life in patients undergoing invasive treatments for localized prostate cancer. J Endourol. 2005;19(3):318-26. [pmid: 15865521].
Stanford JL, Feng Z, Hamilton AS, et al. Urinary and sexual function after radical prostatectomy for clinically localized prostate cancer: the Prostate Cancer Outcomes Study. JAMA. 2000;283(3):354-60. [pmid: 10647798].
Stone NN, Stock RG. Long-term urinary, sexual, and rectal morbidity in patients treated with iodine-125 prostate brachytherapy followed up for a minimum of 5 years. Urology. 2007;69(2):338-42. [pmid: 17320674].
Taira AV, Merrick GS, Galbreath AW, et al. Erectile function durability following permanent prostate brachytherapy. Int J Radiat Oncol Biol Phys. 2009;75(3):639-48. [pmid: 19303721].
Talcott JA, Rossi C, Shipley WU, et al. Patient-reported long-term outcomes after conventional and high-dose combined proton and photon radiation for early prostate cancer. JAMA. 2010;303(11):1046-53. [pmid: 20233822].
Uchida T, Baba S, Irie A, et al. Transrectal high-intensity focused ultrasound in the treatment of localized prostate cancer: a multicenter study. Hinyokika Kiyo. 2005;51(10):651-8. [pmid: 16285617].
Ukoli FA, Lynch BS, Adams-Campbell LL. Radical prostatectomy and quality of life among African Americans. Ethn Dis. 2006;16(4):988-93. [pmid: 17061757].
van Andel G, Visser AP, Zwinderman AH, et al. A prospective longitudinal study comparing the impact of external radiation therapy with radical prostatectomy on health related quality of life (HRQOL) in prostate cancer patients. Prostate. 2004;58(4):354-65. [pmid: 14968436].
Van der Aa F, Joniau S, De Ridder D, Van Poppel H. Potency after unilateral nerve sparing surgery: a report on functional and oncological results of unilateral nerve sparing surgery. Prostate Cancer Prostatic Dis. 2003;6(1):61-5. [pmid: 12664068].
Voerman B, Fischer M, Visser A, et al. Health-related quality of life in Dutch men with prostate cancer. J Psychosoc Oncol. 2006;24(2):49-64. [pmid: 17046806].
Vordermark D, Schwab M, Flentje M, et al. Chronic fatigue after radiotherapy for carcinoma of the prostate: correlation with anorectal and genitourinary function. Radiother Oncol. 2002;62(3):293-7. [pmid: 12175560].
Ward-Smith P, Mehl J. Quality of life before and after prostatectomy as treatment for localized cancer. Urol Nurs. 2007;27(6):542-7. [pmid: 18217538].
Wei JT, Dunn RL, Sandler HM, et al. Comprehensive comparison of health-related quality of life after comtemporary therapies for localized prostate cancer. J Clin Oncol. 2002;20(2):557-66. [pmid: 11786586].
Yeoh EE, Holloway RH, Fraser RJ, et al. Hypofractionated versus conventionally fractionated radiation therapy for prostate carcinoma: updated results of a phase III randomized trial. Int J Radiat Oncol Biol Phys. 2006;66(4):1072-83. [pmid: 16965866].
Zietman AL, DeSilvio ML, Slater JD, et al. Comparison of conventional-dose vs high-dose conformal radiation therapy in clinically localized adenocarcinoma of the prostate: a randomized controlled trial. JAMA. 2005;294(10):1233-9. [pmid: 16160131].

## Appendix B5 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized Controlled Trials (RCTs) and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ RCTs: adequate randomization, including concealment and whether potential confounders were distributed equally among groups
  ○ Cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of ratings based on above criteria

Good | Meets all criteria: comparable groups are assembled initially and maintained throughout the study (followup at least 80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor | Studies will be graded “poor” if any of the following major limitations exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Source Harris et al, 2001^27^

## Appendix B6 Expert Reviewers of the Draft Report

Michael Barry, MD

Director, Health Services Research Program and Chief, General Medicine Unit, Massachusetts General Hospital (MGH); Professor of Medicine, Harvard Medical School; and Medical Director, John D. Stoeckle Center for Primary Care Innovation.

Michael S. Cookson, MD

Professor, Vanderbilt University, Department of Urologic Surgery.

Philipp Dahm, MD

Associate Professor of Urology, Associate Residency Program Director, Director of Clinical Research, University of Florida Department of Urology.

Bruce L. Dalkin, MD, FACS

Professor of Urology and Urological Oncology, Department of Urology, University of Washington School of Medicine.

Richard M. Hoffman, MD, MPH

Professor, Internal Medicine, Division of Epidemiology, University of New Mexico Cancer Center.

Barnett S. Kramer, MD, MPH

Director, National Institutes of Health Office of Medical Applications of Research.

David F. Penson, MD, MPH

Professor of Urologic Surgery, Director of Vanderbilt Center for Surgical Quality and Outcomes Research, Vanderbilt.

Ian Thompson, MD

Professor, Chairman, Department of Urology, University of Texas San Antonio.