# Abbreviations

Abbreviation: Meaning
ADT: Androgen deprivation therapy
AHRQ: Agency for Healthcare Research and Quality
AJCC: American Joint Committee on Cancer
AS: Active surveillance
BSFI: Brief Sexual Function Inventory
CAPRA: Cancer of the Prostate Risk Assessment
CaPSURE: Cancer of the Prostate Strategic Urologic Research Endeavor
CARES-SF: Cancer Rehabilitation Evaluation System–Short Form
CI: Confidence interval
DRE: Digital rectal examination
EBRT: External beam radiotherapy
EPIC: Expanded Prostate Cancer Index Composite
FACT-G: Functional Assessment of Cancer Therapy–General
HDR: High-dose radiotherapy (brachytherapy)
HIFU: High-intensity focused ultrasonography
IPCSS: International Prostate Cancer Symptom Scale
KQ: Key question
LDR: Low-dose radiotherapy (brachytherapy)
LHRH: Luteinizing hormone-releasing hormone
MCS: Mental component score
NA: Not applicable
NR: Not reported
PCS: Physical component score
PCSS: Prostate Cancer Symptom Scale
PSA: Prostate-specific antigen
QLQ-C30: Quality of Life Questionnaire for Cancer
QOL: Quality of life
RCT: Randomized, control trial
RD: Risk difference
RP: Radical prostatectomy
RR: Relative risk
RT: Radiotherapy
SD: Standard deviation
SE: Standard error
SEER: Surveillance, Epidemiology, and End Results
SF-36: Short-Form 36-Item Health Survey
T: Tumor stage
TNM: Tumor, node, metastasis
UCLA-PCI: University of California, Los Angeles Prostate Cancer Index
USPSTF: U.S. Preventive Services Task Force
WW: Watchful waiting