# Appendixes

Appendix A Abbreviations

Appendix B Detailed Methods

Appendix C Evidence Tables and Quality Tables