# Results

A total of 379 potentially relevant articles were identified; of these, two fair-quality trials,6,7 two poor-quality trials,12,13 and two meta-analyses14,15 met inclusion criteria (Figure 2). Additionally, we included a report that describes results from a single center participating in one of the fair-quality trials.16 For completeness, we also included one poor-quality randomized trial that was previously considered by the USPSTF.17 Table 1 summarizes key characteristics of all of these studies. A list of excluded studies can be found in Appendix 6.

Figure 2 Literature Flow Diagram

*Study was not an RCT, systematic review, or meta-analysis, or was a nonrandomized analysis of an RCT.

Figure 2 displays an accounting of studies reviewed for the evidence report. 379 articles were identified through searches of online databases and other sources as being potentially relevant to the evidence report. Of those, 278 were excluded at the title level, and 85 at the abstract level, for not meeting inclusion criteria. The full-text of 16 studies were reviewed for inclusion in the evidence report. Of those, 9 were excluded for not meeting inclusion criteria. The remaining 7 articles were included in the final evidence report.

Table 1 Randomized, Controlled Trials of Prostate Cancer Screening With Mortality Outcomes

Trial | Study Population | Study Population Description | Intervention | Median/ Maximum Length of Followup (Years) | Results | Limitations | Quality Rating | Comments
Quebec Labrie et al 2004 (17) | Men registered on the Quebec City area electoral rolls in 1988 | 46,486 men aged 45–80 years 31,133 men invited for screening; 23.6% received screening 15,353 controls not invited; 7.3% received screening | DRE + PSA at first visit PSA alone at subsequent screens PSA cut-off point >3.0 ng/mL; if PSA previously >3.0 ng/mL, a PSA increase of 20% over previous year value or over predicted PSA (prPSA) Positive screening test led to TRUS-guided biopsy | 7.9/11 | No difference in prostate-cancer specific mortality when data are analyzed via intention-to-screen: RR, 1.01 (95% CI, 0.82–1.40) | No information to assess adequacy of randomization Unclear if outcome assessment was blinded No baseline sociodemographic comparison of the two groups Inadequate reporting of attrition Authors did not primarily use intention- to-screen analysis | Poor | Trial included in the 2008 evidence review and previously considered by the USPSTF
Nörrkoping Sandblom et al 2004 (18) 2011 (13) | Male residents of Nörrkoping, Sweden identified in the Swedish National Population Register in 1987 | 9,026 men aged 50–69 years 1,494 men (every 6th man) invited for screening; 70%–78% received screening, depending on year 7,532 controls received usual care; unknown how many received screening | DRE only in 1987 and 1990 DRE + PSA in 1993 and 1996 PSA cut-off point >4.0 ng/mL Positive screening test led to biopsy; confirmed prostate cancer treated according to regional standardized management program | 6.3/20 | No difference in prostate-cancer specific mortality (RR, 1.16 [95% CI, 0.78–1.73]) or overall survival (log rank test, p=0.14) between invited and non-invited groups | Inadequate randomization and allocation concealment procedures (predictable group assignment) No baseline sociodemographic comparison of the two groups Contamination rate in control group not assessed Inadequate reporting of attrition | Poor | Trial included in the 2008 evidence review and previously considered by the USPSTF; extended followup now available Trial (and sample size/power calculation) originally designed to assess acceptance and feasibility of prostate cancer screening program, not prostate cancer mortality
Stockholm Kjellman et al 2009 (12) | Men living in the catchment area of Stockholm South Hospital in Sweden in 1988 | 26,602/27,204^*^ men aged 55–70 years 2,400^*^ men invited for screening, 74% received screening 24,202/24,804^*^ controls from source population received usual care; contamination not reported | Single screening with DRE, TRUS, and PSA Abnormal DRE or TRUS led to biopsy PSA cut-off point >7.0 ng/mL led to repeat TRUS PSA cut-off point >10.0 ng/mL led to biopsy Treatment was “the standard care at the clinic at that time” | 12.9/15.7 | No difference in prostate cancer mortality: IRR, 1.10 (95% CI, 0.83–1.46) No difference in death from other causes: IRR, 0.98 (95% CI, 0.92–1.05) | Methods of randomization and allocation concealment unclear Unclear if outcome assessment was blinded No baseline sociodemographic comparison of the two groups Contamination rates in control group not assessed Inadequate reporting of attrition Limited applicability to current U.S. practice (high PSA threshold) | Poor | Report has internal discrepancies about the total number of participants because the file containing the registration numbers of the original cohort could not be retrieved
PLCO Andriole et al 2009 (6) | Men enrolled at 10 study centers in the United States from 1993–2001 | 76,693 men aged 55–74 years 38,343 men assigned to screening; overall compliance with screening was 85% for PSA and 86% for DRE 38,350 men assigned to usual care; 52% had at least one PSA during trial | Annual PSA for 6 years Annual DRE for 4 years PSA cut-off point >4.0 ng/mL Positive PSA or DRE referred to patient’s primary care physician for management | 11.5/14.8 | No difference in prostate cancer- specific mortality at 7 or 10 years: rate ratios, 1.13 (95% CI, 0.75–1.70) and 1.11 (95% CI, 0.83–1.50), respectively No difference in overall mortality (excluding prostate, lung, or colorectal cancer) at 7 or 10 years: rate ratios, 0.98 (95% CI, 0.92–1.03) and 0.97 (95% CI, 0.93–1.01), respectively | High rate of contamination in control arm (up to 52% by 6 years) Approximately 44% of men in each arm had undergone one or more PSA tests prior to trial entry | Fair
ERSPC Schroder et al 2009 (7) | Men in 7 European countries enrolled from 1991–2003 | 182,160 men aged 50–74 years; 162,387 men in prespecified “core” subgroup of 55–69 years 82,816 men assigned to screening; 82% had at least one PSA test during trial 99,184 men assigned to the control group; based on single site, screening in controls estimated at ~20% | Variable by center; see Appendix 2 for details Most centers performed PSA every 4 years; some also utilized DRE or TRUS PSA cut-off points ranged from 2.5 to 10.0 ng/mL; 3.0 ng/mL most often utilized, some ancillary testing with lower PSA values Positive screen led to biopsy; treatments according to local policies and guidelines | 9/14.5 | No difference in prostate cancer- specific mortality in all enrolled men: RR, 0.85 (95% CI, 0.73–1.00) Reduced prostate cancer-specific mortality in “core” subgroup: ARR, 0.071%; RR, 0.80 (95% CI, 0.65–0.98); NNS=1,410;NNT=48 | Inconsistencies in screening intervals and PSA cut-off points among study centers Method of allocation concealment not described Differences in exclusion of men by age between centers Exclusion of data from 2 study centers (Portugal and France, which would bring the number of participating countries to 9) Inadequate reporting of attrition | Fair
Substudy of ERSPC: Göteborg Hugosson et al 2010 (16) | Men born between 1930 and 1944 identified from the population register of Göteborg, Sweden in December 1994 | 19,904 men aged 50–64 years 9,952 invited to screening; 76% had at least one PSA 9,952 controls not invited to screening; contamination rate estimated at 3% | PSA every 2 years for 7 rounds PSA cut-off point ranged from 2.5 to 3.0 ng/mL, depending on year Positive screen led to DRE, TRUS, and biopsy Treatment was at the discretion of the participant’s personal physician | 14/14 | Reduced prostate cancer-specific mortality: ARR, 0.40% (95% CI, 0.17–0.64); RR, 0.56 (95% CI, 0.39–0.82); NNS=293 (95% CI, 177–799); NNT=12 | 60% of participants (men born between 1930 and 1939) previously included in overall ERSPC results No baseline demographic comparison of the two groups Inadequate reporting of attrition Contamination rate in controls not formally assessed; unclear how 3% estimate was obtained | Fair | This publication represents single center results reported separately from the overarching ERSPC trial

* Report has internal discrepancies about this number, because the file containing the registration numbers of the original cohort could not be retrieved.

Abbreviations: DRE=digital rectal examination; PSA=prostate-specific antigen; TRUS=transrectal ultrasonography; RR=relative risk; CI=confidence interval ; ARR=absolute risk reduction; NNS=number needed to screen; NNT=number needed to treat; IRR=incidence rate ratio.

## Key Question 1 Does PSA-Based Screening Decrease Prostate Cancer-Specific or All-Cause Mortality?

In 2008, the USPSTF considered two poor-quality randomized controlled trials and one meta-analysis that addressed this question. The first trial, by Labrie et al,17 randomized 46,486 men to PSA-based screening versus usual care and showed no statistically significant difference in prostate cancer mortality between screening-invited and control groups when data were analyzed via intention-to-screen (risk ratio [RR], 1.09 [95% CI, 0.82–1.43]). The second trial, by Sandblom et al,18 involved 9,026 men and also found no statistically significant difference in prostate cancer mortality between screening-invited and control groups (RR, 1.04 [95% CI, 0.64–1.68]). A 2007 Cochrane meta-analysis19 of these two trials found no statistically significant difference in prostate cancer mortality in men randomized to screening versus controls (RR, 1.01 [95% CI, 0.8–1.29]); however, the authors concluded that due to the methodological limitations and high risk for bias inherent in both trials, the evidence was insufficient at that time to support or refute the use of screening to reduce prostate cancer mortality.

New evidence, along with updated results from the Cochrane meta-analysis and the Sandblom trial, is summarized below.

### Nörrkoping Trial

In early 2011, longer-term results from the randomized trial by Sandblom et al became available.13 In 1987, all male residents aged 50 to 69 years living in Nörrkoping, Sweden were identified in the National Population Register, and every sixth man (n=1,494) was invited to participate in a multiyear screening program. The remaining 7,532 men—who were not contacted—were treated as controls. Screening consisted of digital rectal examination in 1987 and 1990; this changed to digital rectal examination plus PSA testing in 1993 and 1996. Depending on the screening round, between 70%–78% of invited men received screening. A PSA cut-off point of >4.0 μg/L was used. A positive screening result led to biopsy, and confirmed prostate cancer was treated according to a standardized management program common to the southeast region of Sweden.

No statistically significant difference in prostate cancer mortality was seen between the screened and control groups after 20 years of followup (RR, 1.16 [95% CI, 0.78–1.73]).

This trial was rated as poor quality, as the method of randomization was inadequate, there was no information available on the baseline comparability of the screened and control groups or the degree of contamination in the control group, and there was insufficient information regarding outcome assessment. Additionally, the sample size was originally calculated to assess the acceptance and feasibility of a prostate cancer screening program rather than mortality outcomes. (See Appendix 3 for additional information on quality ratings for included trials.)

### Stockholm Trial

Kjellman et al12 conducted a comparative study in which 2,400 male residents of Stockholm, Sweden aged 55 to 70 years were invited to a single prostate cancer screening in 1988 and followed for 15 years. Of the men invited, 74% attended the screening, which included a PSA test, digital rectal examination, and transrectal ultrasonography. A PSA threshold of 10 ng/mL triggered prostate biopsy, while a measurement of 7–10 ng/mL led to repeat ultrasonography. Death rates from prostate cancer and all causes other than prostate cancer in the screening-invited group were compared with death rates in the remaining 24,804 men in the source population.

Neither the relative risk of death due to prostate cancer (RR, 1.10 [95% CI, 0.83 to 1.46]) nor the relative risk of death from other causes (RR, 0.98 [95% CI, 0.92 to 1.05]) was statistically significantly different in the screening-invited group compared with the controls. Only three of the 65 cases of prostate cancer found during screening were detected by an elevated PSA level alone.

This trial was rated as poor quality because of uncertainty about initial comparability of the screening and comparison groups and the potential for attribution bias in outcomes assessment, as it is not clear if the review committee was blinded to group allocation. The trial also has internal discrepancies about the total number of participants because the file containing the registration numbers of the original cohort could not be retrieved. This trial’s findings are poorly generalizable to the United States due to the high PSA cut-off points and probable outdated treatments used.

### PLCO Cancer Screening Trial

In the prostate cancer component of the PLCO trial,6 76,693 U.S. men aged 55 to 74 years were randomized to annual PSA-based screening for 6 years in combination with digital rectal examination for 4 years or to usual care. Randomization occurred after consent. Abnormal screening results, defined as a PSA level of ≥4.0 ng/mL or suspicious digital rectal examination findings, were made known to the patient’s primary care clinician, and further diagnostic testing and treatment were based on patient and physician preferences.

After 7 years’ (complete) followup, there was a statistically significant increase in prostate cancer incidence in men assigned to the screening group (RR, 1.22 [95% CI, 1.16–1.29]), but no difference in prostate cancer mortality (RR, 1.13 [95% CI, 0.75–1.70]) compared with the usual care group. Similar findings were observed after 10 years (67% complete followup). There was no difference in all-cause mortality in the screened versus usual care arms (10-year RR, 0.97 [95% CI, 0.93–1.01]) based upon an analysis that excluded lung and colorectal cancer deaths. Eighty-nine percent of men in the screen-invited group and 90% of men in the control group who received a prostate cancer diagnosis chose active treatment (surgery, radiation, and/or hormonal therapy). Treatment choices stratified by prostate cancer stage were similar between the screening and control groups.

The PLCO trial was rated fair quality because of contamination; up to 52% of men assigned to usual care received a PSA test at some point during the trial. Contamination could have compromised the ability of the trial to detect a positive effect of screening on prostate cancer mortality; in order to maintain 90% power at 7 years of followup, the relative prostate cancer mortality reduction from screening would have had to be 40%, according to the group’s baseline calculations.20 However, contamination does not explain the (nonstatistically significant) trend toward increased mortality in the screened arm. Forty-four percent of the men in both the screening and usual care groups had undergone PSA screening prior to entry. Subgroup analyses stratified by a history of PSA testing at baseline did not reveal differential effects on prostate cancer mortality rates between the screen-invited and control arms,6 but the high rate of prescreening affects the ability of the study to be generalized to a screen-naive population.

### ERSPC

The ERSPC trial7 randomized 182,000 men from seven European countries aged 50 to 74 years to be invited for PSA testing every 2 to 7 years—depending on center and year—or to usual care. PSA cut-off points for diagnostic evaluation ranged from 2.5 to 4.0 ng/mL (one center used the cut-off point of 10 ng/mL for several years). Recruitment and randomization procedures and age eligibility for enrollment also varied substantially among study centers. Appendix 4 provides details about the exact differences between study centers. Treatment of prostate cancer was performed according to each center’s local policies and guidelines.

After a median followup of 9 years, the cumulative incidence of prostate cancer diagnoses in men in the screened arm was higher than in the usual care arm (8.2% vs. 4.8%, respectively, or a net increase of 34 additional cases per 1,000 men). There was no statistically significant difference in the risk for prostate cancer death for the entire population of men assigned to screening invitation (ages 50 to 74 years) compared with men assigned to usual care (RR, 0.85 [95% CI, 0.73–1.00]). A prespecified subgroup analysis of 162,243 men aged 55 to 69 years found a statistically significant absolute risk reduction in prostate cancer mortality of 0.071% (RR, 0.80 [95% CI, 0.65–0.98]). Prostate cancer mortality rate ratios were greater than 1 for screen-invited men aged 50 to 54 years (RR, 1.47 [95% CI, 0.41–5.19]) and 70 to 74 years (RR, 1.26 [95% CI, 0.80–1.99]), although these were not statistically significant findings and the confidence interval in the younger age group is very wide. Using the 0.071% risk difference in the subgroup of men aged 55 to 69 years, the authors estimated that 1,410 men would need to be invited to screening and 48 additional men would need to be treated to prevent one prostate cancer death.

Sixty-six percent of men in the ERSPC trial who received a prostate cancer diagnosis were initially managed with surgery, radiation therapy, or hormonal therapy, while 15% chose active surveillance or watchful waiting (specific treatment information was not available for 19% of diagnosed participants). Treatment choice varied by trial arm; participants in the control arm with high-risk prostate cancer were statistically significantly more likely than screen-invited men to receive radiotherapy, expectant management, or hormonal therapy than radical prostatectomy. This may have been because the major screening centers were large university hospitals, and once diagnosed, screen-invited participants tended to also receive treatment from these centers. In contrast, control subjects were not invited to screening centers, and as such, were more likely to be diagnosed and receive treatment at their usual place of care. However, on regression analysis, the association between treatment choice and study arm was weaker than other factors such as age, PSA level, and Gleason score.21

The ERSPC trial was rated fair quality due to the inconsistencies in screening intervals and PSA cut-off points among study centers, differences in exclusion of eligible and randomized men by age between centers, and exclusion of data from two study centers (Portugal and France, which would bring the total number of original participating countries to nine). Contamination was not systematically or uniformly evaluated at all centers for the duration of the trial. According to an earlier publication, PSA testing in men assigned to usual care varied widely by study center, from 8.6% (Spain) to 36.6% (Italy)22; however, based upon the Rotterdam center, contamination was extrapolated to be about 20% for the overall trial.23

Göteborg center. After the publication of the ERSPC results, a single center from within this larger trial chose to report data separately.16 The center designed its protocol independently, but became associated with the ERSPC trial after 1 year. A total of 20,000 men in Göteborg, Sweden aged 50 to 64 years were randomized to PSA screening every 2 years versus usual care. The PSA threshold for additional evaluation varied during the course of the study from 3.0 ng/mL to 2.5 ng/mL. Followup testing included digital rectal examination, transrectal ultrasonography, and prostate biopsy, with treatment choice left to the discretion of the patient’s physician.

Seventy-six percent of invited men attended screening. After a median followup of 14 years, there was a statistically significant increase in prostate cancer incidence in the screen-invited versus control arm (hazard ratio, 1.64 [95% CI, 1.50–1.80]; 11.4% of screening-invited vs. 7.2% of usual care group diagnosed). There was an absolute risk reduction of 0.34% for prostate cancer death in the screen-invited arm compared with controls (RR, 0.56 [95% CI, 0.39–0.82]). The authors estimated that 293 men would need to be invited to screening and 12 additional men would need to be treated in order to prevent one prostate cancer death.

In screening-invited men, 56% chose radical prostatectomy, radiation, or hormonal therapy as a primary treatment strategy, while 42% initially chose surveillance. Primary hormonal therapy was more commonly used in men diagnosed with prostate cancer in the usual care compared with screen-invited arm (22.6% vs. 7%, respectively), but for low- or moderate-risk tumors, curative treatment was applied similarly between the screening (49.2%) and usual care (50.8%) groups.

This study was rated fair quality due to a lack of information regarding baseline comparability of the two arms, as well as attrition and contamination rates (contamination was estimated at 3%, but it is unclear how this estimate was obtained). As noted, the Göteborg center became associated with the larger ERSPC trial shortly after its inception, and outcomes for men born between 1930 and 1939 (60% of the center’s participants) were previously reported as part of the overarching ERSPC publication. No other center from the ERSPC trial separately reported mortality results, but an analysis of the effect of study center exclusion on the overall ERSPC findings demonstrated that exclusion of the Swedish center data alone resulted in loss of the statistically significant effect of screening on prostate cancer mortality (RR, 0.84 [95% CI, 0.70–1.01]), suggesting better results than the other centers.7

### Djulbegovic Meta-Analysis

In 2010, a systematic review and meta-analysis covering the period from January 2005 to July 2010 was published.15 The authors included the following studies in the analysis (total population, 387,286): 1) Quebec (Labrie at al); 2) Nörrkoping; 3) ERSPC, including data from the French and Swedish (Göteborg) centers; and 4) PLCO. To avoid double-counting, participant outcomes that were included in both the Göteborg and overall ERSPC publications were only utilized from the Göteborg paper.

All except for the Quebec study contributed information on diagnosis of prostate cancer; the meta-analysis showed a statistically significant increase in prostate cancer incidence in the screened versus control group (RR, 1.46 [95% CI, 1.21–1.77]). There was a high degree of heterogeneity in the trials for this outcome (I^2^=97%), and the overall quality of evidence was considered low. Prostate cancer mortality was assessed using data from all studies with the exception of the ERSPC French center, as this publication only provided information on prostate cancer incidence. Screening was not associated with a statistically significant reduction in prostate cancer mortality (RR, 0.88 [95% CI, 0.71–1.09]). There was heterogeneity (I^2^=55%), and the quality of evidence for this outcome was rated as moderate. All-cause mortality was assessed using information from PLCO, Nörrkoping, ERSPC, and the Göteborg substudy. No statistically significant difference in overall mortality was observed (RR, 0.99 [95% CI, 0.97–1.01]). The quality of evidence for this outcome was rated as moderate.

### Cochrane Meta-Analysis

An update of the previously described meta-analysis was published in 2011.^14^ It included five trials (total population, 341,351): 1) Nörrkoping, 2) ERSPC (including the results of the Göteborg center), 3) PLCO, 4) Quebec (Labrie et al), and 5) Stockholm, as well as reports on prostate cancer diagnosis, prostate cancer-specific mortality, and overall mortality. The Nörrkoping, Quebec, and Stockholm studies were rated as being at high risk of bias, whereas PLCO and ERSPC were both rated at low risk of bias.

Meta-analysis indicated that screening was associated with a statistically significant increase in the number of men diagnosed with prostate cancer compared with controls (RR, 1.35 [95% CI, 1.06–1.72]). However, no statistically significant difference in prostate cancer-specific mortality was observed between screened and control groups when all trials (RR, 0.95 [95% CI, 0.85–1.07]), or only trials at low risk for bias (i.e., PLCO and ERSPC) (RR, 0.89 [95% CI, 0.77–1.04]), were included. In subgroup analyses, age at screening did not change the outcome. Meta-analysis of the two studies providing information on overall mortality—ERSPC and Stockholm—showed no differences in death from any cause between screened and control groups (RR, 1.00 [95% CI, 0.98–1.02]).

## Key Question 2 What Are the Harms of PSA-Based Screening for Prostate Cancer?

Information about the harms of PSA-based screening for prostate cancer has been reported by two of the randomized trials that directly assess the impact of PSA-based screening on prostate cancer mortality.

The Finnish center of the ERSPC trial reported that after three rounds of PSA testing (using a cut-off point of 4.0 ng/mL and testing every 4 years), 12.5% of participants received at least one false-positive result. A false positive was defined as a positive result and consequent workup with no histopathologic diagnosis of cancer within 1 year of the screening test.24 In the entire ERPSC trial, 75.9% of men that underwent a biopsy because of an elevated PSA value had a false-positive result.7 The PLCO trial also published findings related to false-positive tests. After four PSA tests, men had a 12.9% cumulative risk of receiving at least one false-positive result (defined as a PSA level of ≥4.0 ng/mL and no prostate cancer diagnosis after 3 years), and a 5.5% risk of having at least one biopsy as a direct consequence of a false-positive screening test.25

Physical harms of screening documented in the PLCO trial included rare bleeding or pain from digital rectal examination (0.3 events per 10,000 men screened), bruising or fainting due to venipuncture (26.2 events per 10,000 men screened), and complications of diagnostic procedures (e.g., biopsy), such as infection, bleeding, and urinary difficulty (68 events per 10,000 evaluations).6 The overarching ERSPC publication did not report on prostate biopsy-related harms, except to note that no deaths were associated with the procedure.7 However, the Rotterdam study center published a site-specific assessment of biopsy-related harms.26 Of 5,802 biopsies performed from 1994 to 2001, 200 men (3.5%) developed a fever, 20 men (0.4%) experienced urinary retention, and 27 men (0.5%) required hospitalization for signs of prostatitis or urosepsis. Reports of hematuria (22.6%) and hematospermia (50.4%) more than 3 days after the biopsy were common.

None of the randomized controlled trials of PSA-based screening and prostate cancer mortality provided information on potential psychological harms of prostate cancer screening, such as anxiety, or impact on health-related quality of life. The 2008 evidence review performed for the USPSTF found evidence that false-positive PSA test results are associated with adverse psychological effects, but could not determine the exact magnitude of psychological harms of prostate cancer screening.10