# Methods

## Key Questions and Analytic Framework

This evidence update summarizes new and previously reviewed randomized controlled trials, systematic reviews, and meta-analyses to answer the following key questions: 1) Does PSA-based screening decrease prostate cancer-specific or all-cause mortality? and 2) What are the harms of PSA-based screening for prostate cancer? Figure 1 provides the analytic framework that guided both this and the related treatment review.

Figure 1 Analytic Framework and Key Questions

[underlined: Key Questions]

1. What is the direct evidence that screening for prostate cancer with prostate-specific antigen (PSA), as a single-threshold test or as a function of multiple tests over time, decreases morbidity and/or mortality?
2. What are the harms of PSA-based screening for prostate cancer?

Figure 1 is an analytic framework for the key questions of this report that depicts the events that men could experience as a result of undergoing screening for prostate cancer, with the ultimate goal of reducing mortality and morbidity related to prostate cancer. The figure illustrates how screening can result in early detection of prostate cancer, and detection can lead to various treatments. Treatments include surgery (prostatectomy), radiation therapy, hormonal therapy, cryotherapy, ultrasound therapy, active surveillance or watchful waiting. The figure also depicts the possibility of harms or adverse events occurring as a result of screening for or treatment of localized prostate cancer.

“PSA-based screening” is defined as a screening program for prostate cancer in asymptomatic men that incorporates one or more PSA measurements, with or without additional modalities such as digital rectal examination or transrectal ultrasonography. “Asymptomatic” is defined as without symptoms that are highly suspicious for prostate cancer. Many older men have chronic, stable lower urinary tract symptoms (e.g., due to benign prostatic hyperplasia ) that are not generally associated with an increased risk for prostate cancer.9 As in a previous review for the USPSTF,10 a broad definition of PSA-based screening was utilized that includes traditional single-threshold PSA testing as well as other PSA-based prognostic measures, such as age-adjusted thresholds, velocity, and doubling time.

## Search Strategy

PubMed was searched for English-language randomized controlled trials, systematic reviews, and meta-analyses indexed between January 1, 2007 and July 1, 2011, using combinations of the MeSH terms and key words “prostate neoplasms,” “screening,” “prostate-specific antigen,” “early diagnosis,” “PSA velocity,” “PSA doubling time,” and “prostate specific antigen doubling.” The exact strategy is described in Appendix 1. Additional articles were identified through a search of the Cochrane Database, hand searches of reference lists from included studies and review articles, and recommendations of experts.

## Study Selection

Four contributors independently reviewed title lists, abstracts, and full articles using predetermined inclusion and exclusion criteria. At each point, articles selected for retention by at least one contributor advanced to the next stage of review. Eligible studies were randomized controlled trials, systematic evidence reviews, or meta-analyses that compared PSA-based screening with no screening or usual care in asymptomatic general primary care populations and that reported prostate cancer or all-cause mortality as an outcome. Information about the harms of screening reported in trials meeting the above criteria was included for key question 2.

## Data Abstraction and Quality Assessment

For all citations that met the eligibility criteria, two contributors reviewed the full articles and independently rated their quality using previously published USPSTF criteria.11 Disagreements were resolved through consensus. The quality assessment included the following items: initial assembly and maintenance of comparable groups, absence of important differential loss to followup or overall high loss to followup, use of equal, valid, and reliable outcome measurements, clear definition of interventions, and appropriateness of outcomes. Appendix 2 describes more thoroughly the criteria and definitions for USPSTF quality ratings.

## Data Analysis and Synthesis

The data was synthesized qualitatively in narrative and tabular formats. Information from randomized controlled trials, systematic reviews, and meta-analyses on the direct effect of PSA-based screening on prostate cancer mortality, as well as the harms of screening and diagnostic procedures reported in these trials, were included. Data from the 2008 review10 were included to facilitate an overall assessment of the body of evidence.

## Role of the Funding Source

The general work of the USPSTF is supported by the Agency for Healthcare Research and Quality. This review did not receive specific funding.

## Review of Draft

The draft report was peer reviewed by content experts, USPSTF members, and collaborative federal partners.