# Excluded Studies

Aggarwal R, Weinberg V, Small EJ, et al. The mechanism of action of estrogen in castration-resistant prostate cancer: clues from hormone levels. Clin Genitourin Cancer. 2009;7(3):E71-6. [pmid: 19815485].
Ahmad IU, Forman JD, Sarkar FH, et al. Soy isoflavones in conjunction with radiation therapy in patients with prostate cancer. Nutr Cancer. 2010;62(7):996-1000. [pmid: 20924975].
Akaza H, Kanetake H, Tsukamoto T, et al. Efficacy and safety of dutasteride on prostate cancer risk reduction in Asian men: the results from the REDUCE study. Jpn J Clin Oncol. 2011;41(3):417-23. [pmid: 21123311].
Akaza H, Hinotsu S, Usami M, et al. Combined androgen blockade with bicalutamide for advanced prostate cancer: long-term follow-up of a phase 3, double-blind, randomized study for survival. Cancer. 2009;115(15):3437-45. [pmid: 19536889].
Aktoz T, Kaplan M, Turan U, et al. “Multimodal” approach to management of prostate biopsy pain and effects on sexual function: efficacy of levobupivacaine adjuvant to diclofenac sodium—a prospective randomized trial. Andrologia. 2009;42(1):35-40. [pmid: 20078514].
Alexander A, Crook J, Jones S, et al. Is biochemical response more important than duration of neoadjuvant hormone therapy before radiotherapy for clinically localized prostate cancer? An analysis of the 3- versus 8-month randomized trial. Int J Radiat Oncol Biol Phys. 2010;76(1):23-30. [pmid: 19395187].
Algotar AM, Thompson PA, Ranger-Moore J, et al. Effect of aspirin, other NSAIDs, and statins on PSA and PSA velocity. Prostate. 2010;70(8):883-8. [pmid: 20135645].
Allen JD, Othus MK, Hart A Jr, et al. A randomized trial of a computer-tailored decision aid to improve prostate cancer screening decisions: results from the take the wheel trial. Cancer Epidemiol Biomarkers Prev. 2010;19(9):2172-86. [pmid: 20716619].
Al-Mamgani A, van Putten WL, van der Wielen GJ, et al. Dose escalation and quality of life in patients with localized prostate cancer treated with radiotherapy: long-term results of the Dutch randomized dose-escalation trial (CKTO 96-10 trial). Int J Radiat Oncol Biol Phys. 2011;79(4):1004-12. [pmid: 20421153].
Al-Mamgani A, Heemsbergen WD, Levendag PC, Lebesque JV. Subgroup analysis of patients with localized prostate cancer treated within the Dutch-randomized dose escalation trial. Radiother Oncol. 2010;96(1):13-8. [pmid: 20227123].
Al-Mamgani A, Heemsbergen WD, Peeters ST, Lebesque JV. Role of intensity-modulated radiotherapy in reducing toxicity in dose escalation for localized prostate cancer. Int J Radiat Oncol Biol Phys. 2009;73(3):685-91. [pmid: 18718725].
Andriole GL, Bostwick D, Brawley OW, et al. The effect of dutasteride on the usefulness of prostate specific antigen for the diagnosis of high grade and clinically relevant prostate cancer in men with a previous negative biopsy: results from the REDUCE study. J Urol. 2011;185:126-31. [pmid: 21074214].
Andriole GL, Bostwick DG, Brawley OW, et al. Effect of dutasteride on the risk of prostate cancer. N Engl J Med. 2010;362(13):1192-202. [pmid: 20357281].
Aragon-Ching JB, Gillespie J, Price DK, et al. Lack of prognostic significance of prostate biopsies in metastatic androgen independent prostate cancer. BJU Int. 2007;100(6):1245-8. [pmid: 17850370].
Arai Y, Akaza H, Deguchi T, et al. Evaluation of quality of life in patients with previously untreated advanced prostate cancer receiving maximum androgen blockade therapy or LHRHa monotherapy: a multicenter, randomized, double-blind, comparative study. J Cancer Res Clin Oncol. 2008;134(12):1385-96. [pmid: 18491137].
Arcangeli G, Saracino B, Gomellini S, et al. A prospective phase III randomized trial of hypofractionation versus conventional fractionation in patients with high-risk prostate cancer. Int J Radiat Oncol Biol Phys. 2010;78(1):11-8. [pmid: 20047800].
Arcangeli G, Strigari L, Arcangeli S, et al. Retrospective comparison of external beam radiotherapy and radical prostatectomy in high-risk, clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. 2009;75(4):975-82. [pmid: 19395188].
Armstrong AJ, Creel P, Turnbull J, et al. A phase I-II study of docetaxel and atrasentan in men with castration-resistant metastatic prostate cancer. Clin Cancer Res. 2008;14(19):6270-6. [pmid: 18829508].
Armstrong AJ, Garrett-Mayer E, Ou Yang YC, et al. Prostate-specific antigen and pain surrogacy analysis in metastatic hormone-refractory prostate cancer. J Clin Oncol. 2007;25(25):3965-70. [pmid: 17761981].
Armstrong AJ, Garrett-Mayer ES, Yang YC, et al. A contemporary prognostic nomogram for men with hormone-refractory metastatic prostate cancer: a TAX327 study analysis. Clin Cancer Res. 2007;13(21):6396-403. [pmid: 17975152].
Armstrong AJ, Tannock IF, de Wit R, et al. The development of risk groups in men with metastatic castration-resistant prostate cancer based on risk factors for PSA decline and survival. Eur J Cancer. 2010;46(3):517-25. [pmid: 20005697].
Aronson WJ, Barnard RJ, Freedland SJ, et al. Growth inhibitory effect of low fat diet on prostate cancer cells: results of a prospective, randomized dietary intervention trial in men with prostate cancer. J Urol. 2010;183(1):345-50. [pmid: 19914662].
Ashley RA, Inman BA, Routh JC, et al. Preventing pain during office biopsy of the prostate: a single center, prospective, double-blind, 3-arm, parallel group, randomized clinical trial. Cancer. 2007;110(8):1708-14. [pmid: 17724727].
Auvinen A, Raitanen J, Moss S, et al. Test sensitivity in the European prostate cancer screening trial: results from Finland, Sweden, and the Netherlands. Cancer Epidemiol Biomarkers Prev. 2009;18(7):2000-5. [pmid: 19567505].
Baade PD, Aitken JF, Ferguson M, et al. Diagnostic and treatment pathways for men with prostate cancer in Queensland: investigating spatial and demographic inequalities. BMC Cancer. 2010;10:452. [pmid: 20731875].
Barbosa RA, da Silva CD, Torniziello MY, et al. A comparative study among three techniques of general anesthesia for ultrasound-guided transrectal prostate biopsy. Rev Bras Anestesiol. 2010;60(5):457-65. [pmid: 20863926].
Barry MJ. Screening for prostate cancer—the controversy that refuses to die. N Engl J Med. 2009;360(13):1351-4. [pmid: 19297564].
Barry MJ, Mulley AJ Jr. Why are a high overdiagnosis probability and a long lead time for prostate cancer screening so important?. J Natl Cancer Inst. 2009;101(6):362-3. [pmid: 19276451].
Bass R, Perry B, Langenstroer P, et al. Effects of short-term finasteride on apoptotic factors and androgen receptors in prostate cancer cells. J Urol. 2009;181(2):615-9. [pmid: 19091346].
Beer TM, Lalani AS, Lee S, et al. C-reactive protein as a prognostic marker for men with androgen-independent prostate cancer: results from the ASCENT trial. Cancer. 2008;112(11):2377-83. [pmid: 18428198].
Beer TM, Ryan CW, Venner PM, et al. Intermittent chemotherapy in patients with metastatic androgen-independent prostate cancer: results from ASCENT, a double-blinded, randomized comparison of high-dose calcitriol plus docetaxel with placebo plus docetaxel. Cancer. 2008;112(2):326-30. [pmid: 17960793].
Benchikh A, Savage C, Cronin A, et al. A panel of kallikrein markers can predict outcome of prostate biopsy following clinical work-up: an independent validation study from the European Randomized Study of Prostate Cancer Screening, France. BMC Cancer. 2010;10:635. [pmid: 21092177].
Berg A, Dahl AA, Bruland OS, et al. Definitive radiotherapy with adjuvant long-term antiandrogen treatment for locally advanced prostate cancer: health-related quality of life and hormonal changes. Prostate Cancer Prostatic Dis. 2009;12(3):269-76. [pmid: 19290019].
Bergdahl AG, Aus G, Lilja H, Hugosson J. Risk of dying from prostate cancer in men randomized to screening: differences between attendees and nonattendees. Cancer. 2009;115(24):5672-9. [pmid: 19813273].
Berthold DR, Pond GR, de Wit R, et al. Survival and PSA response of patients in the TAX 327 study who crossed over to receive docetaxel after mitoxantrone or vice versa. Ann Oncol. 2008;19(10):1749-53. [pmid: 18487550].
Berthold DR, Pond GR, Roessner M, et al. Treatment of hormone-refractory prostate cancer with docetaxel or mitoxantrone: relationships between prostate-specific antigen, pain, and quality of life response and survival in the TAX-327 study. Clin Cancer Res. 2008;14(9):2763-7. [pmid: 18451243].
Berthold DR, Pond GR, Soban F, et al. Docetaxel plus prednisone or mitoxantrone plus prednisone for advanced prostate cancer: updated survival in the TAX 327 study. J Clin Oncol. 2008;26(2):242-5. [pmid: 18182665].
Bill-Axelson A, Holmberg L, Ruutu M, et al. Radical prostatectomy versus watchful waiting in early prostate cancer. N Engl J Med. 2011;364(18):1708-17. [pmid: 21542742].
Bill-Axelson A, Holmberg L, Filen F, et al. Radical prostatectomy versus watchful waiting in localized prostate cancer: the Scandinavian Prostate Cancer Group-4 randomized trial. J Natl Cancer Inst. 2008;100(16):1144-54. [pmid: 18695132].
Bittner N, Wallner K, Merrick G, et al. The time gap between Pd-103 prostate brachytherapy and supplemental beam radiation does not impact on rectal morbidity or likelihood of cure. Am J Clin Oncol. 2008;31(3):231-6. [pmid: 18525300].
Black PC, Basen-Engquist K, Wang X, et al. A randomized prospective trial evaluating testosterone, haemoglobin kinetics and quality of life, during and after 12 months of androgen deprivation after prostatectomy: results from the Postoperative Adjuvant Androgen Deprivation trial. BJU Int. 2007;100(1):63-9. [pmid: 17552954].
Boccardo F, Rubagotti A, Conti G, et al. Prednisone plus gefitinib versus prednisone plus placebo in the treatment of hormone-refractory prostate cancer: a randomized phase II trial. Oncology. 2008;74(3–4):223-8. [pmid: 18714171].
Bolla M, Van Tienhoven G, Warde P, et al. External irradiation with or without long-term androgen suppression for prostate cancer with high metastatic risk: 10-year results of an EORTC randomised study. Lancet Oncol. 2010;11(11):1066-73. [pmid: 20933466].
Bostancic C, Merrick GS, Butler WM, et al. Isotope and patient age predict for PSA spikes after permanent prostate brachytherapy. Int J Radiat Oncol Biol Phys. 2007;68(5):1431-7. [pmid: 17544597].
Bostwick DG, Qian J, Drewnowska K, et al. Prostate needle biopsy quality in reduction by dutasteride of prostate cancer events study: worldwide comparison of improvement with investigator training and centralized laboratory processing. Urology. 2010;75(6):1406-10. [pmid: 19942263].
Brown JE, McCloskey EV, Dewar JA, et al. The use of bone markers in a 6-week study to assess the efficacy of oral clodronate in patients with metastatic bone disease. Calcif Tissue Int. 2007;81(5):341-51. [pmid: 17874331].
Buettner F, Gulliford SL, Webb S, et al. Assessing correlations between the spatial distribution of the dose to the rectal wall and late rectal toxicity after prostate radiotherapy: an analysis of data from the MRC RT01 trial. Phys Med Biol. 2009;54(21):6535-48. [pmid: 19826203].
Caffo O, Sava T, Comploj E, et al. Docetaxel, with or without estramustine phosphate, as first-line chemotherapy for hormone-refractory prostate cancer: results of a multicentre, randomized phase II trial. BJU Int. 2008;102(9):1080-5. [pmid: 18485028].
Calais da Silva FE, Bono AV, Whelan P, et al. Intermittent androgen deprivation for locally advanced and metastatic prostate cancer: results from a randomised phase 3 study of the South European Uroncological Group. Eur Urol. 2009;55(6):1269-77. [pmid: 19249153].
Cam K, Kayikci A, Akman Y, Erol A. Prospective assessment of the efficacy of single dose versus traditional 3-day antimicrobial prophylaxis in 12-core transrectal prostate biopsy. Int J Urol. 2008;15(11):997-1001. [pmid: 18721198].
Cantiello F, Imperatore V, Iannuzzo M, et al. Periprostatic nerve block (PNB) alone vs PNB combined with an anaesthetic-myorelaxant agent cream for prostate biopsy: a prospective, randomized double-arm study. BJU Int. 2009;103(9):1195-8. [pmid: 19021624].
Carducci MA, Saad F, Abrahamsson PA, et al. A phase 3 randomized controlled trial of the efficacy and safety of atrasentan in men with metastatic hormone-refractory prostate cancer. Cancer. 2007;110(9):1959-66. [pmid: 17886253].
Carlsson S, Aus G, Wessman C, Hugosson J. Anxiety associated with prostate cancer screening with special reference to men with a positive screening test (elevated PSA): results from a prospective, population-based, randomised study. Eur J Cancer. 2007;43(14):2109-16. [pmid: 17643983].
Carmody J, Olendzki B, Reed G, et al. A dietary intervention for recurrent prostate cancer after definitive primary treatment: results of a randomized pilot trial. Urology. 2008;72(6):1324-8. [pmid: 18400281].
Cavadas V, Osorio L, Sabell F, et al. Prostate cancer prevention trial and European randomized study of screening for prostate cancer risk calculators: a performance comparison in a contemporary screened cohort. Eur Urol. 2010;58(4):551-8. [pmid: 20580483].
Chakravarti A, DeSilvio M, Zhang M, et al. Prognostic value of p16 in locally advanced prostate cancer: a study based on Radiation Therapy Oncology Group Protocol 9202. J Clin Oncol. 2007;25(21):3082-9. [pmid: 17634487].
Chambers SK, Ferguson M, Gardiner RA, et al. ProsCan for men: randomised controlled trial of a decision support intervention for men with localised prostate cancer. BMC Cancer. 2008;8:207. [pmid: 18651985].
Chambers SK, Schover L, Halford K, et al. ProsCan for couples: randomised controlled trial of a couples-based sexuality intervention for men with localised prostate cancer who receive radical prostatectomy. BMC Cancer. 2008;8:226. [pmid: 18687149].
Chavarro JE, Stampfer MJ, Campos H, et al. A prospective study of trans-fatty acid levels in blood and risk of prostate cancer. Cancer Epidemiol Biomarkers Prev. 2008;17(1):95-101. [pmid: 18199715].
Che M, DeSilvio M, Pollack A, et al. Prognostic value of abnormal p53 expression in locally advanced prostate cancer treated with androgen deprivation and radiotherapy: a study based on RTOG 9202. Int J Radiat Oncol Biol Phys. 2007;69(4):1117-23. [pmid: 17689883].
Chelladurai AJ, Gunendran T, Nicholson C, et al. The economic and workload impact of “backdoor” prostate-specific antigen screening on the UK National Health Service: a single-centre experience. BJU Int. 2008;101(3):289-92. [pmid: 18184326].
Chi KN, Hotte SJ, Yu EY, et al. Randomized phase II study of docetaxel and prednisone with or without OGX-011 in patients with metastatic castration-resistant prostate cancer. J Clin Oncol. 2010;28(27):4247-54. [pmid: 20733135].
Chin JL, Ng CK, Touma NJ, et al. Randomized trial comparing cryoablation and external beam radiotherapy for T2C-T3B prostate cancer. Prostate Cancer Prostatic Dis. 2008;11(1):40-5. [pmid: 17579613].
Cho JE, Shim JK, Chang JH, et al. Effect of nicardipine on renal function after robot-assisted laparoscopic radical prostatectomy. Urology. 2009;73(5):1056-60. [pmid: 19394503].
Chu LW, Meyer TE, Li Q, et al. Association between genetic variants in the 8q24 cancer risk regions and circulating levels of androgens and sex hormone-binding globulin. Cancer Epidemiol Biomarkers Prev. 2010;19(7):1848-54. [pmid: 20551303].
Clutter Snyder D, Sloane R, Haines PS, et al. The Diet Quality Index-Revised: a tool to promote and evaluate dietary change among older cancer survivors enrolled in a home-based intervention trial. J Am Diet Assoc. 2007;107(9):1519-29. [pmid: 17761229].
Cohen YC, Liu KS, Heyden NL, et al. Detection bias due to the effect of finasteride on prostate volume: a modeling approach for analysis of the Prostate Cancer Prevention Trial. J Natl Cancer Inst. 2007;99(18):1366-74. [pmid: 17848668].
Collin SM, Metcalfe C, Donovan JL, et al. Associations of sexual dysfunction symptoms with PSA-detected localised and advanced prostate cancer: a case-control study nested within the UK population-based ProtecT (Prostate testing for cancer and Treatment) study. Eur J Cancer. 2009;45(18):3254-61. [pmid: 19541477].
Crawford ED, Grubb R 3rd, Black A, et al. Comorbidity and mortality results from a randomized prostate cancer screening trial. J Clin Oncol. 2011;29(4):355-61. [pmid: 21041707].
Crook J, Ludgate C, Malone S, et al. Final report of multicenter Canadian phase III randomized trial of 3 versus 8 months of neoadjuvant androgen deprivation therapy before conventional-dose radiotherapy for clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. 2009;73(2):327-33. [pmid: 18707821].
Crook JM, Malone S, Perry G, et al. Twenty-four-month postradiation prostate biopsies are strongly predictive of 7-year disease-free survival: results from a Canadian randomized trial. Cancer. 2009;115(3):673-9. [pmid: 19117039].
Croswell JM, Kramer BS, Kreimer AR, et al. Cumulative incidence of false-positive results in repeated, multimodal cancer screening. Ann Fam Med. 2009;7(3):212-22. [pmid: 19433838].
D’Amico AV, Chen MH, Renshaw AA, et al. Risk of prostate cancer recurrence in men treated with radiation alone or in conjunction with combined or less than combined androgen suppression therapy. J Clin Oncol. 2008;26(18):2979-83. [pmid: 18565884].
D’Amico AV, Chen MH, Renshaw AA, et al. Interval to testosterone recovery after hormonal therapy for prostate cancer and risk of death. Int J Radiat Oncol Biol Phys. 2009;75(1):10-5. [pmid: 19395184].
Danforth KN, Hayes RB, Rodriguez C, et al. Polymorphic variants in PTGS2 and prostate cancer risk: results from two large nested case-control studies. Carcinogenesis. 2008;29(3):568-72. [pmid: 17999989].
Davis JW, Chang DW, Chevray P, et al. Randomized phase II trial evaluation of erectile function after attempted unilateral cavernous nerve-sparing retropubic radical prostatectomy with versus without unilateral sural nerve grafting for clinically localized prostate cancer. Eur Urol. 2009;55(5):1135-43. [pmid: 18783876].
Davison BJ, Goldenberg SL, Wiens KP, Gleave ME. Comparing a generic and individualized information decision support intervention for men newly diagnosed with localized prostate cancer. Cancer Nurs. 2007;30(5):E7-15. [pmid: 17876177].
de Bono JS, Logothetis CJ, Molina A, et al. Abiraterone and increased survival in metastatic prostate cancer. New Engl J Med. 2011;364(21):1995-2005. [pmid: 21612468].
de Bono JS, Oudard S, Ozguroglu M, et al. Prednisone plus cabazitaxel or mitoxantrone for metastatic castration-resistant prostate cancer progressing after docetaxel treatment: a randomised open-label trial. Lancet. 2010;376(9747):1147-54. [pmid: 20888992].
de la Rosette JJ, Wink MH, Mamoulakis C, et al. Optimizing prostate cancer detection: 8- versus 12-core biopsy protocol. J Urol. 2009;182(4):1329-36. [pmid: 19683269].
Demark-Wahnefried W, Polascik TJ, George SL, et al. Flaxseed supplementation (not dietary fat restriction) reduces prostate cancer proliferation rates in men presurgery. Cancer Epidemiol Biomarkers Prev. 2008;17(12):3577-87. [pmid: 19064574].
Denham JW, Kumar M, Gleeson PS, et al. Recognizing false biochemical failure calls after radiation with or without neo-adjuvant androgen deprivation for prostate cancer. Int J Radiat Oncol Biol Phys. 2009;74(2):404-11. [pmid: 19176272].
Denham JW, Lamb DS, Joseph D, et al. PSA response signatures: a powerful new prognostic indicator after radiation for prostate cancer?. Radiother Oncol. 2009;90(3):382-8. [pmid: 18992951].
Denham JW, Steigler A, Kumar M, et al. Measuring time to biochemical failure in the TROG 96.01 trial: when should the clock start ticking?. Int J Radiat Oncol Biol Phys. 2009;75:1008-12. [pmid: 19577859].
deVere White RW, Tsodikov A, Stapp EC, et al. Effects of a high dose, aglycone-rich soy extract on prostate-specific antigen and serum isoflavone concentrations in men with localized prostate cancer. Nutr Cancer. 2010;62(8):1036-43. [pmid: 21058191].
Di Lorenzo G, Figg WD, Fossa SD, et al. Combination of bevacizumab and docetaxel in docetaxel-pretreated hormone-refractory prostate cancer: a phase 2 study. Eur Urol. 2008;54(5):1089-94. [pmid: 18276061].
DiPaola RS, Chen YH, Stein M, et al. A randomized phase II trial of mitoxantrone, estramustine and vinorelbine or bcl-2 modulation with 13-cis retinoic acid, interferon and paclitaxel in patients with metastatic castrate-resistant prostate cancer: ECOG 3899. J Transl Med. 2010;8:20. [pmid: 20178647].
Draisma G, Etzioni R, Tsodikov A, et al. Lead time and overdiagnosis in prostate-specific antigen screening: importance of methods and context. J Natl Cancer Inst. 2009;101(6):374-83. [pmid: 19276453].
Dreicer R, Stadler WM, Ahmann FR, et al. MVA-MUC1-IL2 vaccine immunotherapy (TG4010) improves PSA doubling time in patients with prostate cancer with biochemical failure. Invest New Drugs. 2009;27(4):379-86. [pmid: 18931824].
Drewa T. Re: Schroder FH, Kurth K, Fossa SD, et al. Early versus delayed endocrine treatment of T2-T3 pN1-3 M0 prostate cancer without local treatment of the primary tumour: final results of European Organisation for the Research and Treatment of Cancer protocol 30846 after 13 years of follow-up (a randomised controlled trial) [letter]. Eur Urol. 2009;55(5):e82-3. [pmid: 18950934].
Efstathiou JA, Bae K, Shipley WU, et al. Obesity and mortality in men with locally advanced prostate cancer: analysis of RTOG 85-31. Cancer. 2007;110(12):2691-9. [pmid: 17999404].
Efstathiou JA, Chen MH, Renshaw AA, et al. Influence of body mass index on prostate-specific antigen failure after androgen suppression and radiation therapy for localized prostate cancer. Cancer. 2007;109(8):1493-8. [pmid: 17340594].
Ellison GL, Weinrich SP, Lou M, et al. A randomized trial comparing web-based decision aids on prostate cancer knowledge for African-American men. J Natl Med Assoc. 2008;100:1139-45. [pmid: 18942274].
Emerson JS, Reece MC, Levine RS, et al. Predictors of new screening for African American men participating in a prostate cancer educational program. J Cancer Educ. 2009;24(4):341-5. [pmid: 19838896].
Ersoy H, Yigitbasi O, Sagnak L, et al. Comparison of three different chemotherapy regimens containing epirubicin in hormone-refractory prostate cancer patients. ScientificWorldJournal. 2008;8:586-97. [pmid: 18604442].
Evans R, Elwyn G, Edwards A, et al. A randomised controlled trial of the effects of a web-based PSA decision aid, Prosdex: protocol. BMC Fam Pract. 2007;8:58. [pmid: 17916259].
Evans R, Joseph-Williams N, Edwards A, et al. Supporting informed decision making for prostate specific antigen (PSA) testing on the web: an online randomized controlled trial. J Med Internet Res. 2010;12(3):e27. [pmid: 20693148].
Eymard JC, Priou F, Zannetti A, et al. Randomized phase II study of docetaxel plus estramustine and single-agent docetaxel in patients with metastatic hormone-refractory prostate cancer. Ann Oncol. 2007;18(6):1064-70. [pmid: 17434899].
Feyerabend S, Stevanovic S, Gouttefangeas C, et al. Novel multi-peptide vaccination in Hla-A2+ hormone sensitive patients with biochemical relapse of prostate cancer. Prostate. 2009;69(9):917-27. [pmid: 19267352].
Fizazi K, Bosserman L, Gao G, et al. Denosumab treatment of prostate cancer with bone metastases and increased urine N-telopeptide levels after therapy with intravenous bisphosphonates: results of a randomized phase II trial. J Urol. 2009;182(2):509-15. [pmid: 19524963].
Fizazi K, Carducci M, Smith M, et al. Denosumab versus zoledronic acid for treatment of bone metastases in men with castration-resistant prostate cancer: a randomised, double-blind study. Lancet. 2011;377(9768):813-22. [pmid: 21353695].
Fizazi K, Lipton A, Mariette X, et al. Randomized phase II trial of denosumab in patients with bone metastases from prostate cancer, breast cancer, or other neoplasms after intravenous bisphosphonates. J Clin Oncol. 2009;27(10):1564-71. [pmid: 19237632].
Flaig TW, Tangen CM, Hussain MH, et al. Randomization reveals unexpected acute leukemias in Southwest Oncology Group prostate cancer trial. J Clin Oncol. 2008;26(9):1532-6. [pmid: 18349405].
Ford ME, Havstad SL, Fields ME, et al. Effects of baseline comorbidities on cancer screening trial adherence among older African American men. Cancer Epidemiol Biomarkers Prev. 2008;17(5):1234-9. [pmid: 18463399].
Fossa SD. A randomized phase II trial comparing weekly taxotere plus prednisolone versus prednisolone alone in androgen-independent prostate cancer. Front Radiat Ther Oncol. 2008;41:108-16. [pmid: 18544992].
Fradet Y, Egerdie B, Andersen M, et al. Tamoxifen as prophylaxis for prevention of gynaecomastia and breast pain associated with bicalutamide 150 mg monotherapy in patients with prostate cancer: a randomised, placebo-controlled, dose-response study. Eur Urol. 2007;52(1):106-14. [pmid: 17270340].
Frank MO, Kaufman J, Tian S, et al. Harnessing naturally occurring tumor immunity: a clinical vaccine trial in prostate cancer. PLoS One. 2010;5(9).
Frattaroli J, Weidner G, Dnistrian AM, et al. Clinical events in prostate cancer lifestyle trial: results from two years of follow-up. Urology. 2008;72(6):1319-23. [pmid: 18602144].
Frosch DL, Bhatnagar V, Tally S, et al. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
Gallina A, Chun FK, Briganti A, et al. Development and split-sample validation of a nomogram predicting the probability of seminal vesicle invasion at radical prostatectomy. Eur Urol. 2007;52(1):98-105. [pmid: 17267098].
Giannarini G, Autorino R, Valent F, et al. Combination of perianal-intrarectal lidocaine-prilocaine cream and periprostatic nerve block for pain control during transrectal ultrasound guided prostate biopsy: a randomized, controlled trial. J Urol. 2009;181(2):585-91. [pmid: 19084860].
Gittelman M, Pommerville PJ, Persson BE, et al. A 1-year, open label, randomized phase II dose finding study of degarelix for the treatment of prostate cancer in North America. J Urol. 2008;180(5):1986-92. [pmid: 18801505].
Gontero P. Editorial comment on: Randomized phase II trial evaluation of erectile function after attempted unilateral cavernous nerve-sparing retropubic radical prostatectomy with versus without unilateral sural nerve grafting for clinically localized prostate cancer. Eur Urol. 2009;55(5):1144. [pmid: 18783874].
Gosselaar C, Kranse R, Roobol MJ, et al. The interobserver variability of digital rectal examination in a large randomized trial for the screening of prostate cancer. Prostate. 2008;68(9):985-93. [pmid: 18409186].
Gosselaar C, Roobol MJ, Roemeling S, Schroder FH. The role of the digital rectal examination in subsequent screening visits in the European Randomized Study of Screening for Prostate Cancer (ERSPC), Rotterdam. Eur Urol. 2008;54(3):581-8. [pmid: 18423977].
Gosselaar C, Roobol MJ, Roemeling S, et al. The value of an additional hypoechoic lesion-directed biopsy core for detecting prostate cancer. BJU Int. 2008;101(6):685-90. [pmid: 18291017].
Grainger EM, Schwartz SJ, Wang S, et al. A combination of tomato and soy products for men with recurring prostate cancer and rising prostate specific antigen. Nutr Cancer. 2008;60(2):145-54. [pmid: 18444145].
Gravina GL, Festuccia C, Galatioto GP, et al. Surgical and biologic outcomes after neoadjuvant bicalutamide treatment in prostate cancer. Urology. 2007;70(4):728-33. [pmid: 17991545].
Griffith K, Wenzel J, Shang J, et al. Impact of a walking intervention on cardiorespiratory fitness, self-reported physical function, and pain in patients undergoing treatment for solid tumors. Cancer. 2009;115(20):4874-84. [pmid: 19637345].
Grubb RL 3rd, Black A, Izmirlian G, et al. Serum prostate-specific antigen hemodilution among obese men undergoing screening in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Cancer Epidemiol Biomarkers Prev. 2009;18(3):748-51. [pmid: 19258472].
Grubb RL 3rd, Pinsky PF, Greenlee RT, et al. Prostate cancer screening in the Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial: update on findings from the initial four rounds of screening in a randomized trial. BJU Int. 2008;102(11):1524-30. [pmid: 19035857].
Gulley JL, Aragon-Ching JB, Steinberg SM, et al. Kinetics of serum androgen normalization and factors associated with testosterone reserve after limited androgen deprivation therapy for nonmetastatic prostate cancer. J Urol. 2008;180(4):1432-7. [pmid: 18710748].
Gulley JL, Arlen PM, Madan RA, et al. Immunologic and prognostic factors associated with overall survival employing a poxviral-based PSA vaccine in metastatic castrate-resistant prostate cancer. Cancer Immunol Immunother. 2010;59(5):663-74. [pmid: 19890632].
Gulliford SL, Foo K, Morgan RC, et al. Dose-volume constraints to reduce rectal side effects from prostate radiotherapy: evidence from MRC RT01 Trial ISRCTN 47772397. Int J Radiat Oncol Biol Phys. 2010;76(3):747-54. [pmid: 19540054].
Hadaschik BA, Ettinger S, Sowery RD, et al. Targeting prostate cancer with HTI-286, a synthetic analog of the marine sponge product hemiasterlin. Int J Cancer. 2008;122(10):2368-76. [pmid: 18240145].
Hamilton-Reeves JM, Rebello SA, Thomas W, et al. Effects of soy protein isolate consumption on prostate cancer biomarkers in men with HGPIN, ASAP, and low-grade prostate cancer. Nutr Cancer. 2008;60(1):7-13. [pmid: 18444130].
Hara R, Jo Y, Fujii T, et al. Optimal approach for prostate cancer detection as initial biopsy: prospective randomized study comparing transperineal versus transrectal systematic 12-core biopsy. Urology. 2008;71(2):191-5. [pmid: 18308081].
Haseen F, Murray LJ, O’Neill RF, et al. A randomised controlled trial to evaluate the efficacy of a 6 month dietary and physical activity intervention for prostate cancer patients receiving androgen deprivation therapy. Trials. 2010;11:86. [pmid: 20704726].
Hedlund PO, Damber JE, Hagerman I, et al. Parenteral estrogen versus combined androgen deprivation in the treatment of metastatic prostatic cancer, part 2: final evaluation of the Scandinavian Prostatic Cancer Group (SPCG) study no. 5. Scand J Urol Nephrol. 2008;42(3):220-9. [pmid: 18432528].
Heemsbergen WD, Al-Mamgani A, Witte MG, et al. Urinary obstruction in prostate cancer patients from the Dutch trial (68 Gy vs. 78 Gy): relationships with local dose, acute effects, and baseline characteristics. Int J Radiat Oncol Biol Phys. 2010;78(1):19-25. [pmid: 20056354].
Heemsbergen WD, Hoogeman MS, Witte MG, et al. Increased risk of biochemical and clinical failure for prostate patients with a large rectum at radiotherapy planning: results from the Dutch trial of 68 GY versus 78 Gy. Int J Radiat Oncol Biol Phys. 2007;67(5):1418-24. [pmid: 17241751].
Herranz Amo F, Jara Rascon J, Cancho Gil MJ, et al. Effectiveness of two ultrasound-guided transrectal biopsy schemes in the diagnosis of prostate cancer: a randomized study. Arch Esp Urol. 2010;63(2):107-16. [pmid: 20354275].
Herstein A, Wallner K, Merrick G, et al. There is a wide range of predictive dosimetric factors for I-125 and pd-103 prostate brachytherapy. Am J Clin Oncol. 2008;31(1):6-10. [pmid: 18376221].
Higano CS, Schellhammer PF, Small EJ, et al. Integrated data from 2 randomized, double-blind, placebo-controlled, phase 3 trials of active cellular immunotherapy with sipuleucel-T in advanced prostate cancer. Cancer. 2009;115(16):3670-9. [pmid: 19536890].
Higashihara E, Itomura M, Terachi T, et al. Effects of eicosapentaenoic acid on biochemical failure after radical prostatectomy for prostate cancer. In Vivo. 2010;24(4):561-5. [pmid: 20668324].
Hiros M, Selimovic M, Spahovic H, et al. Transrectal ultrasound-guided prostate biopsy, periprostatic local anesthesia and pain tolerance. Bosn J Basic Med Sci. 2010;10(1):68-72. [pmid: 20192935].
Hocking WG, Hu P, Oken MM, et al. Lung cancer screening in the randomized Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial. J Natl Cancer Inst. 2010;102(10):722-31. [pmid: 20442215].
Hoffman RM, Couper MP, Zikmund-Fisher BJ, et al. Prostate cancer screening decisions: results from the National Survey of Medical Decisions (DECISIONS study). Arch Intern Med. 2009;169(17):1611-8. [pmid: 19786681].
Holmstrom B, Johansson M, Bergh A, et al. Prostate specific antigen for early detection of prostate cancer: longitudinal study. BMJ. 2009;339:b3537. [pmid: 19778969].
Holt CL, Wynn TA, Litaker MS, et al. A comparison of a spiritually based and non-spiritually based educational intervention for informed decision making for prostate cancer screening among church-attending African-American men. Urol Nurs. 2009;29(4):249-58. [pmid: 19718941].
Hoque A, Ambrosone CB, Till C, et al. Serum oxidized protein and prostate cancer risk within the Prostate Cancer Prevention Trial. Cancer Prev Res (Phila). 2010;3(4):478-83. [pmid: 20332306].
Horti J, Widmark A, Stenzl A, et al. A randomized, double-blind, placebo-controlled phase II study of vandetanib plus docetaxel/prednisolone in patients with hormone-refractory prostate cancer. Cancer Biother Radiopharm. 2009;24(2):175-80. [pmid: 19409038].
Hosseini SY, Moharramzadeh M, Ghadian AR, et al. Population-based screening for prostate cancer by measuring total serum prostate-specific antigen in Iran. Int J Urol. 2007;14(5):406-11. [pmid: 17511722].
Howard K, Barratt A, Mann GJ, Patel MI. A model of prostate-specific antigen screening outcomes for low- to high-risk men: information to support informed choices. Arch Intern Med. 2009;169(17):1603-10. [pmid: 19786680].
Hu JC, Gu X, Lipsitz SR, et al. Comparative effectiveness of minimally invasive vs open radical prostatectomy. JAMA. 2009;302(14):1557-64. [pmid: 19826025].
Huang SH, Catton C, Jezioranski J, et al. The effect of changing technique, dose, and PTV margin on therapeutic ratio during prostate radiotherapy. Int J Radiat Oncol Biol Phys. 2008;71(4):1057-64. [pmid: 18339487].
Huang WY, Hayes R, Pfeiffer R, et al. Sexually transmissible infections and prostate cancer risk. Cancer Epidemiol Biomarkers Prev. 2008;17(9):2374-81. [pmid: 18768506].
Husaini BA, Reece MC, Emerson JS, et al. A church-based program on prostate cancer screening for African American men: reducing health disparities. Ethn Dis. 2008;18(Suppl 2):S179-84.
Hussain M, Goldman B, Tangen C, et al. Prostate-specific antigen progression predicts overall survival in patients with metastatic prostate cancer: data from Southwest Oncology Group Trials 9346 (Intergroup Study 0162) and 9916. J Clin Oncol. 2009;27(15):2450-6. [pmid: 19380444].
Ide H, Tokiwa S, Sakamaki K, et al. Combined inhibitory effects of soy isoflavones and curcumin on the production of prostate-specific antigen. Prostate. 2010;70(10):1127-33. [pmid: 20503397].
Ignatoski KM, Friedman J, Escara-Wilke J, et al. Change in markers of bone metabolism with chemotherapy for advanced prostate cancer: interleukin-6 response is a potential early indicator of response to therapy. J Interferon Cytokine Res. 2009;29(2):105-12. [pmid: 19014338].
Ilic D, Egberts K, McKenzie JE, et al. Informing men about prostate cancer screening: a randomized controlled trial of patient education materials. J Gen Intern Med. 2008;23(4):466-71. [pmid: 18373146].
Inal GH, Oztekin VC, Ugurlu O, et al. Sixteen gauge needles improve specimen quality but not cancer detection rate in transrectal ultrasound-guided 10-core prostate biopsies. Prostate Cancer Prostatic Dis. 2008;11(3):270-3. [pmid: 18521101].
James ND, Caty A, Borre M, et al. Safety and efficacy of the specific endothelin-A receptor antagonist ZD4054 in patients with hormone-resistant prostate cancer and bone metastases who were pain free or mildly symptomatic: a double-blind, placebo-controlled, randomised, phase 2 trial. Eur Urol. 2009;55(5):1112-23. [pmid: 19042080].
Jegu J, Tretarre B, Grosclaude P, et al. Results and participation factors to the European Randomized Study of Screening for Prostate Cancer (ERSPC) with prostate specific antigen: French departments of Tarn and Herault [French]. Prog Urol. 2009;19(7):487-98. [pmid: 19559380].
Jiang W, Freidlin B, Simon R. Biomarker-adaptive threshold design: a procedure for evaluating treatment with possible biomarker-defined subset effect. J Natl Cancer Inst. 2007;99(13):1036-43. [pmid: 17596577].
Johansson E, Bill-Axelson A, Holmberg L, et al. Time, symptom burden, androgen deprivation, and self-assessed quality of life after radical prostatectomy or watchful waiting: the Randomized Scandinavian Prostate Cancer Group Study Number 4 (SPCG-4) clinical trial. Eur Urol. 2009;55(2):422-30. [pmid: 18783877].
Joseph-Williams N, Evans R, Edwards A, et al. Supporting informed decision making online in 20 minutes: an observational web-log study of a PSA test decision aid. J Med Internet Res. 2010;12(2):e15. [pmid: 20507844].
Joshi N, de Blok W, van Muilekom E, van der Poel H. Impact of posterior musculofascial reconstruction on early continence after robot-assisted laparoscopic radical prostatectomy: results of a prospective parallel group trial. Eur Urol. 2010;58(1):84-9. [pmid: 20362386].
Kandirali E, Ulukaradag E, Uysal B, et al. Is only perianal anesthesia with lidocaine-prilocaine cream sufficient to decrease the pain during transrectal ultrasound-guided prostate biopsy? A prospective randomized study. Urol Int. 2009;82(3):262-5. [pmid: 19440010].
Kang D, Lee KM, Park SK, et al. Functional variant of manganese superoxide dismutase (SOD2 V16A) polymorphism is associated with prostate cancer risk in the Prostate, Lung, Colorectal, and Ovarian Cancer Study. Cancer Epidemiol Biomarkers Prev. 2007;16(8):1581-6. [pmid: 17646272].
Kantoff PW, Schuetz TJ, Blumenstein BA, et al. Overall survival analysis of a phase II randomized controlled trial of a poxviral-based PSA-targeted immunotherapy in metastatic castration-resistant prostate cancer. J Clin Oncol. 2010;28(7):1099-105. [pmid: 20100959].
Kaplan SA, Roehrborn CG, Meehan AG, et al. PCPT: evidence that finasteride reduces risk of most frequently detected intermediate- and high-grade (Gleason score 6 and 7) cancer. Urology. 2009;73(5):935-9. [pmid: 19328538].
Kapur G, Windsor PM, McCowan C. The effect of aerobic exercise on treatment-related acute toxicity in men receiving radical external beam radiotherapy for localised prostate cancer. Eur J Cancer Care (Engl). 2010;19(5):643-7. [pmid: 20030701].
Katsanos KH, Briasoulis E, Tsekeris P, et al. Randomized phase II exploratory study of prophylactic amifostine in cancer patients who receive radical radiotherapy to the pelvis. J Exp Clin Cancer Res. 2010;29:68. [pmid: 20537164].
Keizman D, Zahurak M, Sinibaldi V, et al. Lenalidomide in nonmetastatic biochemically relapsed prostate cancer: results of a phase I/II double-blinded, randomized study. Clin Cancer Res. 2010;16(21):5269-76. [pmid: 20978144].
Kerfoot BP, Lawler EV, Sokolovskaya G, et al. Durable improvements in prostate cancer screening from online spaced education a randomized controlled trial. Am J Prev Med. 2010;39(5):472-8. [pmid: 20965387].
Kerkhof M, Roobol MJ, Cuzick J, et al. Effect of the correction for noncompliance and contamination on the estimated reduction of metastatic prostate cancer within a randomized screening trial (ERSPC section Rotterdam). Int J Cancer. 2010;127(11):2639-44. [pmid: 20196067].
Kerns JW, Krist AH, Woolf SH, et al. Patient perceptions of how physicians communicate during prostate cancer screening discussions: a comparison of residents and faculty. Fam Med. 2008;40(3):181-7. [pmid: 18320396].
Khasraw M, Pavlakis N, McCowatt S, et al. Multicentre phase I/II study of PI-88, a heparanase inhibitor in combination with docetaxel in patients with metastatic castrate-resistant prostate cancer. Ann Oncol. 2010;21(6):1302-7. [pmid: 19917571].
Khor LY, Bae K, Paulus R, et al. MDM2 and Ki-67 predict for distant metastasis and mortality in men treated with radiotherapy and androgen deprivation for prostate cancer: RTOG 92-02. J Clin Oncol. 2009;27(19):3177-84. [pmid: 19470936].
Kibel AS, Rosenbaum E, Kattan MW, et al. Adjuvant weekly docetaxel for patients with high risk prostate cancer after radical prostatectomy: a multi-institutional pilot study. J Urol. 2007;177(5):1777-81. [pmid: 17437819].
Kilpelainen TP, Tammela TL, Maattanen L, et al. False-positive screening results in the Finnish prostate cancer screening trial. Br J Cancer. 2010;102(3):469-74. [pmid: 20051951].
Klein T, Palisaar RJ, Holz A, et al. The impact of prostate biopsy and periprostatic nerve block on erectile and voiding function: a prospective study. J Urol. 2010;184(4):1447-52. [pmid: 20727540].
Klotz L, Boccon-Gibod L, Shore ND, et al. The efficacy and safety of degarelix: a 12-month, comparative, randomized, open-label, parallel-group phase III study in patients with prostate cancer. BJU Int. 2008;102(11):1531-8. [pmid: 19035858].
Kotwal S, Whelan P. Does failure of single hormone therapy delineate hormone refractoriness for prostate cancer?. Scand J Urol Nephrol. 2008;42(2):116-20. [pmid: 17907049].
Koutros S, Berndt SI, Sinha R, et al. Xenobiotic metabolizing gene variants, dietary heterocyclic amine intake, and risk of prostate cancer. Cancer Res. 2009;69(5):1877-84. [pmid: 19223546].
Krainer M, Tomek S, Elandt K, et al. A prospective, open label, randomized phase II trial of weekly docetaxel versus weekly vinorelbine as first line chemotherapy in patients with androgen independent prostate cancer. J Urol. 2007;177(6):2141-5. [pmid: 17509302].
Kripalani S, Sharma J, Justice E, et al. Low-literacy interventions to promote discussion of prostate cancer: a randomized controlled trial. Am J Prev Med. 2007;33(2):83-90. [pmid: 17673094].
Kristal AR, Arnold KB, Neuhouser ML, et al. Diet, supplement use, and prostate cancer risk: results from the prostate cancer prevention trial. Am J Epidemiol. 2010;172(5):566-77. [pmid: 20693267].
Kuban DA, Levy LB, Cheung MR, et al. Long-term failure patterns and survival in a randomized dose-escalation trial for prostate cancer: who dies of disease?. Int J Radiat Oncol Biol Phys. 2011;79(5):1310-7. [pmid: 20493642].
Kuban DA, Tucker SL, Dong L, et al. Long-term results of the M.D. Anderson randomized dose-escalation trial for prostate cancer. Int J Radiat Oncol Biol Phys. 2008;70(1):67-74. [pmid: 17765406].
Laitinen S, Martikainen PM, Tammela TL, Visakorpi T. Cellular changes in prostate cancer cells induced by intermittent androgen suppression. Eur Urol. 2007;52(3):725-32. [pmid: 17141945].
Lamb DS, Denham JW, Joseph D, et al. A comparison of the prognostic value of early PSA test-based variables following external beam radiotherapy, with or without preceding androgen deprivation: analysis of data from the TROG 96.01 randomized trial. Int J Radiat Oncol Biol Phys. 2011;79(2):385-91. [pmid: 20350786].
Langley RE, Godsland IF, Kynaston H, et al. Early hormonal data from a multicentre phase II trial using transdermal oestrogen patches as first-line hormonal therapy in patients with locally advanced or metastatic prostate cancer. BJU Int. 2008;102(4):442-5. [pmid: 18422771].
Laurila M, Tammela TL, Auvinen A, et al. Biological aggressiveness of prostate cancer in the Finnish screening trial. Int J Cancer. 2009;124(3):547-52. [pmid: 19004023].
Lawton CA, Bae K, Pilepich M, et al. Long-term treatment sequelae after external beam irradiation with or without hormonal manipulation for adenocarcinoma of the prostate: analysis of radiation therapy oncology group studies 85-31, 86-10, and 92-02. Int J Radiat Oncol Biol Phys. 2008;70(2):437-41. [pmid: 17881145].
Lee HY, Lee HJ, Byun SS, et al. Effect of intraprostatic local anesthesia during transrectal ultrasound guided prostate biopsy: comparison of 3 methods in a randomized, double-blind, placebo controlled trial. J Urol. 2007;178(2):469-72. [pmid: 17561127].
Lein M, Wirth M, Miller K, et al. Serial markers of bone turnover in men with metastatic prostate cancer treated with zoledronic acid for detection of bone metastases progression. Eur Urol. 2007;52(5):1381-7. [pmid: 17321667].
Lewis SJ, Murad A, Chen L, et al. Associations between an obesity related genetic variant (FTO rs9939609) and prostate cancer risk. PLoS One. 2010;5(10):e13485. [pmid: 20976066].
Lin DW, Neuhouser ML, Schenk JM, et al. Low-fat, low-glycemic load diet and gene expression in human prostate epithelium: a feasibility study of using cDNA microarrays to assess the response to dietary intervention in target tissues. Cancer Epidemiol Biomarkers Prev. 2007;16(10):2150-4. [pmid: 17932364].
Liu B, Lerma FA, Patel S, et al. Dosimetric effects of the prone and supine positions on image guided localized prostate cancer radiotherapy. Radiother Oncol. 2008;88(1):67-76. [pmid: 18207595].
Livingston PM, White VM, Hayman J, et al. The psychological impact of a specialist referral and telephone intervention on male cancer patients: a randomised controlled trial. Psychooncology. 2010;19(6):617-25. [pmid: 19673008].
Lucia MS, Darke AK, Goodman PJ, et al. Pathologic characteristics of cancers detected in the Prostate Cancer Prevention Trial: implications for prostate cancer detection and chemoprevention. Cancer Prev Res (Phila). 2008;1(3):167-73. [pmid: 19138952].
Lucia MS, Epstein JI, Goodman PJ, et al. Finasteride and high-grade prostate cancer in the Prostate Cancer Prevention Trial. J Natl Cancer Inst. 2007;99(18):1375-83. [pmid: 17848673].
Lu-Yao G, Albertsen PC, Stanford JL, et al. Screening, treatment, and prostate cancer mortality in the Seattle area and Connecticut: fifteen-year follow-up. J Gen Intern Med. 2008;23(11):1809-14. [pmid: 18795372].
Lu-Yao GL, Albertsen PC, Moore DF, et al. Outcomes of localized prostate cancer following conservative management. JAMA. 2009;302(11):1202-9. [pmid: 19755699].
Macefield RC, Lane JA, Metcalfe C, et al. Do the risk factors of age, family history of prostate cancer or a higher prostate specific antigen level raise anxiety at prostate biopsy?. Eur J Cancer. 2009;45(14):2569-73. [pmid: 19375907].
Machiels JP, Mazzeo F, Clausse M, et al. Prospective randomized study comparing docetaxel, estramustine, and prednisone with docetaxel and prednisone in metastatic hormone-refractory prostate cancer. J Clin Oncol. 2008;26(32):5261-8. [pmid: 18794543].
Malmi H, Ruutu M, Maattanen L, et al. Why do men opt out of prostate-cancer screening? Attitudes and perception among participants and non-participants of a screening trial. BJU Int. 2010;106(4):472-7. [pmid: 20184578].
Mao S, Daliani DD, Wang X, et al. Employing the treatment-free interval of intermittent androgen ablation to screen candidate prostate cancer therapies. Prostate. 2007;67(15):1677-85. [pmid: 17879948].
Marcella SW, Rhoads GG, Carson JL, et al. Prostate-specific antigen screening and mortality from prostate cancer. J Gen Intern Med. 2008;23(3):248-53. [pmid: 18172740].
Martella O, Galatioto GP, Pace G, et al. Periprostatic nerve block before ultrasound-guided prostate biopsy: a comparison of two local anesthetics. Arch Ital Urol Androl. 2009;81:209-11. [pmid: 20608142].
Martis G, Diana M, Ombres M, et al. Retropubic versus perineal radical prostatectomy in early prostate cancer: eight-year experience. J Surg Oncol. 2007;95(6):513-8. [pmid: 17226809].
Marzi S, Saracino B, Petrongari MG, et al. Modeling of alpha/beta for late rectal toxicity from a randomized phase II study: conventional versus hypofractionated scheme for localized prostate cancer. J Exp Clin Cancer Res. 2009;28:117. [pmid: 19689825].
Mason MD, Sydes MR, Glaholm J, et al. Oral sodium clodronate for nonmetastatic prostate cancer—results of a randomized double-blind placebo-controlled trial: Medical Research Council PR04. J Natl Cancer Inst. 2007;99(10):765-76. [pmid: 17505072].
Mathew P, Thall PF, Bucana CD, et al. Platelet-derived growth factor receptor inhibition and chemotherapy for castration-resistant prostate cancer with bone metastases. Clin Cancer Res. 2007;13(19):5816-24. [pmid: 17908974].
May M, Knoll N, Siegsmund M, et al. Validity of the CAPRA score to predict biochemical recurrence-free survival after radical prostatectomy: results from a European multicenter survey of 1,296 patients. J Urol. 2007;178(5):1957-62. [pmid: 17868719].
Mazaris EM, Varkarakis I, Chrisofos M, et al. Use of nonsteroidal anti-inflammatory drugs after radical retropubic prostatectomy: a prospective, randomized trial. Urology. 2008;72(6):1293-7. [pmid: 18329071].
McCabe JE, Hanchanale VS, Philip J, Javle PM. A randomized controlled trial of topical glyceryl trinitrate before transrectal ultrasonography-guided biopsy of the prostate. BJU Int. 2007;100(3):536-8. [pmid: 17535278].
Meyer MS, Penney KL, Stark JR, et al. Genetic variation in RNASEL associated with prostate cancer risk and progression. Carcinogenesis. 2010;31(9):1597-603. [pmid: 20576793].
Mierzwa ML, Barrett WL, Redmond K, et al. Randomized trial to assess the efficacy of intraoperative steroid use in decreasing acute urinary retention after transperineal radioactive iodine-125 implantation for prostate cancer. Cancer. 2008;113(9):2605-9. [pmid: 18816596].
Miki K, Kiba T, Sasaki H, et al. Transperineal prostate brachytherapy, using I-125 seed with or without adjuvant androgen deprivation, in patients with intermediate-risk prostate cancer: study protocol for a phase III, multicenter, randomized, controlled trial. BMC Cancer. 2010;10:572. [pmid: 20964826].
Mitterberger M, Horninger W, Pelzer A, et al. A prospective randomized trial comparing contrast-enhanced targeted versus systematic ultrasound guided biopsies: impact on prostate cancer detection. Prostate. 2007;67(14):1537-42. [pmid: 17705242].
Mohan R, Beydoun H, Barnes-Ely ML, et al. Patients’ survival expectations before localized prostate cancer treatment by treatment status. J Am Board Fam Med. 2009;22(3):247-56. [pmid: 19429730].
Montgomery RB, Goldman B, Tangen CM, et al. Association of body mass index with response and survival in men with metastatic prostate cancer: Southwest Oncology Group trials 8894 and 9916. J Urol. 2007;178(5):1946-51. [pmid: 17868721].
Moore AL, Dimitropoulou P, Lane A, et al. Population-based prostate-specific antigen testing in the UK leads to a stage migration of prostate cancer. BJU Int. 2009;104(11):1592-8. [pmid: 19549125].
Murad AS, Down L, Davey Smith G, et al. Associations of aspirin, nonsteroidal anti-inflammatory drug and paracetamol use with PSA-detected prostate cancer: findings from a large, population-based, case-control study (the ProtecT study). Int J Cancer. 2011;128:1442-8. [pmid: 20506261].
Musquera M, Fleshner NE, Finelli A, Zlotta AR. The REDUCE trial: chemoprevention in prostate cancer using a dual 5alpha-reductase inhibitor, dutasteride. Expert Rev Anticancer Ther. 2008;8(7):1073-9. [pmid: 18588452].
Nelson JB, Love W, Chin JL, et al. Phase 3, randomized, controlled trial of atrasentan in patients with nonmetastatic, hormone-refractory prostate cancer. Cancer. 2008;113(9):2478-87. [pmid: 18785254].
Neuhouser ML, Barnett MJ, Kristal AR, et al. Dietary supplement use and prostate cancer risk in the Carotene and Retinol Efficacy Trial. Cancer Epidemiol Biomarkers Prev. 2009;18(8):2202-6. [pmid: 19661078].
Nguyen PL, Chen MH, Beard CJ, et al. Radiation with or without 6 months of androgen suppression therapy in intermediate- and high-risk clinically localized prostate cancer: a postrandomization analysis by risk group. Int J Radiat Oncol Biol Phys. 2010;77(4):1046-52. [pmid: 19864082].
Nguyen PL, Chen MH, Renshaw AA, et al. Survival following radiation and androgen suppression therapy for prostate cancer in healthy older men: implications for screening recommendations. Int J Radiat Oncol Biol Phys. 2010;76(2):337-41. [pmid: 19395186].
Nguyen PL, Chen RC, Hoffman KE, et al. Rectal dose-volume histogram parameters are associated with long-term patient-reported gastrointestinal quality of life after conventional and high-dose radiation for prostate cancer: a subgroup analysis of a randomized trial. Int J Radiat Oncol Biol Phys. 2010;78(4):1081-5. [pmid: 20207497].
Nilsson S, Franzen L, Parker C, et al. Bone-targeted radium-223 in symptomatic, hormone-refractory prostate cancer: a randomised, multicentre, placebo-controlled phase II study. Lancet Oncol. 2007;8(7):587-94. [pmid: 17544845].
Norkus D, Miller A, Kurtinaitis J, et al. A randomized trial comparing hypofractionated and conventionally fractionated three-dimensional external-beam radiotherapy for localized prostate adenocarcinoma : a report on acute toxicity. Strahlenther Onkol. 2009;185(11):715-21. [pmid: 19899003].
Norkus D, Miller A, Plieskiene A, et al. A randomized trial comparing hypofractionated and conventionally fractionated three-dimensional conformal external-beam radiotherapy for localized prostate adenocarcinoma: a report on the first-year biochemical response. Medicina (Kaunas). 2009;45(6):469-75. [pmid: 19605967].
Nurani R, Wallner K, Merrick G, et al. Optimized prostate brachytherapy minimizes the prognostic impact of percent of biopsy cores involved with adenocarcinoma. J Urol. 2007;178(5):1968-73. [pmid: 17868717].
Ozen H, Akyol F, Toktas G, et al. Is prophylactic breast radiotherapy necessary in all patients with prostate cancer and gynecomastia and/or breast pain?. J Urol. 2010;184(2):519-24. [pmid: 20620411].
Panebianco V, Sciarra A, Ciccariello M, et al. Role of magnetic resonance spectroscopic imaging ([(1)H]MRSI) and dynamic contrast-enhanced MRI (DCE-MRI) in identifying prostate cancer foci in patients with negative biopsy and high levels of prostate-specific antigen (PSA). Radiol Med. 2010;115(8):1314-29. [pmid: 20852963].
Park HK, Lee KY, Kim KH, et al. Intermediate versus low or high prostate-specific antigen density level: comparison of cancer detection rate between 12- and 18-core prostate biopsy. Scand J Urol Nephrol. 2010;44(6):391-8. [pmid: 20695726].
Park JY, Park SJ, Choi SU, et al. Target-controlled propofol infusion for sedation in patients undergoing transrectal ultrasound-guided prostate biopsy. J Int Med Res. 2007;35(6):773-80. [pmid: 18034990].
Parker C, Clarke N, Logue J, et al. RADICALS (Radiotherapy and Androgen Deprivation in Combination After Local Surgery). Clin Oncol (R Coll Radiol). 2007;19(3):167-71. [pmid: 17359901].
Parsons JK, Newman VA, Mohler JL, et al. Dietary intervention after definitive therapy for localized prostate cancer: results from a pilot study. Can J Urol. 2009;16(3):4648-54. [pmid: 19497171].
Pashayan N, Pharoah P, Neal DE, et al. Stage shift in PSA-detected prostate cancers: effect modification by Gleason score. J Med Screen. 2009;16(2):98-101. [pmid: 19564523].
Pashayan N, Pharoah P, Neal DE, et al. PSA-detected prostate cancer and the potential for dedifferentiation: estimating the proportion capable of progression. Int J Cancer. 2011;128(6):1462-70. [pmid: 20499312].
Penson DF, McLerran D, Feng Z, et al. 5-year urinary and sexual outcomes after radical prostatectomy: results from the Prostate Cancer Outcomes Study. J Urol. 2008;179(5 Suppl):S40-4. [pmid: 18405749].
Penson DF, Rossignol M, Sartor AO, et al. Prostate cancer: epidemiology and health-related quality of life. Urology. 2008;72(6 Suppl):S3-11. [pmid: 19095126].
Petrioli R, Pascucci A, Conca R, et al. Docetaxel and epirubicin compared with docetaxel and prednisone in advanced castrate-resistant prostate cancer: a randomised phase II study. Br J Cancer. 2011;104(4):613-9. [pmid: 21285986].
Pili R, Rosenthal MA, Mainwaring PN, et al. Phase II study on the addition of ASA404 (vadimezan; 5,6-dimethylxanthenone-4-acetic acid) to docetaxel in CRMPC. Clin Cancer Res. 2010;16(10):2906-14. [pmid: 20460477].
Pinsky P, Parnes H, Ford L. Estimating rates of true high-grade disease in the prostate cancer prevention trial. Cancer Prev Res (Phila). 2008;1(3):182-6. [pmid: 19138954].
Pinsky PF, Crawford ED, Kramer BS, et al. Repeat prostate biopsy in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. BJU Int. 2007;99(4):775-9. [pmid: 17223921].
Pinsky PF, Ford M, Gamito E, et al. Enrollment of racial and ethnic minorities in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. J Natl Med Assoc. 2008;100(3):291-8. [pmid: 18390022].
Pinsky PF, Miller A, Kramer BS, et al. Evidence of a healthy volunteer effect in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Am J Epidemiol. 2007;165(8):874-81. [pmid: 17244633].
Pirl WF, Greer JA, Goode M, Smith MR. Prospective study of depression and fatigue in men with advanced prostate cancer receiving hormone therapy. Psychooncology. 2008;17(2):148-53. [pmid: 17443645].
Platz EA, Till C, Goodman PJ, et al. Men with low serum cholesterol have a lower risk of high-grade prostate cancer in the placebo arm of the prostate cancer prevention trial. Cancer Epidemiol Biomarkers Prev. 2009;18(11):2807-13. [pmid: 19887582].
Ploussard G, Paule B, Salomon L, et al. Pilot trial of adjuvant paclitaxel plus androgen deprivation for patients with high-risk prostate cancer after radical prostatectomy: results on toxicity, side effects and quality-of-life. Prostate Cancer Prostatic Dis. 2010;13(1):97-101. [pmid: 19935771].
Pomerantz M, Manola J, Taplin ME, et al. Phase II study of low dose and high dose conjugated estrogen for androgen independent prostate cancer. J Urol. 2007;177(6):2146-50. [pmid: 17509304].
Pommier P, Chabaud S, Lagrange JL, et al. Is there a role for pelvic irradiation in localized prostate adenocarcinoma? Preliminary results of GETUG-01. J Clin Oncol. 2007;25:5366-73. [pmid: 18048817].
Porpiglia F, Fiori C, Grande S, et al. Selective versus standard ligature of the deep venous complex during laparoscopic radical prostatectomy: effects on continence, blood loss, and margin status. Eur Urol. 2009;55(6):1377-83. [pmid: 19243886].
Postma R, Schroder FH, van Leenders GJ, et al. Cancer detection and cancer characteristics in the European Randomized Study of Screening for Prostate Cancer (ERSPC)–section Rotterdam: a comparison of two rounds of screening. Eur Urol. 2007;52(1):89-97. [pmid: 17257742].
Quillin JM, Bodurtha JN, McClish DK, et al. The effect of a school-based educational intervention on gender differences in reported family cancer history. J Cancer Educ. 2008;23(3):180-5. [pmid: 18709590].
Raaijmakers R, de Vries SH, Blijenberg BG, et al. hK2 and free PSA, a prognostic combination in predicting minimal prostate cancer in screen-detected men within the PSA range 4–10 ng/mL. Eur Urol. 2007;52(5):1358-64. [pmid: 17499425].
Raber M, Scattoni V, Roscigno M, et al. Topical prilocaine-lidocaine cream combined with peripheral nerve block improves pain control in prostatic biopsy: results from a prospective randomized trial. Eur Urol. 2008;53(5):967-73. [pmid: 17904278].
Ramirez AG, Miller AR, Gallion K, et al. Testing three different cancer genetics registry recruitment methods with Hispanic cancer patients and their family members previously registered in local cancer registries in Texas. Community Genet. 2008;11(4):215-23. [pmid: 18417969].
Ray ME, Bae K, Hussain MH, et al. Potential surrogate endpoints for prostate cancer survival: analysis of a phase III randomized trial. J Natl Cancer Inst. 2009;101(4):228-36. [pmid: 19211454].
Redman MW, Tangen CM, Goodman PJ, et al. Finasteride does not increase the risk of high-grade prostate cancer: a bias-adjusted modeling approach. Cancer Prev Res (Phila). 2008;1:174-81. [pmid: 19138953].
Reed DR, Wallner KE, Merrick GS, et al. A prospective randomized comparison of stranded vs. loose 125I seeds for prostate brachytherapy. Brachytherapy. 2007;6(2):129-34. [pmid: 17434106].
Roach M 3rd, De Silvio M, Rebbick T, et al. Racial differences in CYP3A4 genotype and survival among men treated on Radiation Therapy Oncology Group (RTOG) 9202: a phase III randomized trial. Int J Radiat Oncol Biol Phys. 2007;69(1):79-87. [pmid: 17498886].
Rochester MA, Griffin S, Chappell B, McLoughlin J. A prospective randomised trial of extended core prostate biopsy protocols utilizing 12 versus 15 cores. Urol Int. 2009;83(2):155-9. [pmid: 19752609].
Rodrigues G, Bae K, Roach M, et al. Impact of ultrahigh baseline PSA levels on biochemical and clinical outcomes in two Radiation Therapy Oncology Group prostate clinical trials. Int J Radiat Oncol Biol Phys. 2011;80(2):445-52. [pmid: 20615632].
Roemeling S, Roobol MJ, de Vries SH, et al. Active surveillance for prostate cancers detected in three subsequent rounds of a screening trial: characteristics, PSA doubling times, and outcome. Eur Urol. 2007;51(5):1244-50. [pmid: 17161520].
Roemeling S, Roobol MJ, Kattan MW, et al. Nomogram use for the prediction of indolent prostate cancer: impact on screen-detected populations. Cancer. 2007;110(10):2218-21. [pmid: 17893906].
Roemeling S, Roobol MJ, Otto SJ, et al. Feasibility study of adjustment for contamination and non-compliance in a prostate cancer screening trial. Prostate. 2007;67(10):1053-60. [pmid: 17458908].
Romero FR, Romero AW, Brenny Filho T, et al. Patients’ perceptions of pain and discomfort during digital rectal exam for prostate cancer screening. Arch Esp Urol. 2008;61(7):850-4. [pmid: 18972927].
Roobol MJ, Grenabo A, Schroder FH, Hugosson J. Interval cancers in prostate cancer screening: comparing 2- and 4-year screening intervals in the European Randomized Study of Screening for Prostate Cancer, Gothenburg and Rotterdam. J Natl Cancer Inst. 2007;99(17):1296-303. [pmid: 17728218].
Roobol MJ, Kerkhof M, Schroder FH, et al. Prostate cancer mortality reduction by prostate-specific antigen-based screening adjusted for nonattendance and contamination in the European Randomised Study of Screening for Prostate Cancer (ERSPC). Eur Urol. 2009;56(4):584-91. [pmid: 19660851].
Roobol MJ, Schroder FH, van Leeuwen P, et al. Performance of the prostate cancer antigen 3 (PCA3) gene and prostate-specific antigen in prescreened men: exploring the value of PCA3 for a first-line diagnostic test. Eur Urol. 2010;58(4):475-81. [pmid: 20637539].
Roobol MJ, Steyerberg EW, Kranse R, et al. A risk-based strategy improves prostate-specific antigen-driven detection of prostate cancer. Eur Urol. 2010;57(1):79-85. [pmid: 19733959].
Rosario DJ, Lane JA, Metcalfe C, et al. Contribution of a single repeat PSA test to prostate cancer risk assessment: experience from the ProtecT study. Eur Urol. 2008;53(4):777-84. [pmid: 18079051].
Rosenberg JE, Weinberg VK, Kelly WK, et al. Activity of second-line chemotherapy in docetaxel-refractory hormone-refractory prostate cancer patients : randomized phase 2 study of ixabepilone or mitoxantrone and prednisone. Cancer. 2007;110(3):556-63. [pmid: 17577218].
Rosenthal MA, Davidson P, Rolland F, et al. Evaluation of the safety, pharmacokinetics and treatment effects of an alpha(nu)beta(3) integrin inhibitor on bone turnover and disease activity in men with hormone-refractory prostate cancer and bone metastases. Asia Pac J Clin Oncol. 2010;6(1):42-8. [pmid: 20398037].
Ross RW, Xie W, Regan MM, et al. Efficacy of androgen deprivation therapy (ADT) in patients with advanced prostate cancer: association between Gleason score, prostate-specific antigen level, and prior ADT exposure with duration of ADT effect. Cancer. 2008;112(6):1247-53. [pmid: 18293426].
Rubel SK, Miller JW, Stephens RL, et al. Testing the effects of a decision aid for prostate cancer screening. J Health Commun. 2010;15(3):307-21. [pmid: 20432110].
Ryan CJ, Halabi S, Ou SS, et al. Adrenal androgen levels as predictors of outcome in prostate cancer patients treated with ketoconazole plus antiandrogen withdrawal: results from a cancer and leukemia group B study. Clin Cancer Res. 2007;13(7):2030-7. [pmid: 17404083].
Saad F, Chen YM, Gleason DM, Chin J. Continuing benefit of zoledronic acid in preventing skeletal complications in patients with bone metastases. Clin Genitourin Cancer. 2007;5:390-6. [pmid: 17956712].
Saad F, Eastham J. Zoledronic acid improves clinical outcomes when administered before onset of bone pain in patients with prostate cancer. Urology. 2010;76(5):1175-81. [pmid: 21056263].
Salonen AJ, Viitanen J, Lundstedt S, et al. Finnish multicenter study comparing intermittent to continuous androgen deprivation for advanced prostate cancer: interim analysis of prognostic markers affecting initial response to androgen deprivation. J Urol. 2008;180(3):915-9. [pmid: 18635219].
Sartor AO, Tangen CM, Hussain MH, et al. Antiandrogen withdrawal in castrate-refractory prostate cancer: a Southwest Oncology Group trial (SWOG 9426). Cancer. 2008;112:2393-400. [pmid: 18383517].
Sartor O, Gomella LG, Gagnier P, et al. Dutasteride and bicalutamide in patients with hormone-refractory prostate cancer: the Therapy Assessed by Rising PSA (TARP) study rationale and design. Can J Urol. 2009;16(5):4806-12. [pmid: 19796455].
Schaeffer AJ, Montorsi F, Scattoni V, et al. Comparison of a 3-day with a 1-day regimen of an extended-release formulation of ciprofloxacin as antimicrobial prophylaxis for patients undergoing transrectal needle biopsy of the prostate. BJU Int. 2007;100(1):51-7. [pmid: 17552953].
Schenk JM, Neuhouser ML, Lin DW, Kristal AR. A dietary intervention to elicit rapid and complex dietary changes for studies investigating the effects of diet on tissues collected during invasive surgical procedures. J Am Diet Assoc. 2009;109(3):459-63. [pmid: 19248862].
Schenk JM, Riboli E, Chatterjee N, et al. Serum retinol and prostate cancer risk: a nested case-control study in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Cancer Epidemiol Biomarkers Prev. 2009;18(4):1227-31. [pmid: 19336558].
Schroder FH. Screening for prostate cancer (PC): an update on recent findings of the European Randomized Study of Screening for Prostate Cancer (ERSPC). Urol Oncol. 2008;26(5):533-41. [pmid: 18774469].
Schroder FH, Bangma CH, Roobol MJ. Is it necessary to detect all prostate cancers in men with serum PSA levels <3.0 ng/mL? A comparison of biopsy results of PCPT and outcome-related information from ERSPC. Eur Urol. 2008;53(5):901-8. [pmid: 18262712].
Schroder FH, Bangma CH, Wolff JM, et al. Can dutasteride delay or prevent the progression of prostate cancer in patients with biochemical failure after radical therapy? Rationale and design of the Avodart after Radical Therapy for Prostate Cancer Study. BJU Int. 2009;103(5):590-6. [pmid: 19226424].
Schroder FH, Tombal B, Miller K, et al. Changes in alkaline phosphatase levels in patients with prostate cancer receiving degarelix or leuprolide: results from a 12-month, comparative, phase III study. BJU Int. 2010;106(2):182-7. [pmid: 19912212].
Sciarra A, Panebianco V, Ciccariello M, et al. Value of magnetic resonance spectroscopy imaging and dynamic contrast-enhanced imaging for detecting prostate cancer foci in men with prior negative biopsy. Clin Cancer Res. 2010;16(6):1875-83. [pmid: 20197480].
Sella A, Zisman A, Kovel S, et al. Neoadjuvant chemohormonal therapy in poor-prognosis localized prostate cancer. Urology. 2008;71(2):323-7. [pmid: 18308112].
Shamash J, Powles T, Sarker SJ, et al. A multi-centre randomised phase III trial of dexamethasone vs dexamethasone and diethylstilbestrol in castration-resistant prostate cancer: immediate vs deferred diethylstilbestrol. Br J Cancer. 2011;104(4):620-8. [pmid: 21285990].
Shao YH, Demissie K, Shih W, et al. Contemporary risk profile of prostate cancer in the United States. J Natl Cancer Inst. 2009;101(18):1280-3. [pmid: 19713548].
Shariat SF, Park S, Trinh QD, et al. Plasminogen activation inhibitor-1 improves the predictive accuracy of prostate cancer nomograms. J Urol. 2007;178(4 Pt 1):1229-36. [pmid: 17698116].
Sheinfeld Gorin S, Franco R, Hajiani F, Senathirajah Y. Systematic development and usability testing of a physician-based prostate cancer education program in an African American community. AMIA Annu Symp Proc. 2007;1112.
Simon JA, Tanzman JS, Sabate J. Lack of effect of walnuts on serum levels of prostate specific antigen: a brief report. J Am Coll Nutr. 2007;26(4):317-20. [pmid: 17906182].
Simoneau AR, Gerner EW, Nagle R, et al. The effect of difluoromethylornithine on decreasing prostate size and polyamines in men: results of a year-long phase IIb randomized placebo-controlled chemoprevention trial. Cancer Epidemiol Biomarkers Prev. 2008;17(2):292-9. [pmid: 18268112].
Smith MR, Bae K, Efstathiou JA, et al. Diabetes and mortality in men with locally advanced prostate cancer: RTOG 92-02. J Clin Oncol. 2008;26(26):4333-9. [pmid: 18779620].
Smith MR, Cook RJ, Coleman R, et al. Predictors of skeletal complications in men with hormone-refractory metastatic prostate cancer. Urology. 2007;70(2):315-9. [pmid: 17826496].
Snyder DC, Morey MC, Sloane R, et al. Reach Out to Enhance Wellness in Older Cancer Survivors (RENEW): design, methods and recruitment challenges of a home-based exercise and diet intervention to improve physical function among long-term survivors of breast, prostate, and colorectal cancer. Psychooncology. 2009;18(4):429-39. [pmid: 19117329].
Song Y, Tangen C, Goodman P, et al. Finasteride, prostate cancer, and weight gain: evidence for genetic or environmental factors that affect cancer outcomes during finasteride treatment. Prostate. 2008;68(3):281-6. [pmid: 18163420].
Souhami L, Bae K, Pilepich M, Sandler H. Timing of salvage hormonal therapy in prostate cancer patients with unfavorable prognosis treated with radiotherapy: a secondary analysis of Radiation Therapy Oncology Group 85-31. Int J Radiat Oncol Biol Phys. 2010;78(5):1301-6. [pmid: 20356687].
South CP, Khoo VS, Naismith O, et al. A comparison of treatment planning techniques used in two randomised UK external beam radiotherapy trials for localised prostate cancer. Clin Oncol (R Coll Radiol). 2008;20(1):15-21. [pmid: 18054471].
Spaccarotella KJ, Kris-Etherton PM, Stone WL, et al. The effect of walnut intake on factors related to prostate and vascular health in older men. Nutr J. 2008;7:13. [pmid: 18454862].
Stamatiou K, Skolarikos A, Heretis I, et al. Does educational printed material manage to change compliance with prostate cancer screening?. World J Urol. 2008;26(4):365-73. [pmid: 18421460].
Sternberg CN, Dumez H, Van Poppel H, et al. Docetaxel plus oblimersen sodium (Bcl-2 antisense oligonucleotide): an EORTC multicenter, randomized phase II study in patients with castration-resistant prostate cancer. Ann Oncol. 2009;20(7):1264-9. [pmid: 19297314].
Sternberg CN, Petrylak DP, Sartor O, et al. Multinational, double-blind, phase III study of prednisone and either satraplatin or placebo in patients with castrate-refractory prostate cancer progressing after prior chemotherapy: the SPARC trial. J Clin Oncol. 2009;27(32):5431-8. [pmid: 19805692].
Stopiglia RM, Ferreira U, Silva MM Jr, et al. Prostate specific antigen decrease and prostate cancer diagnosis: antibiotic versus placebo prospective randomized clinical trial. J Urol. 2010;183(3):940-4. [pmid: 20089269].
Stratton MS, Algotar AM, Ranger-Moore J, et al. Oral selenium supplementation has no effect on prostate-specific antigen velocity in men undergoing active surveillance for localized prostate cancer. Cancer Prev Res (Phila). 2010;3(8):1035-43. [pmid: 20647337].
Strigari L, Arcangeli G, Arcangeli S, Benassi M. Mathematical model for evaluating incidence of acute rectal toxicity during conventional or hypofractionated radiotherapy courses for prostate cancer. Int J Radiat Oncol Biol Phys. 2009;73(5):1454-60. [pmid: 18990503].
Strigari L, Marsella A, Canitano S, et al. Color Doppler quantitative measures to predict outcome of biopsies in prostate cancer. Med Phys. 2008;35(11):4793-9. [pmid: 19070211].
Studer UE, Collette L, Whelan P, et al. Using PSA to guide timing of androgen deprivation in patients with T0-4 N0-2 M0 prostate cancer not suitable for local curative treatment (EORTC 30891). Eur Urol. 2008;53(5):941. [pmid: 18191322].
Swami S, Krishnan AV, Moreno J, et al. Inhibition of prostaglandin synthesis and actions by genistein in human prostate cancer cells and by soy isoflavones in prostate cancer patients. Int J Cancer. 2009;124(9):2050-9. [pmid: 19127598].
Swanson GP, Goldman B, Tangen CM, et al. The prognostic impact of seminal vesicle involvement found at prostatectomy and the effects of adjuvant radiation: data from Southwest Oncology Group 8794. J Urol. 2008;180(6):2453-7. [pmid: 18930488].
Swanson GP, Hussey MA, Tangen CM, et al. Predominant treatment failure in postprostatectomy patients is local: analysis of patterns of treatment failure in SWOG 8794. J Clin Oncol. 2007;25(16):2225-9. [pmid: 17538167].
Syndikus I, Morgan RC, Sydes MR, et al. Late gastrointestinal toxicity after dose-escalated conformal radiotherapy for early prostate cancer: results from the UK Medical Research Council RT01 trial. Int J Radiat Oncol Biol Phys. 2010;77(3):773-83. [pmid: 19836155].
Szmulewitz R, Mohile S, Posadas E, et al. A randomized phase 1 study of testosterone replacement for patients with low-risk castration-resistant prostate cancer. Eur Urol. 2009;56(1):97-103. [pmid: 19282098].
Szumacher E, Harnett N, Warner S, et al. Effectiveness of educational intervention on the congruence of prostate and rectal contouring as compared with a gold standard in three-dimensional radiotherapy for prostate. Int J Radiat Oncol Biol Phys. 2010;76(2):379-85. [pmid: 19467804].
Takenaka A, Hara R, Ishimura T, et al. A prospective randomized comparison of diagnostic efficacy between transperineal and transrectal 12-core prostate biopsy. Prostate Cancer Prostatic Dis. 2008;11(2):134-8. [pmid: 17533394].
Talvas J, Caris-Veyrat C, Guy L, et al. Differential effects of lycopene consumed in tomato paste and lycopene in the form of a purified extract on target genes of cancer prostatic cells. Am J Clin Nutr. 2010;91(6):1716-24. [pmid: 20392890].
Tammemagi MC, Freedman MT, Pinsky PF, et al. Prediction of true positive lung cancers in individuals with abnormal suspicious chest radiographs: a Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial study. J Thorac Oncol. 2009;4(6):710-21. [pmid: 19404219].
Tasevska N, Cross AJ, Dodd KW, et al. No effect of meat, meat cooking preferences, meat mutagens or heme iron on lung cancer risk in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Int J Cancer. 2011;128(2):402-11. [pmid: 20232386].
Tekdogan U, Tuncel A, Nalcacioglu V, et al. Is the pain level of patients affected by anxiety during transrectal prostate needle biopsy?. Scand J Urol Nephrol. 2008;42(1):24-8. [pmid: 17853018].
Thall PF, Logothetis C, Pagliaro LC, et al. Adaptive therapy for androgen-independent prostate cancer: a randomized selection trial of four regimens. J Natl Cancer Inst. 2007;99(21):1613-22. [pmid: 17971530].
Thompson IM, Lucia MS, Redman MW, et al. Finasteride decreases the risk of prostatic intraepithelial neoplasia. J Urol. 2007;178(1):107-9. [pmid: 17499284].
Thompson IM, Pauler Ankerst D, Chi C, et al. Prediction of prostate cancer for patients receiving finasteride: results from the Prostate Cancer Prevention Trial. J Clin Oncol. 2007;25:3076-81. [pmid: 17634486].
Thompson IM, Tangen CM, Ankerst DP, et al. The performance of prostate specific antigen for predicting prostate cancer is maintained after a prior negative prostate biopsy. J Urol. 2008;180(2):544-7. [pmid: 18550097].
Thompson IM, Tangen CM, Goodman PJ, et al. Finasteride improves the sensitivity of digital rectal examination for prostate cancer detection. J Urol. 2007;177(5):1749-52. [pmid: 17437804].
Thompson IM, Tangen CM, Paradelo J, et al. Adjuvant radiotherapy for pathological T3N0M0 prostate cancer significantly reduces risk of metastases and improves survival: long-term followup of a randomized clinical trial. J Urol. 2009;181(3):956-62. [pmid: 19167731].
Tikuisis R, Miliauskas P, Samalavicius NE, et al. Epidural and general anesthesia versus general anesthesia in radical prostatectomy. Medicina (Kaunas). 2009;45(10):772-7. [pmid: 19996663].
Tombal B, Miller K, Boccon-Gibod L, et al. Additional analysis of the secondary end point of biochemical recurrence rate in a phase 3 trial (CS21) comparing degarelix 80 mg versus leuprolide in prostate cancer patients segmented by baseline characteristics. Eur Urol. 2010;57(5):836-42. [pmid: 19962227].
Trachtenberg J, Bogaards A, Weersink RA, et al. Vascular targeted photodynamic therapy with palladium-bacteriopheophorbide photosensitizer for recurrent prostate cancer following definitive radiation therapy: assessment of safety and treatment response. J Urol. 2007;178(5):1974-9. [pmid: 17869307].
Tsavachidou D, McDonnell TJ, Wen S, et al. Selenium and vitamin E: cell type- and intervention-specific tissue effects in prostate cancer. J Natl Cancer Inst. 2009;101(5):306-20. [pmid: 19244175].
Tunn UW, Wiedey K. Safety and clinical efficacy of a new 6-month depot formulation of leuprorelin acetate in patients with prostate cancer in Europe. Prostate Cancer Prostatic Dis. 2009;12(1):83-7. [pmid: 19030021].
Turner EL, Lane JA, Metcalfe C, et al. Psychological distress and prostate specific antigen levels in men with and without prostate cancer. Brain Behav Immun. 2009;23(8):1073-8. [pmid: 19486654].
Ugurlu O, Yaris M, Oztekin CV, et al. Impacts of antibiotic and anti-inflammatory therapies on serum prostate-specific antigen levels in the presence of prostatic inflammation: a prospective randomized controlled trial. Urol Int. 2010;84(2):185-90. [pmid: 20215823].
van Adelsberg J, Gann P, Ko AT, et al. The VIOXX in Prostate Cancer Prevention Study: cardiovascular events observed in the rofecoxib 25 mg and placebo treatment groups. Curr Med Res Opin. 2007;23(9):2063-70. [pmid: 17651539].
van den Bergh RC, Roemeling S, Roobol MJ, et al. Gleason score 7 screen-detected prostate cancers initially managed expectantly: outcomes in 50 men. BJU Int. 2009;103(11):1472-7. [pmid: 19154509].
van den Bergh RC, Roobol MJ, Wolters T, et al. The Prostate Cancer Prevention Trial and European Randomized Study of Screening for Prostate Cancer risk calculators indicating a positive prostate biopsy: a comparison. BJU Int. 2008;102(9):1068-73. [pmid: 18715246].
Van der Kwast TH, Bolla M, Van Poppel H, et al. Identification of patients with prostate cancer who benefit from immediate postoperative radiotherapy: EORTC 22911. J Clin Oncol. 2007;25(27):4178-86. [pmid: 17878474].
van der Wielen GJ, Hoogeman MS, Dohle GR, et al. Dose-volume parameters of the corpora cavernosa do not correlate with erectile dysfunction after external beam radiotherapy for prostate cancer: results from a dose-escalation trial. Int J Radiat Oncol Biol Phys. 2008;71(3):795-800. [pmid: 18164862].
van Gils MP, Hessels D, Peelen WP, et al. Preliminary evaluation of the effect of dutasteride on PCA3 in post-DRE urine sediments: a randomized, open-label, parallel-group pilot study. Prostate. 2009;69(15):1624-34. [pmid: 19588525].
van Leeuwen P, van den Bergh R, Wolters T, et al. Screening: should more biopsies be taken in larger prostates?. BJU Int. 2009;104(7):919-24. [pmid: 19466943].
van Leeuwen PJ, Connolly D, Gavin A, et al. Prostate cancer mortality in screen and clinically detected prostate cancer: estimating the screening benefit. Eur J Cancer. 2010;46(2):377-83. [pmid: 19804966].
Vergis R, Corbishley CM, Thomas K, et al. Expression of Bcl-2, p53, and MDM2 in localized prostate cancer with respect to the outcome of radical radiotherapy dose escalation. Int J Radiat Oncol Biol Phys. 2010;78(1):35-41. [pmid: 20092961].
Vickers A, Cronin A, Roobol M, et al. Reducing unnecessary biopsy during prostate cancer screening using a four-kallikrein panel: an independent replication. J Clin Oncol. 2010;28(15):2493-8. [pmid: 20421547].
Vickers AJ, Cronin AM, Aus G, et al. A panel of kallikrein markers can reduce unnecessary biopsy for prostate cancer: data from the European Randomized Study of Prostate Cancer Screening in Göteborg, Sweden. BMC Med. 2008;6:19. [pmid: 18611265].
Vis AN, Roemeling S, Reedijk AM, et al. Overall survival in the intervention arm of a randomized controlled screening trial for prostate cancer compared with a clinically diagnosed cohort. Eur Urol. 2008;53(1):91-8. [pmid: 17583416].
Volk RJ, Jibaja-Weiss ML, Hawley ST, et al. Entertainment education for prostate cancer screening: a randomized trial among primary care patients with low health literacy. Patient Educ Couns. 2008;73(3):482-9. [pmid: 18760888].
Wang SS, Morton LM, Bergen AW, et al. Genetic variation in catechol-O-methyltransferase (COMT) and obesity in the Prostate, Lung, Colorectal, and Ovarian (PLCO) cancer screening trial. Hum Genet. 2007;122(1):41-9. [pmid: 17497175].
Watanabe H, Kanematsu M, Kondo H, et al. Preoperative detection of prostate cancer: a comparison with 11C-choline PET, 18F-fluorodeoxyglucose PET and MR imaging. J Magn Reson Imaging. 2010;31(5):1151-6. [pmid: 20432351].
Watters JL, Gail MH, Weinstein SJ, et al. Associations between alpha-tocopherol, beta-carotene, and retinol and prostate cancer survival. Cancer Res. 2009;69(9):3833-41. [pmid: 19383902].
Weinrich SP, Seger R, Curtsinger T, et al. Impact of pretest on posttest knowledge scores with a Solomon four research design. Cancer Nurs. 2007;30(5):E16-28. [pmid: 17876174].
Weiss JM, Huang WY, Rinaldi S, et al. Endogenous sex hormones and the risk of prostate cancer: a prospective study. Int J Cancer. 2008;122(10):2345-50. [pmid: 18172860].
Welch HG, Albertsen PC. Prostate cancer diagnosis and treatment after the introduction of prostate-specific antigen screening: 1986–2005. J Natl Cancer Inst. 2009;101(19):1325-9. [pmid: 19720969].
Wiegel T, Bottke D, Steiner U, et al. Phase III postoperative adjuvant radiotherapy after radical prostatectomy compared with radical prostatectomy alone in pT3 prostate cancer with postoperative undetectable prostate-specific antigen: ARO 96-02/AUO AP 09/95. J Clin Oncol. 2009;27(18):2924-30. [pmid: 19433689].
Wilkinson S, Warren K, Ramsden A, et al. Do “rapid” PSA assays reduce anxiety and stress of prostate cancer patients undergoing regular review? A prospective evaluation. Urology. 2008;71(4):567-72. [pmid: 18387384].
Williams RM, Zincke NL, Turner RO, et al. Prostate cancer screening and shared decision-making preferences among African-American members of the Prince Hall Masons. Psychooncology. 2008;17(10):1006-13. [pmid: 18203246].
Wilt TJ, Brawer MK, Barry MJ, et al. The Prostate Cancer Intervention Versus Observation Trial: VA/NCI/AHRQ Cooperative Studies Program #407 (PIVOT): design and baseline results of a randomized controlled trial comparing radical prostatectomy to watchful waiting for men with clinically localized prostate cancer. Contemp Clin Trials. 2009;30(1):81-7. [pmid: 18783735].
Wilt TJ, MacDonald R, Rutks I, et al. Systematic review: comparative effectiveness and harms of treatments for clinically localized prostate cancer. Ann Intern Med. 2008;148(6):435-48. [pmid: 18252677].
Win Z, Ariff B, Harvey CJ, et al. Comparative study of experienced vs non-experienced radiologists in assessing parametric CT images of the response of the prostate gland to radiotherapy. Br J Radiol. 2008;81(967):572-6. [pmid: 18559904].
Witte MG, Heemsbergen WD, Bohoslavsky R, et al. Relating dose outside the prostate with freedom from failure in the Dutch trial 68 Gy vs. 78 Gy. Int J Radiat Oncol Biol Phys. 2010;77(1):131-8. [pmid: 20004526].
Wo JY, Chen MH, Nguyen PL, et al. Evaluating the combined effect of comorbidity and prostate-specific antigen kinetics on the risk of death in men after prostate-specific antigen recurrence. J Clin Oncol. 2009;27(35):6000-5. [pmid: 19858385].
Wolters T, Roobol MJ, Bangma CH, Schroder FH. Is prostate-specific antigen velocity selective for clinically significant prostate cancer in screening? European Randomized Study of Screening for Prostate Cancer (Rotterdam). Eur Urol. 2009;55(2):385-92. [pmid: 18353529].
Wolters T, Roobol MJ, Schroder FH, et al. Can non-malignant biopsy features identify men at increased risk of biopsy-detectable prostate cancer at re-screening after 4 years?. BJU Int. 2008;101(3):283-8. [pmid: 17922858].
Wolters T, Roobol MJ, Steyerberg EW, et al. The effect of study arm on prostate cancer treatment in the large screening trial ERSPC. Int J Cancer. 2009;126(10):2387-93. [pmid: 19739124].
Wolters T, Vissers KJ, Bangma CH, et al. The value of EZH2, p27(kip1), BMI-1 and MIB-1 on biopsy specimens with low-risk prostate cancer in selecting men with significant prostate cancer at prostatectomy. BJU Int. 2010;106(2):280-6. [pmid: 19888978].
Xu L, Ding Y, Catalona WJ, et al. MEK4 function, genistein treatment, and invasion of human prostate cancer cells. J Natl Cancer Inst. 2009;101(16):1141-55. [pmid: 19638505].
Yeoh EK, Bartholomeusz DL, Holloway RH, et al. Disturbed colonic motility contributes to anorectal symptoms and dysfunction after radiotherapy for carcinoma of the prostate. Int J Radiat Oncol Biol Phys. 2010;78(3):773-80. [pmid: 20153122].
Yeoh EK, Holloway RH, Fraser RJ, et al. Anorectal function after three- versus two-dimensional radiation therapy for carcinoma of the prostate. Int J Radiat Oncol Biol Phys. 2009;73(1):46-52. [pmid: 18571336].
Yun TJ, Lee HJ, Kim SH, et al. Does the intrarectal instillation of lidocaine gel before periprostatic neurovascular bundle block during transrectal ultrasound guided prostate biopsies improve analgesic efficacy? A prospective, randomized trial. J Urol. 2007;178(1):103-6. [pmid: 17499292].
Zanardi S, Puntoni M, Maffezzini M, et al. Phase I-II trial of weekly bicalutamide in men with elevated prostate-specific antigen and negative prostate biopsies. Cancer Prev Res (Phila). 2009;2(4):377-84. [pmid: 19336728].
Zeng GG, McGowan TS, Larsen TM, et al. Calcifications are potential surrogates for prostate localization in image-guided radiotherapy. Int J Radiat Oncol Biol Phys. 2008;72(4):963-6. [pmid: 18954708].
Zietman AL, Bae K, Slater JD, et al. Randomized trial comparing conventional-dose with high-dose conformal radiation therapy in early-stage adenocarcinoma of the prostate: long-term results from Proton Radiation Oncology Group/American College of Radiology 95-09. J Clin Oncol. 2010;28(7):1106-11. [pmid: 20124169].