# ERSPC Protocol Differences By Study Center^*^ * Excludes two centers, Portugal and France, as results from these centers were not included in the 2009 ERSPC publication.

| Study Center
Variable | Belgium | The Netherlands | Sweden | Finland | Spain | Italy | Switzerland
Randomization procedures | Randomization after consent | Randomization after consent | Randomization before consent | Randomization before consent | Randomization after consent | Randomization before consent | Randomization after consent
Period of randomization | 6/91–12/03 | 11/93–3/00 | 12/94 | 1/96–1/99 | 2/96–6/99 | 10/96–10/00 | 9/98–8/03
Age eligibility (years, at study entry) | 55–74 | 55–74 | 50–69 | Recruited at 55, 59, 63, 67, screened until 71 | 55–74 | 55–74 | 55–69 with screening until 75
Screening interval (years) | 4–7 | 4 | 2 | 4 | 4 | 4 | 4
PSA cut-off point (ng/mL) | 1991–1994: 10.0 1995–1997: 4.0 | 1993–1997: 4.0 1997+: 3.0 | 1995–1998: 3.0 1999+: 2.5 | 4.0 prompted biopsy 3.0–3.9 prompted DRE and, after 1999, calculation of free PSA: total PSA ratio, with biopsy if either positive | 3.0 | 4.0 prompted biopsy 2.5–3.9 prompted DRE and TRUS | 3.0
Screening procedure | 1991–1997: DRE + TRUS + PSA (cut-off point, 4.0 ng/mL) 1997+: PSA only | 1991–1997: DRE + TRUS + PSA (cut-off point, 4.0 ng/mL) 1997+: PSA only | PSA alone | PSA alone, unless result was 3.0–3.9 ng/mL (see above) | PSA alone | PSA alone, unless result was 2.5–3.9 ng/mL (see above) | PSA alone

Abbreviations: PSA = prostate-specific antigen; DRE = digital rectal examination; TRUS = transrectal ultrasonography.