# Quality Ratings of Randomized, Controlled Trials of Screening

Trial Author Year | Randomization Adequate | Allocation Concealment Adequate | Groups Similar at Baseline | Maintain Comparable Groups | Eligibility Criteria Specified | Outcome Assessors Masked | Care Provider Masked | Patient Masked | Reporting of Attrition, Crossovers, Adherence, Compliance | Differential/ High Loss to Followup | ITT Analysis | Post- randomization Exclusions | Outcomes Prespecified | Quality Rating
Quebec Labrie et al 2004 (17) | Unclear | Unclear | Unclear | Unclear | Yes | Unclear | No | No | Incomplete | Differential: Unclear High overall: Unclear | No | Unclear | Yes | Poor
Nörrkoping Sandblom et al 2004 (18), 2011 (13) | No | No | Unclear | Unclear | Yes | Unclear | No | No | Incomplete | Differential: No High overall: No | Yes | Unclear | Yes | Poor
Stockholm Kjellman et al 2009 (12) | Unclear | Unclear | Unclear | Unclear | Yes | Unclear | No | No | No | Differential: Unclear High overall: Unclear | Yes | Unclear | Yes | Poor
PLCO Andriole et al 2009 (6) | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Differential: No High overall: No | Yes | No | Yes | Fair
ERSPC Schroder et al 2009 (7) | Yes | Unclear | Yes | Unclear | Yes | Yes | No | No | Incomplete | Differential: Unclear High overall: Unclear | Yes | Unclear | Yes | Fair
Substudy of ERSPC: Göteborg Hugosson et al 2011 (16) | Yes | Yes | Unclear | Unclear | Yes | Yes | No | No | Incomplete | Differential: Unclear High overall: Unclear | Yes | Yes | Yes | Fair