# Literature Search Strategy

## Database: PubMed

1. Prostatic Neoplasms[Mesh]
2. Screening OR prostate-specific antigen[Mesh]
3. Early diagnosis[Mesh]
4. PSA velocity[All Fields]
5. Prostate specific antigen velocity[Title/Abstract]
6. PSA doubling time[Title/Abstract]
7. Prostate specific antigen doubling[Title/Abstract]
8. 2 OR 3 OR 4 OR 5 OR 6 OR 7
9. 1 AND 8
10. Limit 9 to English[lang] AND Randomized Controlled Trial[ptyp] AND Publication Date from 2007/01/01 to 2011/07/01