# Appendixes

Appendix 1 Literature Search Strategy

Appendix 2 USPSTF Quality Rating Criteria

Appendix 3 Quality Ratings of Randomized, Controlled Trials of Screening

Appendix 4 ERSPC Protocol Differences By Study Center

Appendix 5 Model to Adjust for Contamination and Compliance in the PLCO Trial

Appendix 6 Excluded Studies