# Acknowledgements

We gratefully acknowledge Mark Helfand, MD, MS and Gary Miranda, MA from the Oregon Health & Science University Evidence-based Practice Center for their helpful comments on earlier versions of this review. We appreciate the careful work Evelyn Whitlock, MD, MPH performed in independently abstracting several of the trials. We are also appreciative of Kathryn Pyle Krages, AMLS, MA and Susan Wingenfeld for administrative and clerical assistance. This systematic evidence review was reviewed by outside experts and representatives of professional societies. A complete list of peer reviewers is available online at www.ahrq.gov/clinic/uspstfix.htm. The authors of this SER are responsible for its contents, including any clinical or treatment recommendations. No statement of this article should be construed as an official position of the Agency for Healthcare Research and Quality or the U.S. Department of Health and Human Services.