# References

1 Bull FC, Jamrozik K Advice on exercise from a family physician can help sedentary patients to become active Am J Prev Med 1998 15(2):85 94 9713663
2 Burton LC, Paglia MJ, German PS, Shapiro S, Damiano AM The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. The Medicare Preventive Services Research Team Preventive Medicine 1995 24(5):492 497 8524724
3 Calfas KJ, Long BJ, Sallis JF, Wooten WJ, Pratt M, Patrick K A controlled trial of physician counseling to promote the adoption of physical activity Preventive Medicine 1996 25(3):225 233 8780999
4 Calfas KJ, Sallis JF, Zabinski BA, et al Preliminary evaluation of a multi-component program for nutrition and physical activity change in primary care: PACE+ for adults Prev Med 2002 34(2):153 161 11817910
5 Elder JP, Williams SJ, Drew JA, Wright BL, Boulan TE Longitudinal effects of preventive services on health behaviors among an elderly cohort Am J Prev Med 1995 11(6):354 359 8775655
6 Goldstein MG, Pinto BM, Marcus BH, et al Physician-based physical activity counseling for middle-aged and older adults: a randomized trial Ann Behav Med 1999 21(1):40 47 18425653
7 Graham-Clarke P, Oldenburg B The effectiveness of a general-practice-based physical activity intervention on patient physical activity status Behavioral Change 1994 11(3):132 144
8 Kerse NM, Flicker L, Jolley D, Arroll B, Young D Improving the health behaviours of elderly people: randomised controlled trial of a general practice education programme BMJ 1999 319(7211):683 687 10480825
9 Kreuter MW, Chheda SG, Bull FC How does physician advice influence patient behavior? Evidence for a priming effect Arch Fam Med 2000 9(5):426 433 10810947
10 Norris SL, Grothaus MA, Buchner DM, Pratt M. Effectiveness of physician-based assessment and counseling for exercise in a staff model HMO. Prev Med. 2000;30:513-523. [pmid: 10901494].
11 Steptoe A, Doherty S, Rink E, Kerry S, Kendrick T, Hilton S Behavioural counseling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: randomised trial BMJ 1999 319(7215):943 947 discussion 947 948 10514155
12 Swinburn BA, Walter LG, Arroll B, Tilyard MW, Russell DG The green prescription study: a randomized controlled trial of written exercise advice provided by general practitioners Am J Public Health 1998 88(2):288 291 9491025
13 Smith BJ, Bauman AE, Bull FC, Booth ML, Harris MF Promoting physical activity in general practice: a controlled trial of written advice and information materials Br J Sports Med 2000 34(4):262 267 10953898
14 The Writing Group for the Activity Counseling Trial Research Group. Effects of physical activity counseling in primary care: a randomized controlled trial. JAMA. 2001;286:677-687. [pmid: 11495617].
15 US. Department of Health and Human Services. Healthy People 2010. Washington, DC: Office of Disease Prevention and Health Promotion. 2000.
16 Simons-Morton DG, Hogan P, Dunn AL, et al. Characteristics of inactive primary care patients: baseline data from the Activity Counseling Trial. Prev Med. 2000;31:513-521. [pmid: 11071831].
17 US. Department of Health and Human Services. Physical Activity and Health: A Report of the Surgeon General. Blair SN, Franks AL, Shelton DM, Livengood JR, Hull FL, Breedlove B, eds. McLean, VA: International Medical Publishing, Inc. 1996.
18 Lee IM, Skerrett PJ Physical activity and all-cause mortality: what is the dose-response relation? Med Sci Sports Exerc. 2001 33(6):S459 S471 11427772
19 Francis KT Status of the year 2000 health goals for physical activity and fitness Phys Ther 1999 79(4):405 414 10201546
20 National Center for Health Statistics. Healthy People 2000 Review, 1997. Hyattsville, MD: Department of Health and Human Services; 1997. DHHS Publication No. (PHS) 98-1256.
21 Anonymous Physician advice and individual behaviors about cardiovascular disease risk reduction--seven states and Puerto Rico, 1997 MMWR Morb Mortal Wkly Rep 1999 48(4):74 77 10023628
22 Damush TM, Stewart AL, Mill KM, King AC, Ritter PL Prevalence and correlates of physician recommendations to exercise among older adults J Gerontol A Biol Sci Med Sci 1999 54(8):M423 427 10496548
23 Dishman RK, Buckworth J Increasing physical activity: a quantitative synthesis Med Sci Sports Exerc 1996 28(6):706 719 8784759
24 King AC, Rejeski WJ, Buchner D. Physical activity interventions targeting older adults. A critical review and recommendations. Am J Prev Med. 1998;15:316-333. [pmid: 9838975].
25 Simons-Morton DG, Calfas KJ, Oldenburg B, Burton NW Effects of interventions in health care settings on physical activity or cardiorespiratory fitness Am J Prev Med 1998 15(4):413 430 9838981
26 King AC. Exercise counseling in health promotion. Br J Sports Med. 2000;34:80-81. [pmid: 10786859].
27 U S. Preventive Services Task Force. Counseling to promote physical activity. Guide to Clinical Preventive Services. 2nd ed. Baltimore, MD: Williams & Wilkins. 1996:611-624.
28 Harris RP, Helfand M, Woolf SH, et al Current methods of the U.S. Preventive Services Task Force, a review on the process Am J Prev Med 2001 20(Suppl 3):21 35 11306229
29 Whitlock EP, Orleans CT, Pender NJ, Allan J Evaluating primary care behavioral counseling interventions: an evidence-based approach Am J Prev Med 2002 22(4):267 284 11988383
30 Fiore M, Bailey W, Cohen S, et al. Treating Tobacco Use and Dependence. Quick Reference Guide for Clinicians. Rockville, MD: U.S. Department of Health and Human Services. 2000.
31 Patrick K, Sallis JF, Prochaska JJ, et al A multicomponent program for nutrition and physical activity change in primary care: PACE+ for adolescents Arch Pediatr Adolesc Med 2001 155(8):940 946 11483123
32 Marcus BH, Goldstein MG, Jette A, et al Training physicians to conduct physical activity counseling Prev Med 1997 26(3):382 388 9144763
33 Muir J, Mant D, Jone L, Yudkin P Effectiveness of health checks conducted by nurses in primary care: results of the OXCHECK study after one year BMJ 1994 308(6924):308 312 8124120
34 Randomised controlled trial evaluating cardiovascular screening and intervention in general practice: principle results of British family heart study. BMJ. 1994;308:313-320. [pmid: 8124121].
35 Dowell AC, Ochera JJ, Hilton SR, et al Prevention in practice: results of a 2-year follow-up of routine health promotion interventions in general practice Fam Pract 1996 13(4):357 362 8872092
36 Halbert JA, Silagy CA, Finucane PM, Withers RT, Hamdorf PA Physical activity and cardiovascular risk factors: effect of advice from an exercise specialist in Australian general practice Med J Aust 2000 173(2):84 87 10937036
37 Harland J, White M, Drinkwater C, Chinn D, Farr L, Howel D The Newcastle exercise project: a randomised controlled trial of methods to promote physical activity in primary care BMJ 1999 319(7213):828 832 10496829
38 Stevens W, Hillsdon M, Thorogood M, McArdle D Cost-effectiveness of a primary care based physical activity intervention in 45-74 year old men and women: a randomised controlled trial Br J Sports Med 1998 32(3):236 241 9773174
39 Taylor AH, Doust J, Webborn N. Randomised controlled trial to examine the effects of a GP exercise referral programme in Hailsham, East Sussex, on modifiable coronary heart disease risk factors. J Epidemiol Community Health. 1998;52:595-601. [pmid: 10320861].
40 Albright CL, Cohen S, Gibbons L, et al Incorporating physical activity advice into primary care: physician-delivered advice within the activity counseling trial Am J Prev Med 2000 18(3):225 234 10722989
41 King AC, Sallis JF, Dunn AL, et al Overview of the Activity Counseling Trial (ACT) intervention for promoting physical activity in primary health care settings. Activity Counseling Trial Research Group Med Sci Sports Exerc 1998 30(7):1086 1096 9662678
42 LaPorte RE, Montoye HJ, Casperson CJ Assessment of physical activity in epidemiologic research: problems and prospects Public Health Rep. 1985 100(2):131 146 3920712
43 Marcus BH, Dubbert PM, Forsyth LH, et al Physical activity behavior change: issues in adoption and maintenance Health Psychol 2000 19(Suppl 1):32 41 10709946
44 Dickey LL, Gemson DH, Carney P Office system interventions supporting primary-care based health behavior change counseling Am J Prev Med. 1999 17(4):299 308 10606199
45 Sallis J, Patrick K, Frank E, Pratt M, Howell W, Galuska DA. Interventions in health care settings to promote healthful eating and physical activity in children and adolescents. Prev Med. 2000;31:S112-120. [pmid: 11070247].
46 Prochaska JJ, Zabinski BA, Calfas KJ, Sallis J, Patrick K PACE+ Interactive Communication Technology for Behavior Change in Clinical Settings Am J Prev Med 2000 19(2):127 131 10913904
47 Orleans CT Promoting the maintenance of health behavior change: recommendations for the next generation of research and practice Health Psychol 2000 19(Suppl 1):76 83 10709951