# Results

Eight randomized controlled trials (2, 4, 6, 8, 10-12, 14) and one non-randomized controlled trial (13) of adults and seniors met the inclusion criteria for this report (Table 1). We found one trial of counseling adolescents in primary care to increase physical activity (31) and no trials of counseling children in a primary care setting. One additional study (32) qualified for inclusion but was a pilot study for a another larger included study (6). In this instance, the evidence tables and results present the results of the larger study (6).

Table 1. Summary of controlled trials of counseling for PA

Study, Authors, Quality Score (Main reasons) | Study Design & Subjects | PA Intervention
Physically Active for Life Goldstein, 1999^ 6 ^ Quality score= Good (met all criteria) | RCTof 24 community-based primary care practices (Adj). Providers:17 intervention, 17 control. Patients: Intervention: n=181 sedentary; avg. age: 65 yrs.; baseline stages: precontemp:13%, contemp:31%, preparation:56%, action 0%. Control (usual care): n=174 sedentary; avg. age: 66 yrs.; baseline stages: precontemp:17%, contemp:33%, preparation:50%, action:0% Sedentary Defn: Not meeting HP Assessment: Previsit interview phone call with all patients. Measured PASE (PV), SF36 (PV), stages, PA preference, barriers at baseline, 6 weeks and 8 months. No direct measure of PA. Follow-up:Intervention: 93% at 6 weeks, 87% at 8 months; Control: 95% at 6 weeks, 88% at 8 months | Theory: Transtheoretical (5 stages), social cognitive theory, health education Behaviors addressed: PA Provider Education: Intervention physicians and office staff received training, pretested manual. Patient PA Goal: HP Protocol: Intervention:1) Assessment attached to patient chart; 2) Physicians gave 5 min. stage-specific advice on benefits, assisted with self-efficacy, community resources, agreed on a written PA prescription and to read patient manual; 3) Patients returned at 1 mo. for adjusted prescription; 4) Patients received poster on maintenance tips. Control: Usual care Provider Compliance: Intervention: 99% PA prescription, 77% FU prescription. 93% patients reported PA counseling; 67% reported PA prescription. Control:1% of patients got PA prescription
Kerse, 1999^ 8 ^ Quality Score= Fair (counseling interventions not clearly defined, low provider compliance) | RCT of 42 metropolitan general practitioners (Adj). Providers: 42 general practitioners Patients: Intervention: n= 135; avg. age:73 yrs; total activity: 281 min/week. Control (usual care) : n= 132; avg. age: 74 yrs.; total activity: 328 min/week Sedentary Defn: Not reported. Assessment: Home interview at baseline and 1 year using questions from Risk Factor Prevalence Survey (PV), PA, functioning status tool, psychosocial measures. No direct PA measure. Follow-up: Intervention: 90% at 1 year; Control : 85% at 1 year | Theory: Not reported. Behaviors Addressed: PA, social activity. Provider Education: 3 hour seminar with exercise physiologist, sociologist and geriatrician; 15 minutes follow-up detailing; summary reading material; prompts on a card. Patient PA Goal: Increase PA Protocol: Intervention: Appropriate counseling for PA and social activity. Other counseling details not reported. Providers were educated on vaccination and prescription with older adults. Control: Usual care. Provider Compliance:Intervention: 32% of patients reported discussing PA with physician. Control: 21%
Norris, 2000^ 10 ^ Quality Score= Fair (baseline differences in patients receiving prior PA counseling, control clinicians increased PA counseling rate during trial) | RCT of 34 primary care practices (Adj). Stratified by clinic to ensure equal numbers of intervention and control. Providers: 34 primary care physicians Patients: Intervention: n=384; avg. age: 53; baseline stages: precontemp: 2.6%; contemp: 51.3%; action: 46.3%. Control (usual care) : n=463; avg. age: 57; baseline stages: precontemp: 3.4%; contemp: 46.8%; action: 49.8% Sedentary Defn: Less than 3 sessions of mod. or vig. activity per week or less than 2 hours of PA per week. Assessment: PACE (PV), PASE (PV), PARQ, Paffenbarger's (PV) SF-36 (PV) Follow-up: Total Group : 93% at 6 weeks, 97% at 6 months | Theory: Transtheoretical (3 stages). Behaviors Addressed: PA Provider Education: 1 hour training. FU calls with providers. Patient PA Goal: PACE Active, HP recommendations. Protocol: Intervention: 1) Physician gave stage-based advice on benefits; discussed PA preferences and assisted with barriers, self-efficacy, self-management; gave stage-based hand-outs; agreed on written goal 2) Research assistant called to discuss any concerns @ one month, 3) As needed, mailed educational materials Control: Usual care Provider Compliance: Intervention: 94% counseled, 90% of these received PA recommendation. Control: 65% counseled, 81% of these received a PA recommendation.
Change of Heart Steptoe, 1999^ 11 ^ Quality Score= Fair (fair follow-up) | RCT of 20 general practices (Adj.) Providers: 20 nurse practitioners Patients: Adults 18-69 1+ CHD risks Intervention : n=316; avg. age 48; BMI >25 and sedentary: 80% Control : n=567; avg. age 46; increased BMI and sedentary: 79% Sedentary Defn: <12 (20 min.) episodes of vigorous or moderate PA in past 4 weeks Assessment: Allied Dunbar National Fitness Survey Follow-up: Intervention: 65% at 4 months, 54% at 1 year; Control (usual care) :74% at 4 months, 62% at 1 year | Theory: Transtheoretical (5 stages). Behaviors Addressed: PA, smoking, diet Provider Education: 3 day training with refresher day @ 6 months Patient PA Goal: >12 (20 min.) moderate or vigorous PA sessions/4 weeks Protocol: Intervention: 1) Baseline assessment; 2) Nurse practitioner gave stage-based advice on benefits and attitudes; assisted with incentives, self monitoring, relapse prevention, barriers; 3) Telephoned patients between counseling sessions; 4) Patient mailed educational materials Control : Usual Care Patient Compliance: 94% attended 1 counseling session; 73% attended 2 sessions
Burton, 1995^ 2 ^ Quality Score = Fair (fair follow-up, counseling interventions not clearly defined) | RCT of 4195 Medicare patients. Providers: 3 hospital based, 13 community group and 103 solo practices. Patients: Intervention:n=2105 sedentary Medicare beneficiaries; age 65-74: 61%; 75-84: 33%; 85+: 6%; baseline stages: good health: 33%; poor health: 72%. Control : n=2090 sedentary Medicare beneficiaries; age 65-74: 62%; 75-84: 33%; 85+: 5%; baseline stages: good health: 34%; poor health: 73% Sedentary Defn: PA such as walking, gardening, housework etc. less than 3 times per week. Assessment: Two preventive exams 1 year apart. Follow-up: Intervention: 75% at 2 years; Control (usual care) 73% at 2 years | Theory: Suggested but not directed. Behaviors addressed: PA, immunization, smoking, drinking. Provider Education:One session reviewing preventive and counseling visits. Received educational materials and continuing medical education credits. Patient PA Goal: Increase PA Protocol: Intervention:1) Advised using pre-visit risk screen feedback and assisted with community resources. 2) 20 minute follow-up counseling sessions as needed. Most counseling details not reported. Control:Usual care Provider Compliance: 89% of physician encounter forms contained PA discussion note. Inferred that up to 39% of patients attended follow-up counseling visit that included PA.
Smith , 2000^ 13 ^ Quality Score= Fair (baseline differences in PA levels in groups) | Nonrandomized controlled trial of patients in 27 general practices. Recruited controls first Providers: 55 general practitioners from Australia Patients: 25-65 year old active and inactive adults Prescription Only Intervention : n=380; avg. age 43 years; total PA median 95 minutes Prescription and Booklet Intervention : n=376; avg. age 43 yrs.; total PA median 120 minutes Control (usual care) : n=386; avg. age 42 yrs; total PA 145 minutes Assessment: 2 week PAR Follow-up: Total Group : 92% at 6-10 weeks; 83% at 7-8 months | Theory: Transtheoretical (5 stages) Behaviors Addressed:PA Provider Education: 20-30 mins of training Patient PA Goal: HP Protocol: Intervention: 1) Research staff assessed in waiting room, GP not told results; 2) GP provided PA prescription; 3) Stage-based booklets sent to random sample Control : Usual care Provider Compliance: (all intervention patients 468/756) 62% written prescription although inferred 468 of 471 sedentary patients for 99% compliance.
Swinburn, 1998^ 12 ^ Quality score = Fair (counseling intervention not well defined, provider compliance not reported) | RCT of 491 patients of 37 providers. Providers: 37 general practitioners in New Zealand Patients: sedentary adults. 50% had at least one coronary heart risk factor. Intervention: n=239 Control: 252. Assessment: Risk Factor Prevalence Survey No. 3 (Australian National Heart Foundation) Follow-up: Intervention : 91% at 6 weeks,: Control : 94% at 6 weeks | Theory: Self-management (goal setting) Behaviors Addressed: PA Provider Education: 1 training session on assessing and prescribing physical activity Patient PA Goal: Increase activity Protocol: Intervention: 1) Patient completed written questionnaire 2) GP advised (avg. 5 minutes) and provided written physical activity prescription 3) Stage-based booklets sent to random sample Control : 1) Patient competed written questionnaire 2) GP advised (avg. 5 minutes) patients to increase physical activity. Counseling details not reported. Provider Compliance: not reported
Calfas, 2001^ 4 ^ Quality score = Fair (nonresponders were excluded) | RCT of 173 patients from 4 primary care settings Providers: 10 physicians and nurse practitioners Patients: adults making a non-urgent visit with 21<BMI<29 avg.age = 38 years (19-59 yrs.) Intervention : received advice and mail, n=45; received advice, mail, phone calls, n=41; received advice, more phonecalls and mail, n-41 Control : received advice, n=46 Assessment: modified (8 statement) PACE+ tool Follow-up: Total Group : 86% at 4 months | Theory: Social cognitive theory, transtheoretical Behaviors Addressed: PA and diet Provider Education: 30-60 minutes of PACE+ training Patient PA Goal: HP Protocol: Intervention: 1) Patient completed computerized assessment and set one physical activity and one diet goal. 2) Clinician advised patient with PACE+ action plan (2-5 mintues). The action plan contained behavioral change goals, patients perceived benefits, sources of social support and 3 potential barriers. 3) patients received varying amounts of follow-up mailings and phonecalls. Control : 1) Patient competed computerized assessment 2) clinicain advised patients with PACE+ action plan (2-5 minutes) Provider Compliance: Clinician advice rate not reported but 61-95% of intervention patients received allotted follow-up mailings and phonecalls
Activity Counseling Trial, 2001^14, 40^ Quality score = Good (met all criteria) | RCT of 874 adult patients from 11 primary care settings. Providers: 51 physicians, 2 physician assistents, 1 nurse practitioner. Patients: inactive adults (ages 35-75 years) in stable health. Intervention: Advised group: n=292, avg age 51 years; Assisted group: n=293, avg age 52 years; Counseled group: n=289, avg age 52 years. Assessment: 7-day PAR (PV), Vo2 max, activity step counter. Follow-up: Total Group: 91% completed 7-day PAR at 24 months, 78% completed fitness test (Vo_2_ max) at 24 months | Theory: Social cognitive theory Behavior:PA Provider Education: Clinicians received advice training; health educators received assist and behavioral counseling training Patient Goal: HP Protocol: Intervention: 4 parts: 1) Patient completed 3 assessment sessions at baseline; 2) All patients received 3 minutes if advice from a clinician and had access to health educators to answer questions; 3) Assist patients also received 30-40 mins. of behavioral counseling, monthly newsletters and interactive mail follow-up, telephone follow-up by health educator to non-respondents; 4) Biweekly telephone counseling calls for 6 weeks, then monthly calls, weekly classes available.Advised group received parts 1-2; Assisted group received parts 1-3; Counseled group received parts 1-4. Control: Advised group Provider Compliance: Initial 3 minutes of advice: 99%; Documented 97%; Avg contact time: Advised group : 18 minutes over 24 month study; Assisted group: 2.7 hours; Counseled group: women 8.9 hours, men 5.6 hours.

Note: Adj indicates Analysis adjusted for clustering effect of randomizing by practice; FU, follow-up; HP, Healthy People 2010 recommendation: Moderate activity 30 min./5 times/week (or) vigorous activity 20 mi./3 times/week; PA, Physical activity; PASE, Physical Activity Scale for the Elderly; PV, Previously validated; SF36, Medical Outcomes Study 36 item short form health survey.

Note: Adj indicates Analysis adjusted for clustering effect of randomizing by practice; BMI, Body mass index; CHD, Coronary heart disease; FU, follow-up; HP, Healthy People 2010 recommendation: Moderate activity 30 min./5 times/week (or) vigorous activity 20 mi./3 times/week; PA, Physical activity; PACE, Physician-based Assessment and Counseling on Exercise; PARQ, Physical Activity Readiness Questionnaire; PASE, Physical Activity Scale for the Elderly; PV, Previously validated; SF36, Medical Outcomes Study 36 item short form health survey.

Note: FU indicates follow-up; HP, Healthy People 2010 recommendation: Moderate activity 30 min./5 times/week (or) vigorous activity 20 mi./3 times/week; PA, Physical activity; PAR, 7 day Physical Activity Recall.

Note: BMI indicates Body mass index; FU, follow-up; HP, Healthy People 2010 recommendation: Moderate activity 30 min./5 times/week (or) vigorous activity 20 mi./3 times/week; PA, Physical activity; PACE+, Patient-centered Assessment and Counseling on Exercise plus nutrition.

Note: FU indicates follow-up; HP, Healthy People 2010 recommendation: Moderate activity 30 min./5 times/week (or) vigorous activity 20 mi./3 times/week; PA, Physical activity; PAR, 7 day Physical Activity Recall; PV, Previously validated; Vo2 max, Maximal oxygen uptake (Vo2 max, ml/min)

We excluded two randomized controlled trials (33, 34) and one cohort study (35) that did not report counseling from a clinician to increase physical activity (even if physical activity outcomes were reported). The trials (Oxcheck and Family Heart) specifically report counseling for smoking cessation and diet changes but do not mention whether any physical activity behavioral intervention occurred. We excluded five randomized controlled trials (36-39) in which all components of the intervention were provided by a research staff member or exercise specialist. Although recruitment of patients occurred in the primary care setting for these five excluded trials (36-39), we found no evidence that a primary care clinician performed any component (assessment, advising, counseling, referral, etc.) of the intervention. The practices in these studies primarily provided a list of eligible patients for the study. For example, in one study (37) a research associate recruited patients from waiting rooms or from lists provided by the general practitioners. The patients were mailed an invitation to participate in an intervention at a fitness center conducted by health educators. As a team, we reviewed this study and excluded it since no components of the intervention were performed by a primary care clinician. Five additional trials (1, 3, 5, 7, 9) were excluded because they received a quality rating of poor (see Appendix C, Table 2).

In all of the included trials, the patient completed a brief self-report tool or a clinician or researcher interviewed the patients to assess physical activity levels. Table 2 briefly describes the tools used in the trials. Clinicians in the trials evaluated whether the patients could safely participate in the trial and excluded those patients for whom physical activity was contraindicated. In most trials, the primary care clinician advised sedentary or minimally active patients to achieve regular, moderate-intensity physical activity; in some trials, clinicians gave an option of a vigorous activity goal.

Table 2. Description of PA self-report tools used in primary care

Tool | Efficacy studies using tool | Type of questions
Physical Activity Scale for the Elderly (PASE) | Goldstein, 1999^ 6 ^ Norris, 2000^ 10 ^ | Seniors select daily activities from list and estimate time. 11 items, two scales. PASE Leisure scored 0-130. PASE household scored 0-170. Takes 5 minutes to complete.
Physician-based Assessment and Counseling on Exercise (PACE) | Norris, 2000^ 10 ^ | Pick 1 of 11 graded statements that best describes activity level and readiness to change. 1 item. Scored 1-11.
Patient-centered Assessment and Counseling on Exercise plus nutrition (PACE+) | Calfas, 2001^ 4 ^ | Pick 1 of 8 graded statements that best describes activity level and readiness to change. Scored 1-8.
College Alumni Questionnaire (CAQ) | Norris, 2000^ 10 ^ | Recall how many stair flights climbed, how many walked blocks, and sports hrs/week. Walking item, total activity item. Scored (kcal/week).
7-day Physical Activity Recall (7-day PAR) | Smith, 2000^ 13 ^ Norris, 2000^ 10 ^ | Recall from lists of various activities assigned a metabolic equivalent (MET): Sleep = 1 MET Activity: Light = 1.1 - 2.9 METs Moderate = 3.0 - 5 METs Hard = 5.1 - 6.9 METs Very Hard = >7.0 METs Scored as total energy expenditure (kcal*kg^−1^*day^−1^)
Current Physical Activity | ACT, 2001^ 40 ^ | Interviewer-administered, shortened 7-day PAR.
Risk Factor Prevalence Survey No. 3, Australian National Heart Foundation | Kerse, 1999^ 8 ^ | 3 dichotomous (yes/no) questions assessing vigorous, less vigorous, and walking activity in past 2 weeks. 3 items. Scored as 1 or 0.
Allied Dunbar National Fit Survey | Steptoe, 1999^ 11 ^ Swinburn, 1998^ 12 ^ | Number of 20 minute episodes of vigorous or moderate activities/4 weeks. Scored as number of sessions.

Four randomized controlled trials (RCTs) (6, 10, 12, 14) and the one nonrandomized controlled trial (13) examined physical activity as the only behavioral outcome measure. Two (6, 14) of these trials received a "good-quality" rating and three were rated "fair-quality." The remaining four RCTs (2, 4, 8, 11) had multiple behavior outcomes (change physical activity levels along with, e.g., diet change, smoking cessation). All four of these trials were rated fair-quality. The first column in Table 1 presents the quality rating and main reasons for them. The good-quality trials (6, 14) met all quality criteria. Each fair-quality study had one or more of the following quality limitations: counseling interventions not clearly defined; had follow-up on only 60% to 79% of patients (2, 11); treatment and control groups with differing baseline activity levels (10, 13); or excluded nonresponders to follow-up in the analysis (4).

In addition to trial quality, provider compliance varied (Table 1). Of the five trials that focused only on changing physical activity, four reported that over 90% of patients received the intended intervention (6, 10, 13, 40). The remaining trial that focused only on changing physical activity did not report clinician compliance rate (12). In the four trials that embedded a physical activity intervention with a package of prevention activities, compliance specifically with the PA intervention, was unclear (2, 4, 11) or low (32%) (8). One trial (11) reported that 94% of intervention patients attended at least one counseling session that addressed physical activity, smoking cessation and/or diet changes. It is not reported what proportion of intervention patients received activity counseling during the session. Another trial (4) reported that 61% to 95% of intervention patients received the allotted follow-up mailings and phone calls, but did not report how many were counseled.

## Efficacy of Counseling

Of the nine trials included here, six contained a usual care comparison and the remaining three compared two or more interventions (no usual care condition). The results of the two types of designs are presented separately to account for the differing control conditions.

### Interventions Compared With a Usual Care Control

All six trials (2, 6, 8, 10, 11, 13) containing a usual care condition reported long-term outcomes (six months or longer), but only three (6, 11, 13) reported short-term outcomes (less than six months) (Table 3). Of the latter, only one (11) reported a statistically significant short-term increase in activity. Specifically, at four months, patients of trained nurses increased their number of physical activity sessions to 13 per four weeks compared with nine per four weeks for patients of nontrained control nurses (difference of 3.7 sessions per four weeks; 95% confidence interval (CI), 1.3 to 6.2 sessions per four weeks; P<0.05) (11). In this trial, a nurse practitioner assessed the patients for sedentary behavior using a question from the Allied Dunbar National Fit Survey (Table 2) (11). The patients were also assessed for other modifiable coronary heart disease risk factors. Seventy-nine percent of the intervention patients were overweight and sedentary. Patients attended up to three counseling sessions that addressed any of three behaviors (smoking, drinking, and sedentary behaviors.)

Table 3. Summary of efficacy of counseling to improve physical activity (compared to usual care)

Study (Quality) | Behavior addressed | Target Population | Activity Goal | Short-term: less than 6 months | Long-term: 6 months +
Goldstein, 1999^ 6 ^ (Good) | PA | 355 adults, aged 50 and older | HP | At 6 weeks, 28% intervention patients met HP goal vs. 21% control (difference of 7%; CI −3% to 15%). | At 8 months, 28% of intervention patients met HP goal vs. 23% control, (difference of 5%; CI −6% to 14%).
Kerse, 1999^ 8 ^ (Fair) | PA, social activity | 267 older adults | Increase | | At 1 year, increased walking (P=.03). Intervention patients increased walking 44 min/week more than control patients, (CI, 4 to 84 min/week).
Steptoe, 1999^ 11 ^ (Fair) | Smokers, diet, PA | 863 adults with at least 2 cardiovascular risks | >12 PA sessions per 4 weeks | At 4 months, increased number of 20 minute PA sessions/4 weeks (P<.05). Intervention patients 13 sessions/4 weeks vs. controls 9 sessions/4 weeks (difference of 3.7; CI, 1.3 to 6.3 sessions/4 weeks.) | At 1 year, increased 20 minute PA sessions (P<.05). Intervention patients performed 14 sessions/4 weeks vs. control patients' 9 sessions/4 weeks (difference of 3.9; CI, 1.0 to 6.8 sessions/4 weeks).
Norris, 2000^ 10 ^ (Fair) | PA | 812 adults 30 years and older | HP | | At 6 months, 66% intervention met HP goal vs. 60% control (difference of 6%; CI, −2% to 12%).
Burton, 1995^ 2 ^ (Fair) | PA, vaccines, smoking, drinking | 4,195 older adults | Increase | | At 2 years, 42% of intervention patients in good health increased PA vs. 42% control group patients in good health. 20% of intervention patients in poor health increased PA vs. 18% of control patients in poor health (difference of 3%; CI, −4% to 9%).
Smith, 2000^ 13 ^ (Fair) | PA | 1,142 adults, ages 25-65 | Two goals: HP and increase by 60 minutes/ week | At 6-10 weeks, 31% of patients receiving prescription and booklet met HP goal vs. 27% of control, difference of 4% (CI, −3% to 10%). 26% of prescription only patients met goal vs. 27% of control, difference of −1%, (CI, −8% to 5%). | At 7-8 months, 24% of prescription and booklet patients met goal vs. 17% of control, difference of 8% (CI, 2% to 13%; adj P>.05). 22% of intervention patients receiving only a PA prescription met goal vs. 17% of control, difference with control of 5% (CI, −1% to 10%).

Note: CI indicates 95% confidence interval; HP, Healthy People 2010 recommendation: Moderate activity 30 min./5 times/week (or) vigorous activity 20 mi./3 times/week; PA, physical activity

This same trial was also one of only two that reported a statistically significant increase in physical activity level long-term (more than six months) (11). At one year, with 54% of the patients responding, the intervention patients performed fourteen 20-minute physical activity sessions per four weeks compared to nine sessions by control patients (difference of 3.9 sessions per four weeks; CI, 1.0 to 6.8 sessions per four weeks; P<.05).

In the other fair-quality trial (8) that reported increased long-term activity, patients of intervention physicians reported walking 44 minutes per week more than patients of control physicians at one-year follow-up (CI, 4 to 84 minutes per week; P=0.03). In this trial, all patients were assessed with three questions from the Risk Factor Survey (Table 2). Twenty-one intervention physicians were trained on prescribing medications and vaccinations to their older adult intervention patients (n=135) and to counsel them about social and physical activity. Twenty-one control physicians treated 132 older adults with usual care. Ninety percent of intervention patients and 85% of control patients completed follow-up one year later. This study provided no details of the counseling intervention or compliance rate by providers, but 32% of patients recalled discussing physical activity with their clinician.

Of the remaining four trials that contained a usual care control group, none reported statistically significant increases in physical activity either short- or long-term (2, 6, 10, 13). In the only good-quality trial with a usual care control group (6), a research staff member assessed the patients using the Physical Activity Scale for the Elderly (PASE) described in Table 2. Seventeen trained physicians provided three to five minutes of physical activity counseling to 181 sedentary older adults while 17 untrained control physicians provided usual care to 174 sedentary adults. Delivery of physical activity prescriptions was confirmed for 99% of intervention group patients. Over 80% of patients responded to follow-up at six weeks and eight months. At six weeks 27% of intervention patients and 21% of control patients reported meeting the recommended HP 2010 moderate physical activity goal (difference of 6%; CI, −3% to 15%) (6). At one year, 28% of intervention patients and 24% of control patients met the recommendation (difference of 4%; CI, −6% to 14%).

In the second RCT (10), 66% of patients of the intervention physicians met either the moderate or vigorous HP 2010 physical activity goal at six months compared with 60% of usual care patients (difference of 6%; CI −2% to 12%). In this trial a nurse or medical assistant assessed the patients with the PASE tool, 7-day recall, College Alumni Questionnaire (CAQ), the Physical Activity Readiness Questionnaire (PARQ), and with the Physician-based Assessment and Counseling for Exercise (PACE) tool (Table 2). Seventeen intervention physicians gave individualized advice based on patients' readiness to change physical activity, discussed benefits and physical activity preferences, assisted patients with barriers, self-efficacy, and self-management. A research assistant called patients at one month to discuss concerns. Seventeen physicians provided usual care. Ninety-seven percent of patients responded to follow-up at six months. The trial was rated as fair-quality because the control physicians increased their counseling rate with usual care patients from 55% to 81% during the study and more control patients had received physical activity counseling in the six months before the trial began (55%) than intervention patients (42%) (difference of 13%; CI, 6% to 20%; P=02).

Despite the good to fair quality score of these last two RCTs (6, 10), their generalizability is uncertain. In both trials, the baseline advice counseling rate was high, particularly among the control physicians. In the first trial, 71% of control and 53% of intervention physicians reported counseling all patients on physical activity before the study began (6). In the second trial, 55% of control patients and 42% of intervention patients reported being counseled to exercise during the six months prior to the study (10). These baseline counseling rates are almost twice the expected rate found in surveys of physicians and limits the ability to detect differences between intervention and control groups. Also, a high percentage (47%) of the patients in one trial (10) were already in the "active" stage at baseline limiting the power to detect predicted treatment effects.

The third (2) of the four negative trials showed no significant increase in physical activity levels as a result of two preventive visits one year apart. At two years, 42% of intervention and 42% of control patients reported an increase in physical activity (no difference). Twenty percent of intervention patients in poor health reported an increase compared with 18% of control patients (difference of 3%; CI, −4% to 9%). Patients in the intervention group were given several preventive clinical screenings and counseled on several behavioral changes during the preventive visits. Details regarding how patients were counseled to change physical activity were not provided. Compliance was unclear since 89% of patients discussed adequate physical activity during the preventive visit but an estimated 39% attended a follow-up visit that included counseling to change physical activity levels.

The final negative study -- a nonrandomized controlled trial (13) -- reported a small, nonsignificant difference in the increase in the number of physical activity minutes per week or the proportion meeting the HP 2010 goals between either of two intervention groups compared with a group of usual care patients. In this trial, 386 usual care patients were recruited before the clinicians received training for the intervention, and the intervention patients were recruited after the training. The 756 intervention patients were then randomly assigned to one of two intervention groups: to receive a physical activity prescription alone (prescription only group), or to receive a prescription combined with a mailed booklet (prescription plus booklet group). Throughout the trial, all patients were assessed using the 7-day recall (Table 2). At the baseline assessment, significantly more (62%) intervention patients were inactive (did not meet the moderate or vigorous HP 2010 goal) compared with 54% of the control patients (difference of 8%; CI, 1% to 15%; P<0.05).

The proportion of patients meeting the HP 2010 activity recommendation did not differ significantly between the intervention groups and usual care group either short term (6-10 weeks) or long term (7-8 months) (Table 3). The greatest differences occurred at 7-8 months: 24% of intervention patients in the "prescription plus booklet" group met the HP 2010 recommendation, compared with 17% of usual care patients (difference of 8%; CI, 2% to 13%; P=.012). This was no longer significant when adjusted for demographics, language, and baseline physical activity level. In the "prescription only" group, 22% of patients achieved the HP 2010 recommendation, compared with 17% of usual care patients (difference of 5%; CI, −1% to 10%). The limitations of this trial were that it was not randomized, and a significantly greater proportion of the intervention patients were inactive compared with the usual care group at baseline. Also, unlike the other three trials (4, 8, 10) that included active and sedentary patients in the trial, active intervention (38%) patients in this trial (13) were given no physical activity prescription for continued activity.

### Interventions Compared With Other Interventions

Three trials compared the efficacy of using different intervention conditions in adults but did not contain a usual care condition (4, 12, 14). The results of these trials are summarized in Table 4 and briefly described below. One trial of adolescents that contained no usual care condition is presented at the end of this section (31).

Table 4. Summary of efficacy of counseling to improve physical activity (comparing interventions)

Study (Quality Score) | Behavior addressed | Target Population | Activity Goal | Short-term: less than 6 months | Long-term: 6 months +
Activity Counseling Trial, 2001^ 14 ^ (Good) | PA | 874 sedentary adults, ages 35-75, in stable health | HP | | No difference in total energy expenditure for male or female patients at 6, 12, or 24 months with one exception. Female patients in the "counseled" group had an average total energy expenditure of 33.3 kcal*kg-1*day-1 at 6 months vs. 32.7 kcal*kg-1*day-1 for female patients in the "assisted" group (difference of 0.54 kcal*kg-1*day-1; CI, .07 to 1.0; adj P=.01).
Swinburn, 1998^ 12 ^ (Fair) | PA | 491 sedentary adults | HP or "active" job. | More patients receiving advice and a written PA prescription performed any activity (51% to 86%, an increase of 35%) at 6 weeks vs. patients who received only advice (56% to 77%, an increase of 21%) (difference of 14%; CI, 6% to 22%; P=0.004). No difference in the number of increased minutes spent in PA for the groups, 156 minutes per 2 weeks. | 47/80 of randomly selected patients (80% response rate) who received advice and a PA prescription were maintaining an increased level of PA at 11 months.
Calfas, 2001^ 4 ^ (Fair) | Diet and PA | 173 adults making a nonurgent visit to the physician and 21<BMI<29. | HP | Patients who set a goal to increase moderate physical activity increased more at 4 months than patients who did not set goals, P<.001. 49% of goal setters increased moderate PA vs. 21% who didn't set goals (difference of 28%; CI, 14% to 42%). Patients who set goals for vigorous activity increased activity more than for those who did not set a goal, P<.001. 51% of goal setters increased vigorous PA vs. 23% who did not set goals (difference of 28%; CI, 14% to 43%).

Note: BMI indicates Body Mass Index; CI, 95% Confidence Interval; HP, Healthy People 2010 recommendation: Moderate activity 30 min./5 times/week (or) vigorous activity 20 mi./3 times/week; PA, Physical activity

In one trial (12), the combination of advising the adult patient, agreeing on a goal, and assisting the patient by providing a written prescription was found to be more effective than providing advice alone. At six weeks follow-up, patients who received both advice and a prescription showed a greater increase (from 51% to 86%, an increase of 35%) in performing any activity than those who received only advice (56% to 77%, an increase of 21%; difference of 14%; CI, 6% to 22%; P=.004). Ninety percent of patients responded to follow-up at six weeks. The report to this trial contained few details on the counseling intervention and reported no information on provider compliance.

Another RCT (4) of 173 adults reported that patients who specifically set goals to increase either moderate or vigorous physical activity levels were more likely to increase physical activity than patients who did not specifically set goals. Forty-nine percent of goal setters increased moderate physical activity compared with 21% of patients who did not set moderate physical activity goals (difference of 28%; CI, 14% to 42%; P<.001). Fifty-one percent of goal setters increased vigorous physical activity compared with 23% of patients who did not set vigorous activity goals (difference of 28%; CI, 14% to 43%; P<.001). In this trial, adult patients completed a computerized, modified PACE tool that assessed physical activity and diet (Table 2). At the completion of the assessment, the computer prompted the patient to select one physical activity goal and one diet goal for an action plan. A physician or nurse practitioner advised all patients using the action plan. Patients were then randomized to receive differing levels of follow-up mailings and phone calls. The trial achieved good follow-up (86%) but excluded nonresponders from the analyses.

In the Activity Counseling Trial (ACT) (41), sedentary adults in stable health were randomized to one of three interventions to receive: clinician advice and educational materials (advice group); clinician advice and educational materials, plus 30-40 minutes of behavioral counseling and interactive mail (assistance group); or all of the above plus counseling phone calls and class offerings (counseling group). At six, 12, and 24 months, men in the different intervention groups had no difference in either expended energy amounts or fitness levels (14). Specifically, at six months women in the counseling group increased self-reported physical activity more than women in the assistance group. Women in the counseling group achieved a total energy expenditure of 33.3 kcal*kg^−1^*day^−1^ at six months compared with 32.7 kcal*kg^−1^*day^−1^ for women in the assistance group (difference of .54 kcal*kg^−1^*day^−1^; 95% CI, .07 to 1.0; adjusted P=0.01). For a 50-55 kg woman, this corresponds to walking an extra two miles per week. At 12 and 24 months women in the different interventions did not differ significantly in total energy expenditure. As for fitness levels, at 24 months, women in the counseling group achieved greater levels of fitness than women in the advice group (difference in Vo_2_max, 73.9 mL/min; 99.2% CI, 0.9 to 147.0 mL/min; P=.046). Women in the assistance group also achieved greater levels of fitness than women in the advice group (difference in Vo_2_max, 80.7 mL/min; 99.2% CI, 8.1 to 153.2 mL/min; P=.02).

Finally, one recently completed trial reported behavior changes in adolescents when they set a goal (31). In this study, 148 healthy adolescents completed PA assessments and received behavioral change counseling by a physician for diet and exercise. Patients were then randomized for extended follow-up strategies (mail and additional booster calls). The adolescents had improved PA at 4 months, particularly when a goal was set. The extended follow-up interventions did not improve results. At baseline, when the whole group was considered, 39% of adolescents were meeting the moderate physical activity goal. The average number of days they reported performing moderate exercise was 3.09 days per week. At 4-month follow-up the average number of days increased to 4.52 days per week for adolescents who set goals to increase moderate exercise. It is unclear how well this study can be generalized to adolescents in routine primary care settings, since many of the enrolled adolescents had made appointments for pre-athletic examinations and because at baseline, 74% of adolescents reported meeting the recommended vigorous exercise goal, which is considerably higher than the 54% to 64% reported in the 1992 National Health Interview Survey - Youth Risk Behavior Survey and 1995 school-based Youth Risk Behavior Survey.

## Potential Adverse Effects of Counseling

Potential harms of physical activity counseling have not been well defined. They likely include musculoskeletal injuries, fall-related injuries and cardiovascular events.

Only one trial, the Activity Counseling Trial (14), (of sedentary patients ages 35-75 years, average 52 years) reported the rate of physical harm that occurred during a two-year followup time. Before enrollment in the trial, a patient had a physical examination including a submaximal treadmill test. Patients with pre-existing heart disease or a finding during the submaximal treadmill were excluded from the trial. Patients taking medications for a chronic disease who had been on a stable dosage for at least three months were also enrolled. All patients were independent in daily living and medically able to increase physical activity. Many of the patients were overweight (average BMI of 29.5) and 9% of patients smoked. Approximately 35% of patients were hypertensive but on stable medication (16).

Although patients in this trial were instructed to gradually increase physical activity, 30% of patients experienced a musculoskeletal injury annually in this trial. Patients in this trial were given a choice in activity goals (five or more days per week of 30 minutes moderate activity sessions or three or more days per week of 30 minutes vigorous activity sessions). For most patients this meant increasing walking or running by 1.5 to 2 miles per day.

One to four percent of the patients were hospitalized annually for a potential cardiac event. Since there was no usual care condition for this trial it is difficult to know whether or how much the interventions contributed to the adverse effects.

Most of the trials included in this review took precautions to avoid injury either by their exclusion criteria and/or providing an option of moderate rather than vigorous activity. Five of the nine trials included in this review specifically stated that patients were excluded for medical reasons (6, 10, 11, 13, 14). Seven of the nine trials offered a moderate activity option (4, 6, 8, 10-12, 14).

## Feasibility and Costs

Assessment and counseling takes patient and staff time, perhaps explaining why only three trials reported that over 90% of patients received the intended intervention (6, 10, 11). Some of the counseling efficacy studies used additional staffing for assessments (6, 8, 11). One RCT documented that a research staff member spent 5.8 minutes assessing each patient using the PASE assessment tool (6).

The Activity Counseling Trial (14) reported that patients who received both advice and counseling (assistance group) had an average of an extra 2.7 hours with a clinician or health educator per two years, compared to simply being advised to increase physical activity (18 minutes of contact time per two years). Women who received advice, counseling, follow-up counseling phone calls, and classes (counseling group) spent an extra nine hours with the clinician or educator than women who were simply advised. Similarly, men in the counseling group spent an extra five hours with the clinician or educator over the two years.