# Introduction

In 1996, the U.S. Preventive Services Task Force (USPSTF) recommended counseling to promote regular physical activity (PA) for all children and adults based on the evidence of the benefits of increased physical activity, but found insufficient evidence that counseling changed physical activity. Since 1996, several trials (1-14) have examined whether counseling and behavioral interventions in primary care help patients to exercise regularly.

Healthy People 2010 (HP 2010) is a set of U.S. national health objectives. Objective 22-2 is to have at least 30% of all people over age 18 performing "moderate activity for at least 30 minutes, preferably daily"(15). "Moderate activity" has been described as "any activity that makes you work as hard as brisk walking"(16). Objective 22-3 is to have "at least 30% of adults performing vigorous physical activity that promotes the development and maintenance of cardiorespiratory fitness three or more times per week for 20 minutes per session"(15). "Vigorous activity" has been described as activity in which one works "as hard as jogging or running"(16). Two national surveys report that approximately 20% to 25% of adults achieve the moderate activity goal and approximately 15% achieve the vigorous activity goal (17). A recent review of observational studies reported that risk for all-cause mortality dropped by 20% to 30% among adults who met an HP 2010 goal and also for adults who exercised moderately or vigorously at least a few times per month or once per week (18). This same review also reported evidence that an even lower volume of exercise was associated with decreased risk for all-cause mortality. In 1996, the Surgeon General released a comprehensive report that summarized the benefits of exercise (17). The results of this report are summarized in Table 1 in Appendix C.

In 1992, 40% of internists reported assessing patients, but only 25% of physicians reported writing physical activity plans for patients (19, 20). Similarly, 30% of nurse practitioners reportedly assessed patients' physical activity levels, but only 14% gave the patients written plans (19, 20). The 1997 Behavioral Risk Factor Surveillance System (BRFSS) noted that 42% of adult respondents reported receiving physician advice to increase physical activity levels (21, 22). About three-fourths of the patients who reported receiving clinician advice also reported increasing physical activity levels, compared to only half of the patients who reported receiving no clinician advice.

Past reviews of physical activity counseling in many settings suggest that interventions that incorporate behavioral intervention strategies are more effective than those that rely on health education alone (23-25). Effective interventions commonly include identifying health benefits of becoming active, helping the patient acquire skills for reaching or maintaining healthy activity levels including skills for overcoming barriers, encouraging the patient to keep an activity log, and providing ongoing support for progress (24). Follow-up contact via telephone with patients engaging home-based (vs fitness center-based) exercise programs improves the duration of effect (23, 24, 26).

Most behavioral counseling by primary care clinicians condenses assessment, behavior change advice, and counseling into a single 3 to 5-minute encounter with the clinician, and for some, a follow-up session with either the clinician or another member of the health care team. Before the first encounter with the physician, patients often complete a self-report tool (3, 6, 10, 13) or answer selected questions from larger validated health-assessment tools, administered by telephone, in the office waiting area, or in the home (1-3, 6-8, 11). Often, a nurse or research assistant conducts a baseline assessment and places it on the medical chart for review during the clinician's visit (1, 5-7, 10, 13). The clinician uses this information to tailor the intervention to the individual's needs. This counseling may occur in combination with other preventive clinical screenings and discussion of other behavioral changes (2, 5, 7, 8).

In this paper, which was prepared for the USPSTF, we examine whether these efforts to condense and adapt more extensive, time-consuming interventions for use by clinicians in the primary care office setting have been successful. We focus on good and fair-quality studies that are relevant to the key question, Does counseling children, adolescents, adults, and seniors in primary care settings to incorporate physical activity into their daily routines improve sedentary or maintain active physical activity levels?